# References

1 Grossman DC, Curry SJ, Owens DK, . Interventions to Prevent Falls in Community-Dwelling Older Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2018;319(16):1696–704. PMID: 29710141.29710141
2 Vespa J, Medina L, Armstrong DM. Demographic Turning Points for the United States: Population Projections for 2020 to 2060. Current Population Reports, P25-1144. Washington, DC: U.S. Census Bureau,; 2020. PMID: None.
3 Centers for Disease Control and Prevention NCfIPaC. Web-based Injury Statistics Query and Reporting System (WISQARS). https://www.cdc.gov/injury/wisqars/index.html. Accessed 10/23/2023. PMID: none.
4 Moreland B, Kakara R, Henry A. Trends in Nonfatal Falls and Fall-Related Injuries Among Adults Aged ≥65 Years — United States, 2012–2018. MMWR Morb Mortal Wkly Rep. 2020;69(27):875–81. PMID: 32644982.32644982
5 Santos-Lozada AR. Trends in Deaths From Falls Among Adults Aged 65 Years or Older in the US, 1999-2020. JAMA. 2023;329(18):1605–7. PMID: 37159042.37159042
6 Centers for Disease Control and Prevention. Older Adult Fall Prevention: Deaths from Older Adult Falls https://www.cdc.gov/falls/data/fall-deaths.html. Accessed 5/1/2023. PMID: None.
7 Burns E, Kakara R. Deaths from falls among persons aged≥ 65 years—United States, 2007–2016. Morbidity and Mortality Weekly Report. 2018;67(18):509. PMID: 29746456.29746456
8 World Health Organization. Falls. https://www.who.int/news-room/fact-sheets/detail/falls. Accessed 12/27/2021. PMID: None.
9 Court-Brown C, Clement N, Duckworth A, . The changing epidemiology of fall-related fractures in adults. Injury. 2017;48(4):819–24. PMID: 28283181.28283181
10 Morri M, Ambrosi E, Chiari P, . One-year mortality after hip fracture surgery and prognostic factors: a prospective cohort study. Sci Rep. 2019;9(1):18718. PMID: 31822743.31822743
11 Dubljanin-Raspopovic E, Markovic-Denic L, Marinkovic J, . Does early functional outcome predict 1-year mortality in elderly patients with hip fracture? Clin Orthop Relat Res. 2013;471(8):2703–10. PMID: 23546850.23546850
12 Rubenstein LZ, Josephson KR. Falls and their prevention in elderly people: what does the evidence show? Med Clin North Am. 2006;90(5):807–24. PMID: 16962843.16962843
13 Tang VL, Sudore R, Cenzer IS, . Rates of Recovery to Pre-Fracture Function in Older Persons with Hip Fracture: an Observational Study. J Gen Intern Med. 2017;32(2):153–8. PMID: 27605004.27605004
14 Florence CS, Bergen G, Atherly A, . Medical Costs of Fatal and Nonfatal Falls in Older Adults. J Am Geriatr Soc. 2018;66(4):693–8. PMID: 29512120.29512120
15 Hoffman GJ, Hays RD, Shapiro MF, . The Costs of Fall-Related Injuries among Older Adults: Annual Per-Faller, Service Component, and Patient Out-of-Pocket Costs. Health Serv Res. 2017;52(5):1794–816. PMID: 27581952.27581952
16 Jehu DA, Davis JC, Falck RS, . Risk factors for recurrent falls in older adults: A systematic review with meta-analysis. Maturitas. 2021;144:23–8. PMID: 33358204.33358204
17 Meekes WM, Korevaar JC, Leemrijse CJ, . Practical and validated tool to assess falls risk in the primary care setting: a systematic review. BMJ Open. 2021;11(9):e045431. PMID: 34588228.34588228
18 Omana H, Bezaire K, Brady K, . Functional Reach Test, Single-Leg Stance Test, and Tinetti Performance-Oriented Mobility Assessment for the Prediction of Falls in Older Adults: A Systematic Review. Phys Ther. 2021;101(10). PMID: 34244801.34244801
19 Strini V, Schiavolin R, Prendin A. Fall Risk Assessment Scales: A Systematic Literature Review. Nurs Rep. 2021;11(2):430–43. PMID: 34968219.34968219
20 Meyer G, Mohler R, Kopke S. Reducing waste in evaluation studies on fall risk assessment tools for older people. Journal of Clinical Epidemiology. 2018;102:139–43. PMID: 29782996.29782996
21 Mascarenhas M, Hill KD, Barker A, . Validity of the Falls Risk for Older People in the Community (FROP-Com) tool to predict falls and fall injuries for older people presenting to the emergency department after falling. Eur. 2019;16(3):377–86. PMID: 31543730.31543730
22 Lamb SE, Bruce J, Hossain A, . Screening and Intervention to Prevent Falls and Fractures in Older People. New England Journal of Medicine. 2020;383(19):1848–59. PMID: 33211928.33211928
23 Kim J, Lee W, Lee SH. A Systematic Review of the Guidelines and Delphi Study for the Multifactorial Fall Risk Assessment of Community-Dwelling Elderly. Int J Environ Res Public Health. 2020;17(17). PMID: 32825699.32825699
24 Lin CC, Meardon S, O’Brien K. The Predictive Validity and Clinical Application of Stopping Elderly Accidents, Deaths & Injuries (STEADI) for Fall Risk Screening. Adv Geriatr Med Res. 2022;4(3). PMID: 36315107.36315107
25 Ritchey K, Olney A, Chen S, . STEADI Self-Report Measures Independently Predict Fall Risk. Gerontol Geriatr Med. 2022;8:23337214221079222. PMID: 35647219.35647219
26 Centers for Disease Control and Prevention. Algorithm for Fall Risk Screening, Assessment, and Intervention. https://www.cdc.gov/steadi/pdf/STEADI-Algorithm-508.pdf. Accessed 1/26/2022. PMID: None.
27 Centers for Disease Control and Prevention. Important Facts About Falls. https://www.cdc.gov/homeandrecreationalsafety/falls/adultfalls.html. Accessed 1/17/2022. PMID: None.
28 Howland J, Hackman H, Taylor A, . Older adult fall prevention practices among primary care providers at accountable care organizations: A pilot study. PLoS One. 2018;13(10):e0205279. PMID: 30307974.30307974
29 Centers for Medicare & Medicaid Services. Medicare Wellness Visits: Initial Preventive Physical Examination (IPPE). https://www.cms.gov/Outreach-and-Education/Medicare-Learning-Network-MLN/MLNProducts/preventive-services/medicare-wellness-visits.html. Accessed 1/17/2022. PMID: None.
30 Centers for Medicare & Medicaid Services. Medicaid Plan Finder. https://www.medicare.gov/plan-compare/#/?lang=en&year=2022. Accessed 1/17/2022. PMID: None.
31 Ganguli I, Souza J, McWilliams JM, . Practices Caring For The Underserved Are Less Likely To Adopt Medicare’s Annual Wellness Visit. Health Aff (Millwood). 2018;37(2):283–91. PMID: 29401035.29401035
32 Eckstrom E, Parker EM, Shakya I, . Coordinated Care Plan to Prevent Older Adult Falls. Atlanta, GA: National Center for Injury Prevention and Control, Centers for Disease Control and Prevention; 2021. PMID: None.
33 The Royal Australian College of General Practitioners. Guidelines for Preventive Activities in General Practice. East Melbourne, Victoria 3002 Australia: 2016. PMID: None.
34 U.S. Department of Health and Human Services, Office of Disease Prevention and Health Promotion. Physical Activity Guidelines for Americans. Washington, DC: 2021. PMID: None.
35 National Institute on Aging. Prevent Falls and Fractures. https://www.nia.nih.gov/health/prevent-falls-and-fractures. Accessed 12/13/2021. PMID: None.
36 Guirguis-Blake JM, Michael YL, Perdue LA, . Interventions to Prevent Falls in Community-Dwelling Older Adults: A Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 159. AHRQ Publication No. 17-05232-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2018. PMID: 3023493230234932.
37 Guirguis-Blake JM, Michael YL, Perdue LA, . Interventions to Prevent Falls in Older Adults: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2018;319(16):1705–16. PMID: 29710140.29710140
38 U.S. Preventive Services Task Force. Vitamin D, Calcium, or Combined Supplementation for the Primary Prevention of Falls and Fractures in Community-Dwelling Adults: Preventive Medication. An Update for This Topic is In Progress. https://www.uspreventiveservicestaskforce.org/uspstf/draft-update-summary/vitamin-d-calcium-combined-supplementation-primary-prevention-falls-fractures-communitydwelling-adults. Accessed May 5, 2023. PMID: None.
39 Skelton DA, Becker C, Lamb SE, . Prevention of Falls Network Europe: a thematic network aimed at introducing good practice in effective falls prevention across Europe. Eur J Ageing. 2004;1(1):89–94. PMID: 28794706.28794706
40 Sterne JAC, Savovic J, Page MJ, . RoB 2: a revised tool for assessing risk of bias in randomised trials. BMJ. 2019;366:l4898. PMID: 31462531.31462531
41 IntHout J, Ioannidis JP, Borm GF. The Hartung-Knapp-Sidik-Jonkman method for random effects meta-analysis is straightforward and considerably outperforms the standard DerSimonian-Laird method. BMC Med Res Methodol. 2014;14:25. PMID: 24548571.24548571
42 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539–58. PMID: 12111919.12111919
43 Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 [updated March 2011]. Higgins J, Green S, editors: The Cochrane Collaboration; 2011. PMID: None.
44 Peters JL, Sutton AJ, Jones DR, . Comparison of two methods to detect publication bias in meta-analysis. JAMA. 2006;295(6):676–80. PMID: 16467236.16467236
45 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Rockville (MD): Agency for Healthcare Research and Quality; 2008. PMID: None.
46 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589.15615589
47 Bhasin S, Gill TM, Reuben DB, . A Randomized Trial of a Multifactorial Strategy to Prevent Serious Fall Injuries. N Engl J Med. 2020;383(2):129–40. PMID: 32640131.32640131
48 Bhasin S, Gill TM, Reuben DB, . Strategies to Reduce Injuries and Develop Confidence in Elders (STRIDE): A Cluster-Randomized Pragmatic Trial of a Multifactorial Fall Injury Prevention Strategy: Design and Methods. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2018;73(8):1053–61. PMID: 29045582.29045582
49 Bruce J, Hossain A, Lall R, . Fall prevention interventions in primary care to reduce fractures and falls in people aged 70 years and over: the PreFIT three-arm cluster RCT. Health Technol Assess. 2021;25(34):1–114. PMID: 34075875.34075875
50 Bruce J, Lall R, Withers EJ, . A cluster randomised controlled trial of advice, exercise or multifactorial assessment to prevent falls and fractures in community-dwelling older adults: protocol for the prevention of falls injury trial (PreFIT). BMJ Open. 2016;6(1):e009362. PMID: 26781504.26781504
51 Bruce J, Ralhan S, Sheridan R, . The design and development of a complex multifactorial falls assessment intervention for falls prevention: The Prevention of Falls Injury Trial (PreFIT). BMC Geriatrics. 2017;17(1):116. PMID: 28571563.28571563
52 Cameron ID, Fairhall N, Langron C, . A multifactorial interdisciplinary intervention reduces frailty in older people: randomized trial. BMC medicine. 2013;11:65. PMID: 23497404.23497404
53 Ciaschini PM, Straus SE, Dolovich LR, . Community-based intervention to optimise falls risk management: a randomised controlled trial. Age Ageing. 2009;38(6):724–30. PMID: 19767629.19767629
54 Close J, Ellis M, Hooper R, . Prevention of falls in the elderly trial (PROFET): a randomised controlled trial. Lancet. 1999;353(9147):93–7. PMID: 10023893.10023893
55 Cohen MA, Miller J, Xiaomei S, . Prevention Program Lowered The Risk Of Falls And Decreased Claims For Long-Term Services Among Elder Participants. Health Affairs. 2015;34(6):971–7. PMID: 26056202.26056202
56 Conroy S, Kendrick D, Harwood R, . A multicentre randomised controlled trial of day hospital-based falls prevention programme for a screened population of community-dwelling older people at high risk of falls. Age Ageing. 2010;39(6):704–10. PMID: 20823124.20823124
57 Davison J, Bond J, Dawson P, . Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention--a randomised controlled trial. Age Ageing. 2005;34(2):162–8. PMID: 15716246.15716246
58 de Vries OJ, Peeters GM, Elders PJ, . Multifactorial intervention to reduce falls in older people at high risk of recurrent falls: a randomized controlled trial. Arch Intern Med. 2010;170(13):1110–7. PMID: 20625015.20625015
59 Elley CR, Robertson MC, Garrett S, . Effectiveness of a falls-and-fracture nurse coordinator to reduce falls: a randomized, controlled trial of at-risk older adults. J Am Geriatr Soc. 2008;56(8):1383–9. PMID: 18808597.18808597
60 Fairhall N, Aggar C, Kurrle SE, . Frailty Intervention Trial (FIT). BMC Geriatr. 2008;8:27. PMID: 18851754.18851754
61 Fairhall N, Sherrington C, Cameron ID, . A multifactorial intervention for frail older people is more than twice as effective among those who are compliant: complier average causal effect analysis of a randomised trial. J Physiother. 2017;63(1):40–4. PMID: 27993489.27993489
62 Fairhall N, Sherrington C, Lord SR, . Effect of a multifactorial, interdisciplinary intervention on risk factors for falls and fall rate in frail older people: a randomised controlled trial. Age Ageing. 2014;43(5):616–22. PMID: 24381025.24381025
63 Ferrer A, Formiga F, Sanz H, . Multifactorial assessment and targeted intervention to reduce falls among the oldest-old: a randomized controlled trial. Clin Interv Aging. 2014;9:383–93. PMID: 24596458.24596458
64 Finnegan S, Bruce J, Skelton DA, . Development and delivery of an exercise programme for falls prevention: the Prevention of Falls Injury Trial (PreFIT). Physiotherapy. 2018;104(1):72–9. PMID: 28801033.28801033
65 Ganz DA, Siu AL, Magaziner J, . Protocol for serious fall injury adjudication in the Strategies to Reduce Injuries and Develop Confidence in Elders (STRIDE) study. Injury Epidemiology. 2019;6:14. PMID: 31245263.31245263
66 Ganz DA, Yuan AH, Greene EJ, . Effect of the STRIDE fall injury prevention intervention on falls, fall injuries, and health-related quality of life. Journal of the American Geriatrics Society. 2022;70(11):3221–9. PMID: 35932279.35932279
67 Gill TM, Bhasin S, Reuben DB, . Effect of a Multifactorial Fall Injury Prevention Intervention on Patient Well-Being: The STRIDE Study. Journal of the American Geriatrics Society. 2021;69(1):173–9. PMID: 33037632.33037632
68 Gill TM, McGloin JM, Latham NK, . Screening, Recruitment, and Baseline Characteristics for the Strategies to Reduce Injuries and Develop Confidence in Elders (STRIDE) Study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2018;73(11):1495–501. PMID: 30020415.30020415
69 Hendriks MR, Bleijlevens MH, van Haastregt JC, . Lack of effectiveness of a multidisciplinary fall-prevention program in elderly people at risk: a randomized, controlled trial. J Am Geriatr Soc. 2008;56(8):1390–7. PMID: 18662214.18662214
70 Hogan DB, MacDonald FA, Betts J, . A randomized controlled trial of a community-based consultation service to prevent falls. CMAJ. 2001;165(5):537–43. PMID: 11563205.11563205
71 Imhof L, Naef R, Wallhagen MI, . Effects of an advanced practice nurse in-home health consultation program for community-dwelling persons aged 80 and older. J Am Geriatr Soc. 2012;60(12):2223–31. PMID: 23194103.23194103
72 La Porta F, Lullini G, Caselli S, . Efficacy of a multiple-component and multifactorial personalized fall prevention program in a mixed population of community-dwelling older adults with stroke, Parkinson’s Disease, or frailty compared to usual care: The PRE.C.I.S.A. randomized controlled trial. Front Neurol. 2022;13:943918. PMID: 36119666.36119666
73 Lightbody E, Watkins C, Leathley M, . Evaluation of a nurse-led falls prevention programme versus usual care: a randomized controlled trial. Age Ageing. 2002;31(3):203–10. PMID: 12006310.12006310
74 Logan PA, Coupland CA, Gladman JR, . Community falls prevention for people who call an emergency ambulance after a fall: randomised controlled trial. BMJ. 2010;340:c2102. PMID: 20460331.20460331
75 Lord SR, Tiedemann A, Chapman K, . The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(8):1296–304. PMID: 16078954.16078954
76 McMahon S, Greene E, Latham N, . Engagement of older adults in STRIDE’s multifactorial fall injury prevention intervention. Journal of the American Geriatrics Society. 2022;70(11):3116–26. PMID: 35924574.35924574
77 Moller UO, Kristensson J, Midlov P, . Effects of a one-year home-based case management intervention on falls in older people: a randomized controlled trial. J Aging Phys Act. 2014;22(4):457–64. PMID: 24152667.24152667
78 Palvanen M, Kannus P, Piirtola M, . Effectiveness of the Chaos Falls Clinic in preventing falls and injuries of home-dwelling older adults: a randomised controlled trial. Injury. 2014;45(1):265–71. PMID: 23579066.23579066
79 Peeters GM, de Vries OJ, Elders PJ, . Prevention of fall incidents in patients with a high risk of falling: design of a randomised controlled trial with an economic evaluation of the effect of multidisciplinary transmural care. BMC Geriatr. 2007;7:15. PMID: 17605771.17605771
80 Perula LA, Varas-Fabra F, Rodriguez V, . Effectiveness of a multifactorial intervention program to reduce falls incidence among community-living older adults: a randomized controlled trial. Arch Phys Med Rehabil. 2012;93(10):1677–84. PMID: 22609117.22609117
81 Reuben DB, Gazarian P, Alexander N, . The Strategies to Reduce Injuries and Develop Confidence in Elders Intervention: Falls Risk Factor Assessment and Management, Patient Engagement, and Nurse Co-management. Journal of the American Geriatrics Society. 2017;65(12):2733–9. PMID: 29044479.29044479
82 Russell MA, Hill KD, Day LM, . A randomized controlled trial of a multifactorial falls prevention intervention for older fallers presenting to emergency departments. J Am Geriatr Soc. 2010;58(12):2265–74. PMID: 21143436.21143436
83 Salminen M, Vahlberg T, Kivela SL. The long-term effect of a multifactorial fall prevention programme on the incidence of falls requiring medical treatment. Public Health. 2009;123(12):809–13. PMID: 19958918.19958918
84 Salminen MJ, Vahlberg TJ, Salonoja MT, . Effect of a risk-based multifactorial fall prevention program on the incidence of falls. J Am Geriatr Soc. 2009;57(4):612–9. PMID: 19392952.19392952
85 Spice CL, Morotti W, George S, . The Winchester falls project: a randomised controlled trial of secondary prevention of falls in older people. Age Ageing. 2009;38(1):33–40. PMID: 18829689.18829689
86 Tinetti ME, Baker DI, McAvay G, . A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331(13):821–7. PMID: 8078528.8078528
87 van Haastregt JC, Diederiks JP, van Rossum E, . Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321(7267):994–8. PMID: 11039967.11039967
88 Vind AB, Andersen HE, Pedersen KD, . The Effect of a program of Multifactorial Fall Prevention on Health Related Quality of Life, Functional Ability, Fear of Falling and Psychological Well-being. A Randomized Controlled Trial. Aging Clin Exp Res. 2010;22(3):249–54. PMID: 19934621.19934621
89 Vind AB, Andersen HE, Pedersen KD, . An outpatient multifactorial falls prevention intervention does not reduce falls in high-risk elderly Danes. J Am Geriatr Soc. 2009;57(6):971–7. PMID: 19507291.19507291
90 Wagner EH, LaCroix AZ, Grothaus L, . Preventing disability and falls in older adults: a population-based randomized trial. Am J Public Health. 1994;84(11):1800–6. PMID: 7977921.7977921
91 Newbury JW, Marley JE, Beilby JJ. A randomised controlled trial of the outcome of health assessment of people aged 75 years and over. Med J Aust. 2001;175(2):104–7. PMID: 11556409.11556409
92 Ambrens M, van Schooten KS, Lung T, . Economic evaluation of the e-Health StandingTall balance exercise programme for fall prevention in people aged 70 years and over. Age & Ageing. 2022;51(6):01. PMID: 35679193.35679193
93 Arkkukangas M, Johnson ST, Hellstrom K, . Fall Prevention Exercises With or Without Behavior Change Support for Community-Dwelling Older Adults: A Two-Year Follow-Up of a Randomized Controlled Trial. J Aging Phys Act. 2019/06/13 ed2019. p. 34–41. PMID: 31188707.31188707
94 Arkkukangas M, Soderlund A, Eriksson S, . One-Year Adherence to the Otago Exercise Program With or Without Motivational Interviewing in Community-Dwelling Older Adults. J Aging Phys Activity. 2018;26(3):390–5. PMID: 28952864.28952864
95 Arkkukangas M, Soderlund A, Eriksson S, . Fall Preventive Exercise With or Without Behavior Change Support for Community-Dwelling Older Adults: A Randomized Controlled Trial With Short-Term Follow-up. Journal of Geriatric Physical Therapy. 2019;42(1):9–17. PMID: 28244890.28244890
96 Barnett A, Smith B, Lord SR, . Community-based group exercise improves balance and reduces falls in at-risk older people: a randomised controlled trial. Age Ageing. 2003;32(4):407–14. PMID: 12851185.12851185
97 Blank WA, Freiberger E, Siegrist M, . An interdisciplinary intervention to prevent falls in community-dwelling elderly persons: protocol of a cluster-randomized trial [PreFalls]. BMC Geriatr. 2011;11:7. PMID: 21329525.21329525
98 Buchner DM, Cress ME, de Lateur BJ, . The effect of strength and endurance training on gait, balance, fall risk, and health services use in community-living older adults. J Gerontol A Biol Sci Med Sci. 1997;52(4):M218–M24. PMID: 9224433.9224433
99 Buchner DM, Cress ME, Wagner EH, . The Seattle FICSIT/MoveIt study: the effect of exercise on gait and balance in older adults. J Am Geriatr Soc. 1993;41(3):321–5. PMID: 8440857.8440857
100 Buchner DM, Hornbrook MC, Kutner NG, . Development of the common data base for the FICSIT trials. J Am Geriatr Soc. 1993;41(3):297–308. PMID: 8440854.8440854
101 Callisaya ML, Jayakody O, Vaidya A, . A novel cognitive-motor exercise program delivered via a tablet to improve mobility in older people with cognitive impairment - StandingTall Cognition and Mobility. Exp Gerontol. 2021;152:111434. PMID: 34098009.34098009
102 Campbell AJ, Robertson MC, Gardner MM, . Randomised controlled trial of a general practice programme of home based exercise to prevent falls in elderly women. BMJ. 1997;315(7115):1065–9. PMID: 9366737.9366737
103 Chyu MC, James CR, Sawyer SF, . Effects of tai chi exercise on posturography, gait, physical function and quality of life in postmenopausal women with osteopaenia: a randomized clinical study. Clinical Rehabilitation. 2010;24(12):1080–90. PMID: 20702512.20702512
104 Dargent-Molina P, El Khoury F, Cassou B. The ‘Ossebo’ intervention for the prevention of injurious falls in elderly women: background and design. Glob Health Promot. 2013;20(2 Suppl):88–93. PMID: 23678502.23678502
105 Day L, Fildes B, Gordon I, . Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. PMID: 12130606.12130606
106 Delbaere K, Valenzuela T, Lord SR, . E-health StandingTall balance exercise for fall prevention in older people: results of a two year randomised controlled trial. BMJ. 2021;373:n740. PMID: 33824131.33824131
107 El-Khoury F, Cassou B, Latouche A, . Effectiveness of two year balance training programme on prevention of fall induced injuries in at risk women aged 75-85 living in community: Ossebo randomised controlled trial. BMJ. 2015;351:h3830. PMID: 26201510.26201510
108 Fitzharris MP, Day L, Lord SR, . The Whitehorse NoFalls trial: effects on fall rates and injurious fall rates. Age Ageing. 2010;39(6):728–33. PMID: 20817936.20817936
109 Goldberg SE, van der Wardt V, Brand A, . Promoting activity, Independence and stability in early dementia (PrAISED): a, multisite, randomised controlled, feasibility trial. BMC Geriatrics. 2019;19(1):353. PMID: 31842828.31842828
110 Harwood RH, van der Wardt V, Goldberg SE, . A development study and randomised feasibility trial of a tailored intervention to improve activity and reduce falls in older adults with mild cognitive impairment and mild dementia. Pilot feasibility stud. 2018;4:49. PMID: 29468084.29468084
111 Hentschke C, Halle M, Geilhof B, . 24-Months Cluster-Randomized Intervention Trial of a Targeted Fall Prevention Program in a Primary Care Setting. Journal of General Internal Medicine. 2021;08:08. PMID: 34240282.34240282
112 Karinkanta S, Heinonen A, Sievanen H, . A multi-component exercise regimen to prevent functional decline and bone fragility in home-dwelling elderly women: randomized, controlled trial. Osteoporos Int. 2007;18(4):453–62. PMID: 17103296.17103296
113 Karinkanta S, Kannus P, Uusi-Rasi K, . Combined resistance and balance-jumping exercise reduces older women’s injurious falls and fractures: 5-year follow-up study. Age Ageing. 2015;44(5):784–9. PMID: 25990940.25990940
114 Karinkanta S, Nupponen R, Heinonen A, . Effects of exercise on health-related quality of life and fear of falling in home-dwelling older women. J Aging Phys Act. 2012;20(2):198–214. PMID: 22472580.22472580
115 Korpelainen R, Keinanen-Kiukaanniemi S, Heikkinen J, . Effect of impact exercise on bone mineral density in elderly women with low BMD: a population-based randomized controlled 30-month intervention. Osteoporos Int. 2006;17(1):109–18. PMID: 15889312.15889312
116 Korpelainen R, Keinanen-Kiukaanniemi S, Nieminen P, . Long-term outcomes of exercise: follow-up of a randomized trial in older women with osteopenia. Arch Intern Med. 2010;170(17):1548–56. PMID: 20876406.20876406
117 Kovacs E, Prokai L, Meszaros L, . Adapted physical activity is beneficial on balance, functional mobility, quality of life and fall risk in community-dwelling older women: a randomized single-blinded controlled trial. Eur J Phys Rehabil Med. 2013;49(3):301–10. PMID: 23486300.23486300
118 Kronhed AG, Hallberg I, Odkvist L, . Effect of training on health-related quality of life, pain and falls in osteoporotic women. Adv Physiother. 2009;11(3):154–65.
119 Lamb SE, Mistry D, Alleyne S, . Aerobic and strength training exercise programme for cognitive impairment in people with mild to moderate dementia: the DAPA RCT. Health Technology Assessment (Winchester, England). 2018;22(28):1–202. PMID: 29848412.29848412
120 Lipsitz LA, Macklin EA, Travison TG, . A Cluster Randomized Trial of Tai Chi vs Health Education in Subsidized Housing: The MI-WiSH Study. Journal of the American Geriatrics Society. 2019;67(9):1812–9. PMID: 31116883.31116883
121 Logghe IH, Verhagen AP, Rademaker AC, . Explaining the ineffectiveness of a Tai Chi fall prevention training for community-living older people: a process evaluation alongside a randomized clinical trial (RCT). Arch Gerontol Geriatr. 2011;52(3):357–62. PMID: 20965096.20965096
122 Logghe IH, Zeeuwe PE, Verhagen AP, . Lack of effect of Tai Chi Chuan in preventing falls in elderly people living at home: a randomized clinical trial. J Am Geriatr Soc. 2009;57(1):70–5. PMID: 19054193.19054193
123 Luukinen H, Lehtola S, Jokelainen J, . Pragmatic exercise-oriented prevention of falls among the elderly: a population-based, randomized, controlled trial. Prev Med. 2007;44(3):265–71. PMID: 17174387.17174387
124 Merom D, Mathieu E, Cerin E, . Social Dancing and Incidence of Falls in Older Adults: A Cluster Randomised Controlled Trial. PLoS Medicine / Public Library of Science. 2016;13(8):e1002112. PMID: 27575534.27575534
125 Miko I, Szerb I, Szerb A, . Effect of a balance-training programme on postural balance, aerobic capacity and frequency of falls in women with osteoporosis: A randomized controlled trial. J Rehabil Med. 2018;50(6):542–7. PMID: 29767227.29767227
126 Morgan RO, Virnig BA, Duque M, . Low-intensity exercise and reduction of the risk for falls among at-risk elders. J Gerontol A Biol Sci Med Sci. 2004;59(10):1062–7. PMID: 15528779.15528779
127 Ng TP, Feng L, Nyunt MS, . Nutritional, Physical, Cognitive, and Combination Interventions and Frailty Reversal Among Older Adults: A Randomized Controlled Trial. Am J Med. 2015. PMID: 26159634.26159634
128 Ohman H, Savikko N, Strandberg T, . Effects of Exercise on Functional Performance and Fall Rate in Subjects with Mild or Advanced Alzheimer’s Disease: Secondary Analyses of a Randomized Controlled Study. Dement Geriatr Cogn Disord. 2016;41(3–4):233–41. PMID: 27160164.27160164
129 Oliveira JS, Sherrington C, Paul SS, . A combined physical activity and fall prevention intervention improved mobility-related goal attainment but not physical activity in older adults: a randomised trial. J Physiother. 2019;65(1):16–22. PMID: 30581138.30581138
130 Patil R, Karinkanta S, Tokola K, . Effects of Vitamin D and Exercise on the Wellbeing of Older Community-Dwelling Women: A Randomized Controlled Trial. Gerontology. 2016;62(4):401–8. PMID: 26682749.26682749
131 Pitkala KH, Poysti MM, Laakkonen ML, . Effects of the Finnish Alzheimer disease exercise trial (FINALEX): a randomized controlled trial. JAMA Intern Med. 2013;173(10):894–901. PMID: 23589097.23589097
132 Pitkala KH, Raivio MM, Laakkonen ML, . Exercise rehabilitation on home-dwelling patients with Alzheimer’s disease--a randomized, controlled trial. Study protocol. Trials. 2010;11:92. PMID: 20925948.20925948
133 Rikkonen T, Sund R, Koivumaa-Honkanen H, . Effectiveness of exercise on fall prevention in community-dwelling older adults: a 2-year randomized controlled study of 914 women. Age & Ageing. 2023;52(4):01. PMID: 37097767.37097767
134 Robertson MC, Devlin N, Gardner MM, . Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls. 1: Randomised controlled trial. BMJ. 2001;322(7288):697–701. PMID: 11264206.11264206
135 Rosado H, Bravo J, Raimundo A, . Can two multimodal psychomotor exercise programs improve attention, affordance perception, and balance in community dwellings at risk of falling? A randomized controlled trial. BMC Public Health. 2022;21(Suppl 2):2336. PMID: 35818044.35818044
136 Rosado H, Bravo J, Raimundo A, . Effects of two 24-week multimodal exercise programs on reaction time, mobility, and dual-task performance in community-dwelling older adults at risk of falling: a randomized controlled trial. BMC Public Health. 2021;21(Suppl 2):408. PMID: 34758759.34758759
137 Sherrington C, Lord SR, Vogler CM, . A post-hospital home exercise program improved mobility but increased falls in older people: a randomised controlled trial. PLoS ONE. 2014;9(9):e104412. PMID: 25180702.25180702
138 Siegrist M, Freiberger E, Geilhof B, . Fall Prevention in a Primary Care Setting. Dtsch. 2016;113(21):365–72. PMID: 27504699.27504699
139 Soukkio P, Suikkanen S, Kaaria S, . Effects of 12-month home-based physiotherapy on duration of living at home and functional capacity among older persons with signs of frailty or with a recent hip fracture - protocol of a randomized controlled trial (HIPFRA study). BMC Geriatrics. 2018;18(1):232. PMID: 30285645.30285645
140 Stathi A, Greaves CJ, Thompson JL, . Effect of a physical activity and behaviour maintenance programme on functional mobility decline in older adults: the REACT (Retirement in Action) randomised controlled trial. Lancet Public Health. 2022;7(4):e316–e26. PMID: 35325627.35325627
141 Stathi A, Withall J, Greaves CJ, . A community-based physical activity intervention to prevent mobility-related disability for retired older people (REtirement in ACTion (REACT)): study protocol for a randomised controlled trial. Trials. 2018;19(1):228. PMID: 29665854.29665854
142 Suikkanen S, Soukkio P, Aartolahti E, . Effect of 12-Month Supervised, Home-Based Physical Exercise on Functioning Among Persons With Signs of Frailty: A Randomized Controlled Trial. Archives of Physical Medicine & Rehabilitation. 2021;102(12):2283–90. PMID: 34283997.34283997
143 Suikkanen SA, Soukkio PK, Aartolahti EM, . Effects of Home-Based Physical Exercise on Days at Home and Cost-Effectiveness in Pre-Frail and Frail Persons: Randomized Controlled Trial. J Am Med Dir Assoc. 2021;22(4):773–9. PMID: 32694001.32694001
144 Tiedemann A, Paul S, Ramsay E, . What is the effect of a combined physical activity and fall prevention intervention enhanced with health coaching and pedometers on older adults’ physical activity levels and mobility-related goals? Study protocol for a randomised controlled trial. BMC Public Health. 2015;15:477. PMID: 25956926.25956926
145 Tinetti ME, Baker DI, Garrett PA, . Yale FICSIT: risk factor abatement strategy for fall prevention. J Am Geriatr Soc. 1993;41(3):315–20. PMID: 8440856.8440856
146 Tomita M, Fisher N, Ramsey D, . Effects of Virtual-Group Exercise at Home (V-GEAH) on Adherence and Fall Risks in Older Adults with a History of Falling. Gerontology Geriatr Res. 2016;2(3):1018.
147 Tomita MR, Fisher NM, Ramsey D, . Follow-Up of a Virtual-Group-Exercise at Home Program to Reduce Fall Risks. Journal of the American Geriatrics Society. 2019;67(9):1981–3. PMID: 31206588.31206588
148 Trombetti A, Hars M, Herrmann FR, . Effect of music-based multitask training on gait, balance, and fall risk in elderly people: a randomized controlled trial. Arch Intern Med. 2011;171(6):525–33. PMID: 21098340.21098340
149 Tuvemo Johnson S, Anens E, Johansson AC, . The Otago Exercise Program With or Without Motivational Interviewing for Community-Dwelling Older Adults: A 12-Month Follow-Up of a Randomized, Controlled Trial. J Appl Gerontol. 2021;40(3):289–99. PMID: 32114877.32114877
150 Uusi-Rasi K, Kannus P, Karinkanta S, . Study protocol for prevention of falls: a randomized controlled trial of effects of vitamin D and exercise on falls prevention. BMC Geriatr. 2012;12:12. PMID: 22448872.22448872
151 Uusi-Rasi K, Patil R, Karinkanta S, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 2015;175(5):703–11. PMID: 25799402.25799402
152 Uusi-Rasi K, Patil R, Karinkanta S, . A 2-Year Follow-Up After a 2-Year RCT with Vitamin D and Exercise: Effects on Falls, Injurious Falls and Physical Functioning Among Older Women. J Gerontol A Biol Sci Med Sci. 2017;72(9):1239–45. PMID: 28369286.28369286
153 Voukelatos A, Cumming RG, Lord SR, . A randomized, controlled trial of tai chi for the prevention of falls: the Central Sydney tai chi trial. J Am Geriatr Soc. 2007;55(8):1185–91. PMID: 17661956.17661956
154 Voukelatos A, Merom D, Rissel C, . The effect of walking on falls in older people: the ‘Easy Steps to Health’ randomized controlled trial study protocol. BMC Public Health. 2011;11:888. PMID: 22115340.22115340
155 Voukelatos A, Merom D, Sherrington C, . The impact of a home-based walking programme on falls in older people: the Easy Steps randomised controlled trial. Age Ageing. 2015;44(3):377–83. PMID: 25572426.25572426
156 Wayne PM, Gagnon MM, Macklin EA, . The Mind Body-Wellness in Supportive Housing (Mi-WiSH) study: Design and rationale of a cluster randomized controlled trial of Tai Chi in senior housing. Contemporary Clinical Trials. 2017;60:96–104. PMID: 28694204.28694204
157 Gill TM, Pahor M, Guralnik JM, . Effect of structured physical activity on prevention of serious fall injuries in adults aged 70-89: randomized clinical trial (LIFE Study). BMJ. 2016;352:i245. PMID: 26842425.26842425
158 Freiberger E, Haberle L, Spirduso WW, . Long-term effects of three multicomponent exercise interventions on physical performance and fall-related psychological outcomes in community-dwelling older adults: a randomized controlled trial. J Am Geriatr Soc. 2012;60(3):437–46. PMID: 22324753.22324753
159 Kamide N, Shiba Y, Shibata H. Effects on balance, falls, and bone mineral density of a home-based exercise program without home visits in community-dwelling elderly women: a randomized controlled trial. J Physiol Anthropol. 2009;28(3):115–22. PMID: 19483372.19483372
160 Shumway-Cook A, Silver I, Mary L, . Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. J Gerontol A Biol Sci Med Sci. 2007;62(12):1420–7. PMID: 18166695.18166695
161 Sherrington C, Fairhall N, Kirkham C, . Exercise to Reduce Mobility Disability and Prevent Falls After Fall-Related Leg or Pelvic Fracture: RESTORE Randomized Controlled Trial. Journal of General Internal Medicine. 2020;35(10):2907–16. PMID: 32016702.32016702
162 Daly RM, Gianoudis J, Kersh ME, . Effects of a 12-Month Supervised, Community-Based, Multimodal Exercise Program Followed by a 6-Month Research-to-Practice Transition on Bone Mineral Density, Trabecular Microarchitecture, and Physical Function in Older Adults: A Randomized Controlled Trial. Journal of Bone & Mineral Research. 2020;35(3):419–29. PMID: 31498937.31498937
163 Sherrington C, Fairhall N, Kirkham C, . Exercise and fall prevention self-management to reduce mobility-related disability and falls after fall-related lower limb fracture in older people: protocol for the RESTORE (Recovery Exercises and STepping On afteR fracturE) randomised controlled trial. BMC Geriatrics. 2016;16:34. PMID: 26838998.26838998
164 Gianoudis J, Bailey CA, Ebeling PR, . Effects of a targeted multimodal exercise program incorporating high-speed power training on falls and fracture risk factors in older adults: a community-based randomized controlled trial. J Bone Miner Res. 2014;29(1):182–91. PMID: 23775701.23775701
165 Gianoudis J, Bailey CA, Sanders KM, . Osteo-cise: strong bones for life: protocol for a community-based randomised controlled trial of a multi-modal exercise and osteoporosis education program for older adults at risk of falls and fractures. BMC Musculoskelet Disord. 2012;13:78. PMID: 22640372.22640372
166 Smulders E, Weerdesteyn V, Groen BE, . Efficacy of a short multidisciplinary falls prevention program for elderly persons with osteoporosis and a fall history: a randomized controlled trial. Arch Phys Med Rehabil. 2010;91(11):1705–11. PMID: 21044715.21044715
167 Matchar DB, Duncan PW, Lien CT, . Randomized Controlled Trial of Screening, Risk Modification, and Physical Therapy to Prevent Falls Among the Elderly Recently Discharged From the Emergency Department to the Community: The Steps to Avoid Falls in the Elderly Study. Archives of Physical Medicine & Rehabilitation. 2017;98(6):1086–96. PMID: 28202383.28202383
168 Taylor ME, Wesson J, Sherrington C, . Tailored Exercise and Home Hazard Reduction Program for Fall Prevention in Older People With Cognitive Impairment: The i-FOCIS Randomized Controlled Trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2021;76(4):655–65. PMID: 32949456.32949456
169 Chu MM, Fong KN, Lit AC, . An Occupational Therapy Fall Reduction Home Visit Program for Community-Dwelling Older Adults in Hong Kong After an Emergency Department Visit for a Fall. Journal of the American Geriatrics Society. 2017;65(2):364–72. PMID: 27858951.27858951
170 Cockayne S, Pighills A, Adamson J, . Home environmental assessments and modification delivered by occupational therapists to reduce falls in people aged 65 years and over: the OTIS RCT. Health Technol Assess. 2021;25(46):1–118. PMID: 34254934.34254934
171 Cockayne S, Pighills A, Adamson J, . Can occupational therapist-led home environmental assessment prevent falls in older people? A modified cohort randomised controlled trial protocol. BMJ Open. 2018;8(9):e022488. PMID: 30206086.30206086
172 Cockayne S, Pighills A, Fairhurst C, . Home hazard assessment and environmental modification to prevent falls in older people: the OTIS trial. F1000Res. 2021;25 June 2021(500):1–18.34316353
173 Pighills AC, Torgerson DJ, Sheldon TA, . Environmental assessment and modification to prevent falls in older people.[Erratum appears in J Am Geriatr Soc. 2011 Apr;59(4):776]. J Am Geriatr Soc. 2011;59(1):26–33. PMID: 21226674.21226674
174 Stark S, Keglovits M, Somerville E, . Home Hazard Removal to Reduce Falls Among Community-Dwelling Older Adults: A Randomized Clinical Trial. JAMA netw. 2021;4(8):e2122044. PMID: 34463746.34463746
175 Stark S, Somerville E, Keglovits M, . Protocol for the home hazards removal program (HARP) study: a pragmatic, randomized clinical trial and implementation study. BMC Geriatrics. 2017;17(1):90. PMID: 28427336.28427336
176 Stevens M, Holman CD, Bennett N, . Preventing falls in older people: outcome evaluation of a randomized controlled trial. J Am Geriatr Soc. 2001;49(11):1448–55. PMID: 11890582.11890582
177 Blalock SJ, Casteel C, Roth MT, . Impact of enhanced pharmacologic care on the prevention of falls: a randomized controlled trial. Am J Geriatr Pharmacother. 2010;8(5):428–40. PMID: 21335296.21335296
178 Boye ND, van der Velde N, de Vries OJ, . Effectiveness of medication withdrawal in older fallers: results from the Improving Medication Prescribing to reduce Risk Of FALLs (IMPROveFALL) trial. Age & Ageing. 2017;46(1):142–6. PMID: 28181639.28181639
179 Hartholt KA, Boye ND, Van der Velde N, . [Cost] effectiveness of withdrawal of fall-risk increasing drugs versus conservative treatment in older fallers: design of a multicenter randomized controlled trial (IMPROveFALL-study). BMC Geriatr. 2011;11:48. PMID: 21854643.21854643
180 Mott D, Martin B, Breslow R, . The development of a community-based, pharmacistprovided falls prevention MTM intervention for older adults: Relationship building, methods, and rationale. Inov Pharm. 2014;5(1):140. PMID: 25309809.25309809
181 Mott DA, Martin B, Breslow R, . Impact of a medication therapy management intervention targeting medications associated with falling: Results of a pilot study. J Am Pharm Assoc (2003). 2016;56(1):22–8. PMID: 26802916.26802916
182 Polinder S, Boye ND, Mattace-Raso FU, . Cost-utility of medication withdrawal in older fallers: results from the improving medication prescribing to reduce risk of FALLs (IMPROveFALL) trial. BMC Geriatrics. 2016;16(1):179. PMID: 27809792.27809792
183 Romskaug R, Molden E, Straand J, . Cooperation between geriatricians and general practitioners for improved pharmacotherapy in home-dwelling elderly people receiving polypharmacy - the COOP Study: study protocol for a cluster randomised controlled trial. Trials [Electronic Resource]. 2017;18(1):158. PMID: 28372591.28372591
184 Romskaug R, Skovlund E, Straand J, . Effect of Clinical Geriatric Assessments and Collaborative Medication Reviews by Geriatrician and Family Physician for Improving Health-Related Quality of Life in Home-Dwelling Older Patients Receiving Polypharmacy: A Cluster Randomized Clinical Trial. JAMA Intern Med. 2020;180(2):181–9. PMID: 31617562.31617562
185 Dorresteijn TA, Rixt Zijlstra GA, Van Haastregt JC, . Feasibility of a nurse-led in-home cognitive behavioral program to manage concerns about falls in frail older people: a process evaluation. Res Nurs Health. 2013;36(3):257–70. PMID: 23533013.23533013
186 Dorresteijn TA, Zijlstra GA, Ambergen AW, . Effectiveness of a home-based cognitive behavioral program to manage concerns about falls in community-dwelling, frail older people: results of a randomized controlled trial.[Erratum appears in BMC Geriatr. 2016;16:108; PMID: 27220990]. BMC Geriatr. 2016;16:2. PMID: 26739339.26739339
187 Dorresteijn TA, Zijlstra GA, Delbaere K, . Evaluating an in-home multicomponent cognitive behavioural programme to manage concerns about falls and associated activity avoidance in frail community-dwelling older people: Design of a randomised control trial [NCT01358032]. BMC Health Serv Res. 2011;11:228. PMID: 21933436.21933436
188 Kempen GI, Oude Wesselink SF, van Haastregt JC, . Long-term effect on mortality of a multicomponent cognitive behavioural group intervention to reduce fear of falling in older adults: a randomised controlled trial. Age Ageing. 2011;40(4):519–23. PMID: 21551460.21551460
189 Lim ML, Tran M, van Schooten KS, . A Self-Guided Online Cognitive Behavioural Therapy to Reduce Fear of Falling in Older People: a Randomised Controlled Trial. Int J Behav Med. 2022;02:02. PMID: 35655058.35655058
190 Zijlstra GA, van Haastregt JC, Ambergen T, . Effects of a multicomponent cognitive behavioral group intervention on fear of falling and activity avoidance in community-dwelling older adults: results of a randomized controlled trial. J Am Geriatr Soc. 2009;57(11):2020–8. PMID: 19793161.19793161
191 Clemson L, Cumming RG, Kendig H, . The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J Am Geriatr Soc. 2004;52(9):1487–94. PMID: 15341550.15341550
192 Caristia S, Campani D, Cannici C, . Physical exercise and fall prevention: A systematic review and meta-analysis of experimental studies included in Cochrane reviews. Geriatr Nurs. 2021;42(6):1275–86. PMID: 34555570.34555570
193 de Souto Barreto P, Rolland Y, Vellas B, . Association of Long-term Exercise Training With Risk of Falls, Fractures, Hospitalizations, and Mortality in Older Adults: A Systematic Review and Meta-analysis. JAMA Intern Med. 2019;179(3):394–405. PMID: 30592475.30592475
194 Elliott S, Leland NE. Occupational Therapy Fall Prevention Interventions for Community-Dwelling Older Adults: A Systematic Review. Am J Occup Ther. 2018;72(4):7204190040p1–p11. PMID: 29953828.29953828
195 Hopewell S, Adedire O, Copsey BJ, . Multifactorial and multiple component interventions for preventing falls in older people living in the community. Cochrane Database Syst Rev. 2018;7:CD012221. PMID: 30035305.30035305
196 Hopewell S, Copsey B, Nicolson P, . Multifactorial interventions for preventing falls in older people living in the community: a systematic review and meta-analysis of 41 trials and almost 20 000 participants. Br J Sports Med. 2020;54(22):1340–50. PMID: 31434659.31434659
197 Klempel N, Blackburn NE, McMullan IL, . The Effect of Chair-Based Exercise on Physical Function in Older Adults: A Systematic Review and Meta-Analysis. Int J Environ Res Public Health. 2021;18(4). PMID: 33669357.33669357
198 Sherrington C, Fairhall NJ, Wallbank GK, . Exercise for preventing falls in older people living in the community. Cochrane Database Syst Rev. 2019;1:CD012424. PMID: 30703272.30703272
199 Sherrington C, Fairhall N, Kwok W, . Evidence on physical activity and falls prevention for people aged 65+ years: systematic review to inform the WHO guidelines on physical activity and sedentary behaviour. Int J Behav Nutr Phys Act. 2020;17(1):144. PMID: 33239019.33239019
200 Zhao R, Bu W, Chen X. The efficacy and safety of exercise for prevention of fall-related injuries in older people with different health conditions, and differing intervention protocols: a meta-analysis of randomized controlled trials. BMC Geriatr. 2019;19(1):341. PMID: 31795944.31795944
201 Hamer MK, DeCamp M, Bradley CJ, . Adoption and Value of the Medicare Annual Wellness Visit: A Mixed-Methods Study. Med Care Res Rev. 2023:10775587231166037. PMID: 37098854.37098854
202 National Institutes of Health, U.S. National Library of Medicine. Electronic Strategies for Tailored Exercise to Prevent FallS (eSTEPS). https://clinicaltrials.gov/ct2/show/study/NCT04993781#contacts. Accessed May 5, 2023. PMID: None.
203 Montero-Odasso M, van der Velde N, Martin FC, . World guidelines for falls prevention and management for older adults: a global initiative. Age Ageing. 2022;51(9). PMID: 36178003.36178003
204 National Institute for Health and Care Excellence. Falls in Older People: Assessing Risk and Prevention. United Kingdom: 2013. PMID: None.
205 Panel on Prevention of Falls in Older Persons, American Geriatrics Society and British Geriatrics Society. Summary of the Updated American Geriatrics Society/British Geriatrics Society Clinical Practice Guideline for Prevention of Falls in Older Persons. Journal of the American Geriatrics Society. 2011;59(1):148–57. PMID: 21226685.21226685