# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Howard Tracer, MD, at the Agency for Healthcare Research and Quality; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; National Institute on Aging, National Institute on Minority Health and Health Disparities, National Institute of Child Health and Human Development, and the Office of Research on Women’s Heath for providing federal partner review of the draft report; David Ganz, MD, PhD, Manuel Montero-Odasso, MD, PhD, AGSF, FGSA, FRCPC, and Elizabeth Phelan, MD, MS, who provided expert review of the draft report; and Melinda Davies, MAIS, and Jill Pope, BS, for technical and editorial assistance at the Center for Health Research.