# Chapter 4 Discussion

## Summary of Evidence

We conducted a systematic review to support the USPSTF in updating its recommendation on falls prevention in older community-dwelling adults. A summary of evidence for each intervention type appears in Tables 4 and 5. Of the 83 included trials, 32 were newly identified trials reporting falls, people with falls, or fall-related injuries in average- and increased-risk older adults: three new multifactorial, 19 new exercise, three new exercise plus education, two new exercise plus environmental, three new environmental, two new medication review, one new psychological, and no new education-only intervention trials. The largest bodies of literature evaluated within this review were multifactorial and exercise interventions, which included 28 trials (N=27,784) and 37 trials (N=16,117), respectively. Our findings suggest that there is a statistically significant reduction only in the number of falls with multifactorial interventions and a statistically significant reduction in multiple fall-related outcomes with exercise interventions. These overall conclusions are generally consistent with our previous review,^37^ with the addition of newly published trials as well as trials solely recruiting specific populations with mild dementia, osteoporosis, osteoarthritis, and sarcopenia. In fact, there were few trials in these populations.^101,^ ^103,^ ^109,^ ^118,^ ^119,^ ^125,^ ^128,^ ^162^ Of note, this update did not include vitamin D interventions, as another in-process review will address the effectiveness of vitamin D to prevent falls and fractures.^38^ Our findings are likewise consistent with other reviews of exercise and multifactorial interventions in community-dwelling older adults.^192–200^

Table 4 Strength of Evidence: Multifactorial and Exercise Intervention Trials

Intervention | Number of included studies | Summary of findings | Consistency and precision | Other limitations | Strength of evidence^*^ | Applicability
Multifactorial | k=28; n random=27,784 | Falls:; IRR, 0.84 (95% CI, 0.74 to 0.95); I^2^=85.0%; k=20, n analyzed=22,115 | Consistent, precise | Heterogenous assessment interventions and referrals.; Heterogeneous populations as reflected in wide variation in baseline falls risk; heterogeneous interventions; trials typically powered for falls and not other outcomes. | Moderate for benefit | Populations studied older community-dwelling adults at both average and increased risk for falls. Most participants were at increased risk based on history of previous fall.; Most studies took place outside the US but results are generalizable. Implementation of this multi-step, complex intervention would be challenging in any setting.; Populations studied were largely those at increased risk of falls based on history of previous fall.
Multifactorial | k=28; n random=27,784 | People with 1+ fall:; RR, 0.96 (95% CI, 0.91 to 1.02); I^2^=48.2%; k=26, n analyzed=23,626 | Inconsistent, imprecise | | Low for no benefit
Multifactorial | k=28; n random=27,784 | People with 2+ falls:; RR, 0.99 (95% CI, 0.94 to 1.04); I^2^=0.0%; k=11, n analyzed=14,471 | Inconsistent, imprecise | | Low for no benefit
Multifactorial | k=28; n random=27,784 | Falls resulting in injury or medical care:; IRR, 0.92 (95% CI, 0.84 to 1.01); I^2^=21.8%; k=12, n analyzed=10,563 | Inconsistent, imprecise | | Low for no benefit
Multifactorial | k=28; n random=27,784 | People with fall resulting in injury or medical care:; RR, 0.92 (95% CI, 0.83 to 1.02); I^2^=47.3%; k=13, n analyzed=13,460 | Inconsistent, imprecise | | Low for no benefit
Multifactorial | k=28; n random=27,784 | Fall-related fractures:; IRR, 1.01 (95% CI, 0.81 to 1.26); I^2^=34.0%; k=7, n analyzed=15,211 | Inconsistent, imprecise | | Low for no benefit
Multifactorial | k=28; n random=27,784 | People with fall-related fracture:; RR, 0.86 (95% CI, 0.60 to 1.24); I^2^=49.0%; k=7, n analyzed=13,912 | Inconsistent, imprecise | | Low for no benefit
Multifactorial | k=28; n random=27,784 | Mortality:; RR, 1.01 (95% CI, 0.88 to 1.17); I^2^=0%; k=24, n analyzed=21,596 | Inconsistent, imprecise | | Low for no benefit
Multifactorial | k=28; n random=27,784 | Harms:; Rare, minor, and associated with the exercise components; k=5, n analyzed=4,199 | Inconsistent, imprecise | Harms sparsely reported and often only reported in intervention arm. | Insufficient
Exercise | k=37; n random=16,117 | Falls:; IRR, 0.85 (95% CI, 0.75 to 0.96); I^2^=82.7%; k=29, n analyzed=14,475 | Consistent, precise | Heterogeneous populations as reflected in wide variation in baseline falls risk; heterogeneous interventions; trials typically powered for falls and not other outcomes.; Heterogeneous exercise interventions: individual vs. group; multiple different exercise components administered; different program frequencies and durations. | Moderate for benefit | Applicable to older community-dwelling populations at both average and increased risk for falls. Most participants in trials were at increased risk based on history of previous fall.; Applicable to interventions (individual PT and exercise classes) that are typically available in the US.; No single exercise/PT program protocol appears as a “best” model. Nearly all programs include gait/balance/functional training and strength/resistance.; Adherence to exercise classes may be variable in real world settings.
Exercise | k=37; n random=16,117 | People with 1+ fall:; RR, 0.92 (95% CI, 0.87 to 0.98); I^2^=24.3%; k=25, n analyzed=13,384 | Consistent, precise | | Moderate for benefit
Exercise | k=37; n random=16,117 | People with 2+ falls:; RR, 0.77 (95% CI, 0.57 to 1.04); I^2^=45.0%; k=9, n analyzed=8,502 | Consistent, imprecise | | Low for no benefit
Exercise | k=37; n random=16,117 | Falls resulting in injury or medical care:; IRR, 0.84 (95% CI, 0.74 to 0.95); I^2^=14.6%; k=12, n analyzed=3,984 | Consistent, precise | | Low for benefit
Exercise | k=37; n random=16,117 | Fall-related fractures:; IRR, 0.81 (95% CI, 0.57 to 1.15); I^2^= 39.1%; k=8, n analyzed=8,537 | Inconsistent, imprecise | | Low for no benefit
Exercise | k=37; n random=16,117 | People with fall resulting in injury or medical care:; RR, 0.90 (95% CI, 0.79 to 1.02); I^2^=26.7%; k=9, n analyzed=3,924 | Consistent, imprecise | | Low for no benefit
Exercise | k=37; n random=16,117 | People with fall-related fracture:; RR range, 0.36 (95% CI, 0.15 to 0.89) to 1.95 (95% CI, 0.22 to 17.3); k=4, n analyzed=7994 | Inconsistent, imprecise | | Insufficient
Exercise | k=37; n random=16,117 | Mortality:; RR, 0.87 (95% CI, 0.71 to 1.06); I^2^=0.0%; k=15, n analyzed=10,461 | Consistent, imprecise | | Low for no benefit
Exercise | k=37; n random=16,117 | Harms; Generally minor musculoskeletal side effects; serious side effects were generally very rare (<1%).; k=19, n analyzed=6,985 | Consistent, imprecise | Harms were sparsely reported and often only reported for the intervention arm. | Low for harm

* For our review-of-reviews method, we adopted the strength of the overall body of evidence assigned within the primary systematic review. In most cases, these grades were based on the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group definitions, which consider study limitations, consistency of effect, imprecision, indirectness, and publication bias. Where strength of evidence grades were not available, we adapted the EPC approach to assign an overall strength of evidence grade based on consensus discussions involving at least two reviewers.

Abbreviations: CI = confidence interval; IRR = incidence rate ratio; k = number of studies; n = number of participants; PT = physical therapy; RR = relative risk; US = United States.

Table 5 Strength of Evidence: Other Interventions

Intervention | Number of included studies | Summary of findings | Consistency and precision | Other limitations | Strength of evidence^*^ | Applicability
Exercise + Edu | k=4; n random= 1,047 | Falls:; IRR range, 0.61 (95% CI, 0.40, 0.94) to 1.08 (95% CI, 0.70 to 1.67); k=4, n analyzed=1,043 | Consistent Imprecise | Few heterogenous trials with mixed results | Low for no benefit | Intervention relevant to older community-dwelling populations at average and increased risk for falls; however, trials included only those at increased risk for falls.; Exercise programs may be accessible in the US.; Education programs variable.
Exercise + Edu | k=4; n random= 1,047 | People with 1+ fall:; RR range, 0.87 (95% CI, 0.57 to 1.34) to 1.07 (95% CI, 0.57 to 2.00); k=4, n analyzed=1,043 | Inconsistent Imprecise | Few heterogenous trials with mixed results | Low for no benefit
Exercise + Edu | k=4; n random= 1,047 | People with 2+ falls:; RR, 1.0 (95% CI, 0.65 to 1.53) and 1.59 (95% CI, 0.67 to 3.79); k=2, n analyzed=498 | Inconsistent, imprecise | Few heterogenous trials with mixed results | INSUFFICIENT
Exercise + Edu | k=4; n random= 1,047 | Falls resulting in injury or medical care:; IRR range, 0.58 (95% CI, 0.33 to 1.01) to 1.02 (0.61 to 1.69); k=3, n analyzed=881 | Consistent Imprecise | Few heterogenous trials with mixed results | Low for no benefit
Exercise + Edu | k=4; n random= 1,047 | Mortality:; RR, 0.67 (95% CI, 0.11 to 3.97) and 1.0 (95% CI, 0.06 to 15.72); k=2, n analyzed=615 | Inconsistent Imprecise | Few heterogenous trials with mixed results | INSUFFICIENT
Exercise + Edu | k=4; n random= 1,047 | Harms; Two trials reported no AEs in IG, two trials reported mostly musculoskeletal side effects associated with exercise intervention in IG; k=4, n analyzed=522 | Consistent, imprecise | Few trials, no trials ascertained AEs in the CG. Ascertainment measurements unclear for harms. | Low for harm
Exercise + Environment | k=3; n random= 935 | Falls:; IRR, 0.73 (95% CI, 0.60 to 0.90) and 0.78 (95% CI, 0.57 to 1.07); k=2, n analyzed=581 | Consistent Imprecise | Few heterogenous trials with mixed results. | INSUFFICIENT | Intervention relevant to older adult community-dwelling populations at average and increased risk for falls; however, trials only recruited participants at increased risk for falls.
Exercise + Environment | k=3; n random= 935 | People with 1+ fall:; RR range, 0.81 (95% CI, 0.60 to 1.08) to 0.99 (95% CI, 0.82 to 1.19); k=3, n analyzed=935 | Consistent, imprecise | Few heterogenous trials with mixed results. | Low for no benefit | Intervention relevant to older adult community-dwelling populations at average and increased risk for falls; however, trials only recruited participants at increased risk for falls.
Exercise + Environment | k=3; n random= 935 | People with 2+ falls:; RR, 0.68 (95% CI, 0.46 to 1.01) and 0.73 (95% CI, 0.54 to 0.99); k=2, n analyzed=581 | Consistent, imprecise | Few heterogenous trials with mixed results. | INSUFFICIENT | Intervention relevant to older adult community-dwelling populations at average and increased risk for falls; however, trials only recruited participants at increased risk for falls.
Exercise + Environment | k=3; n random= 935 | Falls resulting in injury:; IRR, 0.88 (95% CI, 0.67 to 1.15) and 1.18 (95% CI, 0.76 to 1.83); k=2, n analyzed=581 | Inconsistent Imprecise | Few heterogenous trials with mixed results. | INSUFFICIENT | Intervention relevant to older adult community-dwelling populations at average and increased risk for falls; however, trials only recruited participants at increased risk for falls.
Exercise + Environment | k=3; n random= 935 | Mortality:; RR, 0.34 (95% CI, 0.09 to 1.23); k=1, n analyzed=309 | Consistency NA, Imprecise | Few heterogenous trials with mixed results. | INSUFFICIENT | Intervention relevant to older adult community-dwelling populations at average and increased risk for falls; however, trials only recruited participants at increased risk for falls.
Exercise + Environment | k=3; n random= 935 | Harms: No trials reported on harms | NA | No trials | INSUFFICIENT | Intervention relevant to older adult community-dwelling populations at average and increased risk for falls; however, trials only recruited participants at increased risk for falls.
Environment | k=6; n random= 4,162 | Falls:; IRR, 0.83 (95% CI, 0.59 to 1.18); I^2^=82.2%; k=6, n analyzed=3,956 | Inconsistent, Imprecise | Small number of trials. Some studies implemented modifications and others only made recommendations. | Low for no benefit | Intervention relevant to older community-dwelling populations at average and increased risk for falls.
Environment | k=6; n random= 4,162 | People with 1+ fall:; RR, 0.94 (95% CI, 0.83 to 1.07); I^2^=20.3%; k=5, n analyzed=2,242 | Consistent, imprecise | Small number of trials. Some studies implemented modifications and others only made recommendations. | Low for no benefit | Intervention relevant to older community-dwelling populations at average and increased risk for falls.
Environment | k=6; n random= 4,162 | People with 2+ falls:; RR range, 0.36 (95% CI, 0.07 to 1.75) to 1.04 (95% CI, 0.89 to 1.22); k=4, n analyzed=2,077 | Consistent, imprecise | Small number of trials. Some studies implemented modifications and others only made recommendations. | Low for no benefit | Intervention relevant to older community-dwelling populations at average and increased risk for falls.
Environment | k=6; n random= 4,162 | Falls resulting in injury:; IRR, 0.97 (95% CI, 0.75 to 1.26) and 1.06 (95% CI, 0.93 to 1.21); k=2, n analyzed=1,604 | Inconsistent Imprecise | Small number of trials. Some studies implemented modifications and others only made recommendations. | INSUFFICIENT | Intervention relevant to older community-dwelling populations at average and increased risk for falls.
Environment | k=6; n random= 4,162 | Mortality:; RR, 1.87 (95% CI, 0.87 to 4.01); k=1, n analyzed=1,201 | Consistency NA, Imprecise | Small number of trials. Some studies implemented modifications and others only made recommendations. | INSUFFICIENT | Intervention relevant to older community-dwelling populations at average and increased risk for falls.
Environment | k=6; n random= 4,162 | Harms: No serious AEs directly related to the IG (k=1, n=430); No AEs during the trial (k=1, n analyzed=175) | Consistent, imprecise | Small number of trials. Some studies implemented modifications and others only made recommendations. | INSUFFICIENT | Intervention relevant to older community-dwelling populations at average and increased risk for falls.
Medication review/modification | k=4; n random= 1,052 | Falls:; IRR, 1.01 (95% CI, 0.81 to 1.26); k=1, n analyzed=186 | Consistency NA, Imprecise | Small number of trials. Outcomes reported variably across trials.; All study IGs included at least a one-time medication assessment but followup varied and may have additionally included time to PCP contact or modification implementation.; Adherence was generally <50%. | INSUFFICIENT | Intervention relevant to populations at average and increased risk for falls.; Three of four trials were conducted in the US.; Only two trials were conducted in clinical setting by geriatrician; the other two were conducted in pharmacy by pharmacist.
Medication review/modification | k=4; n random= 1,052 | People with 1+ fall:; RR range, 1.02 (95% CI, 0.79 to 1.31) to 1.16 (95% CI, 0.55 to 2.41); k=3, n analyzed=846; OR, 0.75 (95% CI, 0.35 to 1.60); k=1, n analyzed=158 | Inconsistent, imprecise | | Low for no benefit
Medication review/modification | k=4; n random= 1,052 | People with 2+ falls:; RR, 1.16 (95% CI, 0.79 to 1.71) and 2.10 (95% CI, 0.56 to 7.83); k=2, n analyzed=660 | Consistent, imprecise | | INSUFFICIENT
Medication review/modification | k=4; n random= 1,052 | Falls resulting in injury:; IRR, 0.87 (95% CI, 0.62 to 1.24); k=1, n analyzed=186 | Consistency NA, Imprecise | | INSUFFICIENT
Medication review/modification | k=4; n random= 1,052 | Mortality:; RR, 0.40 (95% CI, 0.10 to 1.55) and 1.50 (95% CI, 0.26 to 8.77); k=2, n analyzed=344 | Inconsistent Imprecise | | INSUFFICIENT
Medication review/modification | k=4; n random= 1,052 | Harms: No trials reported on harms | NA | | INSUFFICIENT
Psychological | k=3; n random= 979 | Falls:; IRR, 95% CI, 0.65 to 1.13) and 0.86 (95% CI, 0.65 to 1.14); k=2, n analyzed=886 | Consistent, imprecise | Small number of studies. | INSUFFICIENT | Intervention relevant to populations at average and increased risk for falls.; Both non-US trials, with intervention facilitated by a nurse. Results applicable to US population.
Psychological | k=3; n random= 979 | People with 1+ fall:; RR, 0.72 (95% CI, 0.58 to 0.90) and 0.96 (95% CI, 0.80 to 1.15); OR, 1.40 (95% CI, 0.45 to 4.37); k=3, n analyzed=936 | Inconsistent, imprecise | Small number of studies. | INSUFFICIENT | Intervention relevant to populations at average and increased risk for falls.; Both non-US trials, with intervention facilitated by a nurse. Results applicable to US population.
Psychological | k=3; n random= 979 | People with 2+ falls:; RR, 0.59 (95% CI, 0.43 to 0.81) and 0.89 (95% CI, 0.67 to 1.19); k=2, n analyzed=886 | Consistent, imprecise | Small number of studies. | INSUFFICIENT | Intervention relevant to populations at average and increased risk for falls.; Both non-US trials, with intervention facilitated by a nurse. Results applicable to US population.
Psychological | k=3; n random= 979 | Falls resulting in injury:; IRR, 0.78 (95% CI, 0.45 to 1.35) and 1.42 (95% CI, 0.96 to 2.10); k=2, n analyzed=886 | Inconsistent, Imprecise | Small number of studies. | INSUFFICIENT | Intervention relevant to populations at average and increased risk for falls.; Both non-US trials, with intervention facilitated by a nurse. Results applicable to US population.
Psychological | k=3; n random= 979 | Mortality:; RR, 0.98 (95% CI, 0.77 to 1.25) and 1.01 (95% CI, 0.36 to 2.81); k=2, n analyzed=928 | Consistent, Imprecise | Small number of studies. | INSUFFICIENT | Intervention relevant to populations at average and increased risk for falls.; Both non-US trials, with intervention facilitated by a nurse. Results applicable to US population.
Psychological | k=3; n random= 979 | Harms: No AEs or side effects reported; k=1, n analyzed=540 | NA | Small number of studies. | INSUFFICIENT | Intervention relevant to populations at average and increased risk for falls.; Both non-US trials, with intervention facilitated by a nurse. Results applicable to US population.
Education | k=1; n random= 310 | No. of falls:; IRR, 0.68 (95% CI, 0.57 to 0.83); k=1, n analyzed=310 | Consistency NA, Imprecise | Single, small trial. | INSUFFICIENT | Standardized education protocol applied to adults at increased risk of falling. Conducted in Australia.
Education | k=1; n random= 310 | People with 1+ fall:; RR, 0.90 (95% CI, 0.73 to 1.10); k=1, n analyzed=310 | Consistency NA, Imprecise | Single, small trial. | INSUFFICIENT | Standardized education protocol applied to adults at increased risk of falling. Conducted in Australia.
Education | k=1; n random= 310 | People with 2+ falls:; RR, 0.74 (95% CI, 0.52 to 1.04); k=1, n analyzed=310 | Consistency NA, Imprecise | Single, small trial. | INSUFFICIENT | Standardized education protocol applied to adults at increased risk of falling. Conducted in Australia.
Education | k=1; n random= 310 | No. of falls resulting in injury:; k=0 | NA | Single, small trial. | INSUFFICIENT | Standardized education protocol applied to adults at increased risk of falling. Conducted in Australia.
Education | k=1; n random= 310 | Mortality:; k=0 | NA | Single, small trial. | INSUFFICIENT | Standardized education protocol applied to adults at increased risk of falling. Conducted in Australia.
Education | k=1; n random= 310 | Harms:; k=0 | NA | Single, small trial. | INSUFFICIENT | Standardized education protocol applied to adults at increased risk of falling. Conducted in Australia.

* For our review-of-reviews method, we adopted the strength of the overall body of evidence assigned within the primary systematic review. In most cases, these grades were based on the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group definitions, which consider study limitations, consistency of effect, imprecision, indirectness, and publication bias. Where strength of evidence grades were not available, we adapted the EPC approach to assign an overall strength of evidence grade based on consensus discussions involving at least two reviewers.

Abbreviations: AE = adverse event; CI = confidence interval; Edu = education; IRR = incidence rate ratio; k = number of studies; n = number of participants; NA = not applicable; OR = odds ratio; RR = relative risk; US = United States.

For multifactorial interventions, similar to the previous review,^37^ only the number of falls outcome was statistically significant in the pooled analysis. There were three new fair- or good-quality trials^47,^ ^49,^ ^72^ that were added to the evidence base for this update; however, these trials had null findings for their primary outcomes. One hypothesis for these results is that the contemporary standard of care may provide a level of risk modification in the control group (falls risk assessment, medication review, exercise referrals) that may diminish relative benefits seen in the intervention. Some of the trials included a universally recommended exercise component,^55,^ ^59,^ ^78,^ ^80,^ ^84^ while others provided exercise referrals only to some participants based on the initial risk assessment.^47,^ ^49,^ ^53,^ ^57–59,^ ^62,^ ^63,^ ^70,^ ^75,^ ^77,^ ^78,^ ^82,^ ^85,^ ^86,^ ^89,^ ^90^ Furthermore, the systematic multifactorial interventions in these trials were extensive in their assessment and referrals; there was adherence drop off at each step of the process, which may have diminished potential effectiveness. The effectiveness of such multistep interventions may require extensive monitoring and followup to ensure adherence.

Evidence is most consistent across multiple fall-related outcomes for the exercise trials. For exercise interventions, the included trials doubled in number compared to our previous review, and the conclusions are mostly similar.^37^ There remains a statistically significant association with number of falls, people with a fall, and injurious falls. In contrast to the previous review, there is no longer a statistically significant association between exercise and people with an injurious fall. This change in conclusion for this one fall-related outcome and the discordance across fall-related outcomes cannot be readily explained as the clinical and statistical heterogeneity in this body of evidence are substantial. We explored heterogeneity by various study, population, and intervention characteristics and found no patterns that suggested that any of these variables altered treatment effectiveness. Furthermore, two exercise trials reported within-study subgroup analyses for falls and/or fracture reporting no interaction by age, sex, history of falls, frailty, and/or cognitive impairment.^49,^ ^106^ In terms of exercise harms, theoretically, increasing physical activity could lead to more frequent falls and injuries, but the trial literature is too limited to confirm this idea. Some of the exercise intervention trials and multifactorial interventions with exercise components have reported largely minor adverse effects associated with exercise, including muscle soreness; injurious falls occurring during exercise sessions were rare.^49,^ ^106,^ ^120^

For all other interventions, conclusions were limited by few trials for each intervention type and the availability of new trials could alter effect direction and size considerably.

To determine the absolute benefit of multifactorial and exercise interventions, we estimated the number of falls and people with a fall that could be prevented based on the pooled relative effect sizes and confidence intervals from our review and both fall rates from the included trials and national falls data^4^ (Figure 34). These estimates should be interpreted with caution as they may suggest a false precision given the heterogeneity of intervention protocols and population characteristics for any given program and clinical population. In a hypothetical population of 1,000 older adults, based on national fall rates, multifactorial interventions would be expected to prevent between 36 and 186 falls. Exercise interventions would be expected to prevent 29 to 179 falls and 6 to 36 people from experiencing a fall, and 9 to 44 falls resulting in injury. These absolute benefits would be greater in populations at higher risk for falls. It is important to underscore that overall, the participants in the multifactorial and exercise trials were at higher risk for falls than the national average and absolute benefits will be greater in higher risk populations. Furthermore, the multifactorial trial populations were at even higher risk for falls compared to the exercise trial populations (falls: weighted mean, 1.46 falls per person-year versus 1.16 falls per person-year, respectively; weighted mean percent of people with one or more falls: 48.4% versus 41.4%, respectively).

Figure 34 Absolute Reduction in Falls and Falls Resulting in Injury^*^ * In a hypothetical population of 1,000 older adults with a fall rate of 714 falls/1,000 person-years, 27.5% older adults with a fall, fall injury rate of 170 fall injuries/1,000 person-years, and 10.2% older adults with a fall injury (based on 2018 BRFSS data,^4^) and using the lower confidence interval, point estimate, and upper confidence interval from our pooled results, this figure estimates the reductions in the fall-related events/people.

Figure 34 shows the number of falls and people with a fall that could be prevented based on the pooled relative effect sizes and confidence intervals from the current review and both falls rates from the included trials and national falls data. Briefly, in a hypothetical population of 1,000 older adults, based on national fall rates, multifactorial interventions would be expected to prevent between 36 and 186 falls. Exercise interventions would be expected to prevent 29 to 179 falls and 6 to 36 people from experiencing a fall, and 9 to 44 falls resulting in injury.

## Falls and Fall-Related Outcomes

Most trials were designed to be powered for falls. However, the authors often assumed a larger difference between the intervention and control groups than what we have found in our review. Both falls and people with a fall represent clinically meaningful outcomes. Since each fall could result in injury, an intervention that reduces the number of falls could provide an important public health benefit by reducing the number of injuries and thus overall morbidity. Likewise, reducing the number of people experiencing a fall may represent an important outcome to individuals seeking to prevent the first fall and subsequent injury, activity limitation, and functional decline.

For effective interventions, trials would ideally show that interventions lead to fewer falls, fewer people with a fall, and in turn, fewer fall-induced injuries. We attempted to increase our power to analyze the effect of interventions on injuries by creating a composite category of “falls resulting in injury or medical care” (defined as a trial-reported injurious fall, fall-induced injury, or fall with injury resulting in medical attention), although we recognized that the severity of injuries may vary widely even among falls that lead to visits to an ED. For exercise interventions, we found a reduction in the number of injurious falls and people with injurious falls. The available evidence on injurious falls or people with injurious falls for the remaining intervention categories is either too limited or findings suggest no effect. However, concluding that interventions other than exercise have no effect on fall-related injuries would be premature given that so few of the trials were designed to have adequate power for preventing injury (or fracture). The uncertainty of the effect of all interventions except exercise on injuries remains.

## Implementation Issues

There are some important implementation considerations in applying our findings to the U.S. healthcare system for the multifactorial and exercise interventions. First, identifying those at increased fall risk who would be candidates for interventions remains a challenge. Simplified self-administered questionnaires are ideal for efficiency, and while history of falls predicts future falls as well as primary care feasible questionnaires/functional tests, the use of falls history alone precludes prevention of the first fall.

While the majority of exercise trials consisted of group exercise programs (24 of 36 trials), one quarter (nine of 36 trials) involved individual programs similar to what is available in the United States in the form of physical therapy referral. Most exercise trials included an additional unsupervised physical activity component independent of the structured group or individual sessions. Most of the exercise trials included multiple exercise types, and the most common included gait/balance/function and strength/resistance training. Exploration of heterogeneity did not reveal any treatment modification based on exercise format or components, suggesting that primary care referrals for group community exercise programs, as well as traditional office-based physical therapy, are effective. The types of exercise programs provided varied across the interventions; however, the most commonly cited program was the Otago Exercise Program, which was delivered fully or partially by six studies.^49,^ ^59,^ ^125,^ ^142,^ ^149,^ ^168^ The next most commonly cited exercise programs delivered were tai chi exercise programs (in four studies),^103,^ ^120,^ ^122,^ ^153^ the Weight-bearing exercise for Better Balance program (delivered fully or in part in three studies),^137,^ ^161,^ ^168^ and the Standing Tall program (delivered in two trials).^101,^ ^106^ In the multifactorial trials, the individual treatment intervention—including physician specialty referrals, physical therapy/exercise, and environment interventions—are largely reflective of what patients could receive piecemeal in primary care. However, given the time constraints in a busy primary care clinic, these referrals may or may not be delivered in such a comprehensive fashion in the current U.S. healthcare delivery system, despite the introduction of the Medicare Initial and Annual Preventive Visits.^201^ Adherence with multiple referrals and recommendations provided in a single visit presents an implementation challenge and may require case management for follow through. The exercise/physical therapy interventions included in the multifactorial trials are similar to what patients receive in the U.S. clinical setting in their design (physical therapist designed and individually developed program based on functional assessment and diagnoses), delivery (physical therapist delivered most of the interventions—some individually and some group), and components (balance, gait, strength).

## Ongoing Trials

There are several other ongoing research trials addressing the effectiveness of in-person and digital exercise programs, educational programs, home visitation programs, medication review interventions, and multicomponent interventions. These ongoing trials are listed in Appendix M Table 1. Four of these trials are based in the United States and the largest ongoing trial is the Electronic Strategies for Tailored Exercise to Prevent FallS (eSTEPS) study (jointly funded by Brigham and Women’s Hospital and the National Institute on Aging of the National Institutes of Health).^202^ This is a large-scale (n=8,353), pragmatic cluster RCT of a clinical decision support implemented tailored falls prevention exercise plan (eSTEPS) in community-dwelling older adults at risk for falls (based on the STEADI screening protocol). The trial will recruit participants from urban and rural primary care clinics in the United States, and report falls and fall-related injuries. The scheduled completion date is March 2025.^202^

## Limitations of the Literature and Future Research Needs

Future research addressing multifactorial risk assessment interventions should include detailed protocol descriptions of such interventions, including the specific protocol for the risk assessment and referrals as well as the time and personnel required to administer the assessment. Such protocols should be tested in large pragmatic trials using streamlined protocols for multifactorial risk assessment and referrals that are feasible for use in primary care practices. Further, it would be helpful to have large trials of medication review in the clinical setting with seamless communications with primary care providers who can assess appropriateness of medication changes. Likewise, large trials providing environmental recommendations using checklists as well as capacity to implement modifications may provide an intervention that limits financial and logistical barriers to modification implementation. It remains uncertain whether psychological or educational interventions are effective for falls prevention, so trials of these interventions are needed. Finally, to provide adequate evidence on potential harms, all future research studies need to monitor adverse effects more consistently in both the control and intervention groups. There are several implementation issues, including equity issues surrounding best practices for implementing multifactorial and exercise interventions in historically marginalized and medically underserved communities and how to improve adherence in all populations in real-world settings. Future trials should recruit diverse participants representative of the U.S. population and report population characteristics. Additional trials are needed for multifactorial and exercise interventions in community-dwelling adults with mild cognitive impairment and mild dementia, osteoporosis, osteoarthritis, and sarcopenia. Any future research for multifactorial and exercise interventions in mixed-risk populations should report results stratified by risk category.

## Limitations of Our Approach

There are several limitations to our review scope and approach that are important to note. We included trials only when the primary or secondary aim was to prevent falls among older adults and a falls outcome was reported, both to select interventions with biologic plausibility of reducing falls and for pragmatic purposes. Further, our inclusion criteria generally represented community-dwelling older adults seen in primary care, and there are many subgroups of older adults to which these results may not apply. While we expanded our criteria to include trials recruiting older adults with mild cognitive impairment or mild dementia, osteoporosis, osteoarthritis, and sarcopenia, we still excluded trials that specifically recruited participants with major neurologic diagnoses (e.g., moderate to severe dementia, Parkinson’s disease, stroke) because those populations may require specialized approaches to preventing falls.

Our attempts to describe the recruitment setting may also have limitations. While we aimed to distinguish studies that recruited participants from primary care and the community as separate from those that identified participants through their use of the ED, mixed recruitment strategies at times meant we may have under or overestimated the applicability of the recruitment setting.

Further, we tried to consistently categorize and describe the interventions, but the intervention procedures were not always described in adequate detail. This likely resulted in imprecision and potentially some inaccuracies in our categorizations and descriptions of some of the included interventions. Similarly, we did not include comparative effectiveness trials and excluded any trial where the comparison group had an active control (e.g., stretching, walking). At times it was difficult to determine whether a comparator was too intense to be considered a minimal control. Our protocol prioritized health outcomes consistent with the USPSTF methodology—specifically falls, falls-related morbidity, and mortality—and did not include intermediate functional outcomes, such as changes in balance, endurance, or walking speed. It is possible that these interventions also have a beneficial impact on these intermediate functional outcomes, which may lead to a later decrease in falls. Additionally, while we recognize that falls efficacy scales and fear of falling are commonly reported in trials, we excluded these outcomes in favor of direct fall event outcomes. We also did not examine other non-fall–related health outcomes that may have a positive association with these interventions (e.g., the effect of exercise on cardiovascular or mental health outcomes).

## Conclusion

The current evidence base demonstrates that exercise is associated with fewer falls, fewer people with a fall, and a reduced number of injurious falls in average- and increased-risk community-dwelling older adults. Multifactorial interventions appear to reduce falls but not people with a fall or injuries; trials are clinically and statistically heterogeneous. Other single falls prevention interventions, including environmental modification, medication management, education, and psychological interventions, as well as falls interventions with multiple components like exercise plus education and exercise plus environment have either few trials showing no statistically significant effect or a few trials reporting mixed results.