# Chapter 3 Results

## KQ 1

Do Interventions to Prevent Falls in Unselected or Increased-Risk Community-Dwelling Older Adults Reduce Falls, Fall-Related Morbidity, or Mortality?

## KQ1a

How Is “Increased Risk” Defined in the Included Trials?

## KQ 2

Do Interventions to Prevent Falls in Unselected or Increased-Risk Community-Dwelling Older Adults Result in Any Adverse Effects?

We reviewed 5,142 abstracts and 403 full-text articles for KQ 1 and KQ 2 (Appendix B Figure 1). Overall, we included 83 trials (reported in 145 publications); 32 were newly identified trials and 51 were carried forward from the previous review. Lists of included and excluded studies (with the reasons for exclusion) are available in Appendix C and Appendix D, respectively.

Most of our included studies investigated the effectiveness of multifactorial (k=28) and exercise (k=37) interventions. The remaining studies examined interventions including exercise with the addition of an education component (k=4), exercise with the addition of an environment assessment (k=3), environment assessments with or without modifications (k=6), medication review with or without modification (k=4), psychological interventions (k=3), and education interventions (k=1). An evidence map with total number of studies by intervention group is shown in Figures 3 and 4.

Figure 3 Total Number of Studies and Randomized Participants, by Intervention Group

Abbreviations: k = number of studies, n = number of participants.

Figure 3 shows the total number of studies and randomized participants, by intervention group. In total, there are 83 studies with 48,889 participants. For multifactorial interventions, there are 28 studies with 27,784 participants. For exercise interventions, there are 37 studies with 16,117 participants. For environment interventions, there are 6 studies with 4,162 participants. For exercise + education interventions, there are 4 studies with 1,047 participants. For exercise + environment interventions, there are 3 studies with 935 participants. For medication review/modification interventions, there are 4 studies with 1,052 participants. For psychological interventions, there are 3 studies with 979 participants. For education interventions, there is 1 study with 310 participants.

Figure 4 Evidence Map by Intervention Type: Outcomes and Number of People Analyzed

Figure 4 is an evidence map of outcomes and number of people analyzed, sorted by intervention type. The outcomes are falls, falls resulting in injury or medical care, people with one or more falls, people with a fall resulting in injury or medical care, mortality, and harms.

The most robust results with consistent associations across fall-related outcomes were found for exercise interventions, with statistically significant effects favoring the intervention for the number of falls, the number of falls resulting in injury or medical care, and persons with one or more falls. For multifactorial interventions, only the number of falls was statistically significantly reduced for the intervention group when compared to the control group. The findings from the remaining interventions did not demonstrate a consistent relationship with falls, fall-related morbidity, or mortality—the small number of studies per intervention grouping often precluded any meta-analyses. Harms for all intervention types were scantly reported but generally mild in severity and associated with any exercise components of interventions.

### Multifactorial Interventions

#### Summary of Results

We identified 28 trials (n=27,784) of multifactorial interventions to prevent falls in community-dwelling older adults (Figure 5). Each trial examined direct interventions and referrals customized to participants based on an initial risk assessment, although the specific assessment and intervention components varied. Most of the trials recruited participants determined to be at high risk for falls; history of falls was the most common risk factor used for trial recruitment. Pooled results from 20 trials (n=22,115) demonstrated that multifactorial interventions were associated with a lower risk of falling at the longest followup (6–28 months) with substantial heterogeneity in the effect size (incidence rate ratio (IRR), 0.84 [95% CI, 0.74 to 0.95]; I^2^=85.0%). However, pooled results from 26 trials (n=23,626) demonstrated no association of multifactorial interventions with the risk of people experiencing a fall at the longest followup (6–28 months) (RR, 0.96 [95% CI, 0.91 to 1.02]; I^2^=48.2%). Multifactorial interventions were not associated with mortality at longest followup (6–42 months) in the multifactorial group compared to the control group (k=24; n=21,596; RR, 1.01 [95% CI, 0.88 to 1.17]; I^2^=0%). Qualitative analyses demonstrated multifactorial interventions were not associated with a change in hospitalization, institutionalization, IADLs, or QOL, but these outcomes are reported in just a small proportion of studies. There is sparse evidence on the harms of multifactorial interventions, and when reported, they were rare, minor, and associated with the exercise components of multifactorial interventions.

Figure 5 Pooled Analyses for Multifactorial, Exercise, and Environment Interventions

Abbreviations: CI = confidence interval; IRR = incidence rate ratio; k = number of studies; n = number of participants; RR = relative risk.

Figure 5 shows a forest plot of pooled analyses for multifactorial, exercise, and environment interventions.

#### Characteristics of Included Studies

We included 28 trials (in 45 articles) of multifactorial assessments and interventions (n=27,784).^22,^ ^47–90^ Of the 28 trials, 25 were included in the previous review^53–59,^ ^62,^ ^63,^ ^69–71,^ ^73–75,^ ^77,^ ^78,^ ^80,^ ^82,^ ^84–87,^ ^89,^ ^90^ and three were newly identified.^47,^ ^49,^ ^72^ One trial^91^ from the previous review was excluded due to a high risk of bias for its falls ascertainment.

##### Study Characteristics

We identified nine good-quality^47,^ ^49,^ ^56,^ ^62,^ ^74,^ ^75,^ ^84,^ ^86,^ ^89^ and 19 fair-quality^53–55,^ ^57–59,^ ^63,^ ^69–73,^ ^77,^ ^78,^ ^80,^ ^82,^ ^85^ trials with a primary or secondary aim of examining the effectiveness of multifactorial interventions on falls and/or fall-related injuries (Table 3; Appendix E Table 1). Most of the trials were conducted outside of the United States, with only four taking place in the United States,^47,^ ^55,^ ^86,^ ^90^ 18 in Europe,^49,^ ^54,^ ^56–58,^ ^63,^ ^69,^ ^71–74,^ ^77,^ ^78,^ ^80,^ ^84,^ ^85,^ ^87,^ ^89^ four in Australia or New Zealand,^59,^ ^62,^ ^75,^ ^82^ and two in Canada.^53,^ ^70^ The size of the trials (intervention plus control groups randomized for our analysis) ranged from 153^77^ to 6,524^49^ participants. One very large trial^49^ was unusual in that the trial tested the effectiveness of screening and multifactorial assessment and intervention: all those in the intervention group received a screening assessment and only those assessed at intermediate or high risk for falls actually were assigned to receive the multifactorial assessment and interventions.

Table 3 Summary of Study and Participant Characteristics, All Interventions

Characteristic | No. of studies^*^ for each intervention type
Characteristic | MF | Exercise | Exercise + Edu + Other | Exercise + Environ | Environ | Med Review/Mod | Psych | Edu
Total studies | 28 | 37 | 4 | 3 | 6 | 4 | 3 | 1
Newly identified | 3 | 19 | 3 | 2 | 3 | 2 | 1 | 0
Previously identified | 25 | 18 | 1 | 1 | 3 | 2 | 2 | 1
Quality rating | - | - | - | - | - | - | - | -
Good | 9 | 5 | 3 | 1 | 3 | 2 | 0 | 0
Fair | 19 | 32 | 1 | 2 | 3 | 2 | 3 | 1
Country | - | - | - | - | - | - | - | -
US | 4 | 5 | 1 | 0 | 1 | 3 | 0 | 0
Europe | 18 | 20 | 1 | 0 | 3 | 1 | 2 | 0
Other | 6 | 12 | 2 | 3 | 2 | 0 | 1 | 1
Recruitment setting | - | - | - | - | - | - | - | -
Clinic (with or without community-based) | 16 | 13 | 1 | 1 | 2 | 1 | 0 | 0
Community- or population-based only | 0 | 19 | 1 | 1 | 3 | 1 | 3 | 1
ED or hospital only | 7 | 2 | 0 | 1 | 1 | 1 | 0 | 0
Other | 5 | 3 | 2 | 0 | 0 | 1 | 0 | 0
Baseline risk of falling | - | - | - | - | - | - | - | -
At increased risk | 21 | 20 | 3 | 1 | 3 | 3 | 3 | 1
Unselected for risk | 7 | 17 | 1 | 2 | 3 | 1 | 0 | 0
Falls data collection | - | - | - | - | - | - | - | -
Diary/calendar (+/− recall, administrative records) | 21 | 24 | 4 | 3 | 5 | 3 | 3 | 1
Recall and administrative records | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0
Recall only (1 to 6 months) | 6 | 11 | 0 | 0 | 1 | 1 | 0 | 0
Administrative records only | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
Race/ethnicity | - | - | - | - | - | - | - | -
Majority White | 3 | 7 | 1 | 0 | 0 | 2 | - | -
Race/ethnicity not reported | 23 | 30 | 3 | 2 | 5 | 2 | 3 | 1
Randomized sample size, range | 153-6,524 | 35-6,502 | 96-453 | 272-354 | 165-1,879 | 80-612 | 50-540 | 310
Age, weighted mean | 79 | 77 | 75 | 79 | 77 | 77 | 78 | 78
Female, percent | 62 | 68 | 78 | 63 | 60 | 66 | 71 | 74

* Value instead of number of studies when indicated.

Abbreviations: ED = emergency department; Edu = education interventions; Environ = environmental interventions; MF = multifactorial interventions; No. = number; Psych = psychological interventions; US = United States.

##### Population Characteristics

Most trials recruited participants age 65 years or older^54,^ ^57,^ ^58,^ ^69,^ ^70,^ ^72,^ ^73,^ ^77,^ ^84,^ ^85,^ ^89,^ ^90^ or 70 years or older,^47,^ ^49,^ ^56,^ ^62,^ ^78,^ ^80,^ ^86,^ ^87^ but two trials recruited participants from the oldest old age groups (≥80^71^ or ≥85^63^ years) (Table 3; Appendix E Tables 1 and 2). Mean age ranged from 72 years^53^ to 85 years.^63^ The proportion of women in the trials ranged from 53 percent^49^ to 94 percent.^53^ Race and ethnicity were rarely reported (k=5). In three trials,^47,^ ^49,^ ^90^ 91 to 99 percent of participants were White. One trial^47^ additionally reported that 5 percent of participants were Black and 8 percent were Hispanic/Latino. One trial^53^ from Canada identified 6 percent of participants as being from “Aboriginal origin” and a trial^59^ from New Zealand reported 3 percent of participants classified themselves as “Maori or Pacific.” Measures of socioeconomic status, such as education or income level, varied widely. Nearly all trials solely recruited older adults living in the community. Fifteen trials recruited at least some proportion of participants from clinics,^47,^ ^49,^ ^53,^ ^56,^ ^58,^ ^59,^ ^62,^ ^63,^ ^71,^ ^72,^ ^77,^ ^78,^ ^80,^ ^84,^ ^85,^ ^87^ and six trials exclusively recruited from the ED.^54,^ ^57,^ ^69,^ ^73,^ ^82,^ ^89^ Three U.S. trials recruited patients from health maintenance organizations or health insurance databases.^55,^ ^86,^ ^90^ An additional trial recruited patients in Australia from health insurance member databases.^75^

Sixteen trials excluded patients with cognitive impairment or dementia; many of these trials provided different Mini-Mental State Examination (MMSE) cutoff scores for inclusion.^47,^ ^54,^ ^57–59,^ ^62,^ ^69,^ ^71,^ ^72,^ ^75,^ ^77,^ ^82,^ ^84–86,^ ^89^ An additional eight trials excluded those who could not understand instructions or provide their own informed consent.^56,^ ^58,^ ^59,^ ^71,^ ^73,^ ^74,^ ^78,^ ^80^ None of the trials specifically recruited those with cognitive impairment, but one trial removed its initial exclusion of those with cognitive impairment in order to recruit enough generalizable participants,^82^ and one trial allowed participants with cognitive impairment with proxy consent.^47^

Seven trials recruited patients unselected for their risk of falling (with the exception of their age).^49,^ ^55,^ ^63,^ ^71,^ ^75,^ ^80,^ ^90^ Among those unselected participants reporting percent at risk (k=5), 19 to 44 percent of those recruited were at increased risk for falls.^49,^ ^55,^ ^63,^ ^71,^ ^75,^ ^80,^ ^90^ Twenty-one trials^47,^ ^53,^ ^54,^ ^56–59,^ ^62,^ ^69,^ ^70,^ ^72–74,^ ^77,^ ^78,^ ^82,^ ^84–87,^ ^89^ solely recruited patients at increased risk for falls according to various definitions (Figure 6; Appendix E Table 2). Nearly half of the trials (13 of 28) defined high risk as having a history of falling as the sole risk criterion.^55,^ ^59,^ ^70,^ ^71,^ ^80,^ ^84,^ ^85,^ ^90^ The remainder of the trials recruited participants who fulfilled one or more risk factor criteria from a list of possible risk factors. Of the trials using multiple risk factors to define fall risk, the most common risk factors included a hospitalization or ED visit,^53,^ ^54,^ ^57,^ ^58,^ ^69,^ ^73,^ ^74,^ ^77,^ ^82,^ ^89^ physical function testing,^49,^ ^53,^ ^56,^ ^78,^ ^86,^ ^87^ and a history of one or more falls.^47,^ ^49,^ ^56,^ ^78,^ ^87^ Three trials explicitly required participants to have the ability to walk independently without assistance from a device.^56,^ ^81,^ ^82,^ ^86^ Overall, among the 26 trials reporting the proportion of those at risk, 65 percent of participants were at increased risk of falling.

Figure 6 Baseline Fall Risk Ascertainment for Multifactorial Interventions

Abbreviations: ED = emergency department; NR = not reported.

Figure 6 shows baseline fall risk ascertainment for the multifactorial intervention trials. Fall risk factors include fall history, hospital/ED, physical function, osteoporosis/osteopenia, medications, frailty, fear of falling, other, and not reported.

Trials reporting some measure of ADL function generally reported fairly independent ADLs,^55,^ ^58,^ ^63^ although there were a few exceptions, such as the trial by Moller et al.,^77^ which required participants to need assistance with at least two ADLs, and the trial by Russell et al.,^82^ in which a third of participants needed some assistance with ADLs. Sixteen trials reported a measure of medication use; mean number of medications ranged from 5.0 to 15.5 and the proportion of people taking more than four medications ranged from 41 to 65 percent. Seven trials^47,^ ^58,^ ^59,^ ^62,^ ^69,^ ^78,^ ^82^ reported mean number of medical comorbidities ranging from 1^58^ to 7.^62^ One trial specifically recruited a high proportion of individuals with stroke (15%) and Parkinson’s disease (19%).^72^

##### Intervention Details

The 28 multifactorial trial publications described a heterogeneous group of complex assessment and intervention components (Figures 7–9; Appendix E Table 3). All trials administered an initial assessment, which included several components such as medical history, medication review, clinical and laboratory tests, and patient questioning to assess and plan for fall risk mitigation (Figure 7). Most trials (24 of 28) provided outside referrals (Figure 8) and administered some research team–delivered intervention components (Figure 9). The referrals and study-delivered treatment interventions were largely individualized and based on the risk factors identified in the initial assessment. They generally targeted multiple intervention components, such as exercise (unsupervised or supervised, group or individual), psychological (cognitive behavioral therapy), nutrition therapy, education (e.g., via DVDs, lectures, pamphlets), medication management, urinary incontinence management, environment (e.g., assistive technology or dwelling recommendations), and referral to physical or occupational therapy, social or community services, and specialists (e.g., ophthalmologist, neurologist, cardiologist). Nineteen trials included one or more home visits for the initial assessment, environment interventions, and/or physical therapy/exercises.^53–55,^ ^57,^ ^59,^ ^62,^ ^69–74,^ ^77,^ ^78,^ ^80,^ ^82,^ ^84,^ ^86,^ ^87^ The vast majority of interventions in the trials, however, occurred in the outpatient setting. All interventions were in person, with some trials additionally including some telephone coaching.^47,^ ^55,^ ^71,^ ^77,^ ^90^

Figure 7 Baseline Assessment Components for Multifactorial Interventions

Abbreviations: assist device = assistive devices; cog fxn = cognitive function; CVD = cardiovascular disease; EtOH/drugs = alcohol and drug use; Diag = diagnosis; Environ = environment; exam = examination; fxn = function; incont = incontinence; meds = medications; nutr = nutrition; ortho hypo = orthostatic hypotension.

Figure 7 shows baseline fall risk ascertainment for the exercise intervention trials. Fall risk factors include fall history, hospital/ED, physical function, osteoporosis/osteopenia, medications, and frailty.

Figure 8 Referrals/Recommendations as Indicated by the Assessment Results for Multifactorial Interventions

Abbreviations: environ = environment; exer = exercise; meds = medications; aud = auditory; PCP = primary care practitioner; OT = occupational therapist; assist devices = assistive devices; pod = podiatry; nut = nutrition; EtOH = alcohol; CVD = cardiovascular disease; neuro = neurology; psych = psychiatry; unspec = unspecified.

Figure 8 shows referrals/recommendations as indicated by the assessment results for multifactorial interventions.

Figure 9 Components Delivered to All Intervention Participants for Multifactorial Interventions

Figure 9 shows components delivered to all intervention participants for multifactorial interventions. Components include advice, environment assessment, educational material, exercise, falls education, and counseling. All studies received advice.

Initial assessment. All 28 trials administered an initial assessment of modifiable fall risk factors in order to customize the intervention for each participant (Figure 7; Appendix E Table 3). This initial assessment could include a multidisciplinary comprehensive geriatric assessment or an assessment of falls risk factors with any number of the following assessment components: balance, gait, vision, cardiovascular health (e.g., postural blood pressure or pulse, carotid sinus stimulation), medication, environment/home hazard, cognition, and psychological health. The vast majority of the trials’ initial assessments included an environmental assessment, functional assessment, medication review, and vision screening. The other assessment components varied. All trials assessed falls risk factors, most (k=24) including functional assessments(s) (i.e., TUG, Short Physical Performance Battery (SPPB)),^47,^ ^49,^ ^53–59,^ ^62,^ ^63,^ ^69–73,^ ^75,^ ^77,^ ^78,^ ^84–87,^ ^89^ an environmental assessment (k=24),^47,^ ^49,^ ^53–59,^ ^62,^ ^63,^ ^69,^ ^70,^ ^72–74,^ ^77,^ ^78,^ ^80,^ ^84–87,^ ^90^ or a medication review (k=22),^47,^ ^49,^ ^53–58,^ ^62,^ ^63,^ ^69,^ ^72–74,^ ^77,^ ^78,^ ^84–87,^ ^89,^ ^90^ but only three trials^72,^ ^75,^ ^82^ administered a validated/formal falls risk assessment tool (Fall Risk for Older People in the Community [FROP-Com]). Of the 24 trials that provided an environmental assessment, 17 were conducted in participants’ homes.^53–55,^ ^57,^ ^59,^ ^62,^ ^69,^ ^70,^ ^72–74,^ ^77,^ ^78,^ ^80,^ ^84,^ ^86,^ ^87^ Twenty trials assessed participants vision;^47,^ ^49,^ ^54,^ ^57–59,^ ^63,^ ^69–73,^ ^75,^ ^78,^ ^82,^ ^84–86,^ ^89,^ ^90^ 11 trials assessed cognitive function;^54,^ ^59,^ ^63,^ ^69,^ ^71–73,^ ^78,^ ^85,^ ^87,^ ^89^ nine trials assessed medical diagnoses;^56–59,^ ^62,^ ^69,^ ^71,^ ^86,^ ^89^ nine trials assessed mental health;^54,^ ^62,^ ^69,^ ^71,^ ^78,^ ^82,^ ^84,^ ^86,^ ^89^ nine trials assessed orthostatic blood pressure;^47,^ ^49,^ ^53,^ ^56–58,^ ^70,^ ^82,^ ^85^ eight trials assessed cardiovascular health;^57,^ ^59,^ ^69,^ ^72,^ ^73,^ ^78,^ ^85,^ ^89^ six trials assessed hearing;^63,^ ^69,^ ^71,^ ^73,^ ^86,^ ^90^ six trials assessed ADLs;^53,^ ^54,^ ^63,^ ^78,^ ^86,^ ^87^ five trials assessed foot health;^47,^ ^49,^ ^72,^ ^73,^ ^85^ and three trials administered a physical examination.^56,^ ^58,^ ^69^ The initial assessment occurred in a clinical setting and/or the participant’s home. The assessment was completed by nursing professionals (18 trials), physicians (12 trials), physical therapists (11 trials), and/or occupational therapists (6 trials).

Individualized services. Based on the results of the initial assessment, a variety of services or referrals for a service were described in the included trials (Figure 8; Appendix E Table 3). Eighteen trials referred some or all of the participants to an individual (such as one administered by a physical therapist) or group exercise intervention.^47,^ ^49,^ ^53,^ ^57–59,^ ^62,^ ^63,^ ^70,^ ^72,^ ^75,^ ^77,^ ^78,^ ^82,^ ^85,^ ^86,^ ^89,^ ^90^ Fourteen trials performed or referred participants to a medication review.^47,^ ^49,^ ^53,^ ^54,^ ^62,^ ^72–74,^ ^78,^ ^84–86,^ ^89,^ ^90^ Thirteen trials referred participants to vision and/or hearing specialists.^47,^ ^49,^ ^57–59,^ ^63,^ ^70,^ ^72,^ ^73,^ ^75,^ ^85,^ ^89,^ ^90^ Seven trials referred participants to occupational therapy.^49,^ ^53,^ ^59,^ ^62,^ ^77,^ ^82,^ ^85^ Nine trials referred participants back to their primary care provider with risk assessment information and recommendations,^47,^ ^49,^ ^55,^ ^58,^ ^59,^ ^69,^ ^72,^ ^82,^ ^90^ and 11 trials communicated with primary care providers specifically regarding medication assessment results.^47,^ ^49,^ ^53,^ ^54,^ ^62,^ ^73,^ ^74,^ ^84–86,^ ^90^ Of the trials that provided an environmental assessment, 17 provided additional recommendations or referrals for modifications with or without modification implementation, if indicated by the initial assessment.^47,^ ^49,^ ^54–59,^ ^63,^ ^69,^ ^70,^ ^72,^ ^80,^ ^85–87,^ ^90^

Intervention components delivered to all participants in the intervention group. All trials delivered individualized falls prevention advice and recommendations based on the multifactorial risk assessment. Additionally, several trials provided intervention components to all participants regardless of the results of the risk assessment (Figure 9; Appendix E Table 3). Eleven trials provided environmental assessments, which were generally home visits with specific recommendations for modifications with or without modification implementation.^54,^ ^59,^ ^63,^ ^69,^ ^72–74,^ ^77,^ ^78,^ ^84,^ ^87^ Eight trials^53,^ ^55,^ ^56,^ ^59,^ ^63,^ ^72,^ ^80,^ ^84^ provided educational materials related to falls prevention (e.g., printed materials) while five^56,^ ^72,^ ^74,^ ^80,^ ^84^ delivered falls-specific group education sessions. Nine of the trials^55,^ ^56,^ ^59,^ ^72,^ ^74,^ ^77,^ ^78,^ ^80,^ ^84^ delivered a physical activity intervention (exercise or physical therapy) to all participants and three trials^47,^ ^55,^ ^71^ delivered counseling/behavior modification coaching interventions focused on risk factor mitigation.

Intervention intensity and format. We could not quantify the intensity of the multifactorial interventions because total contact time was rarely reported, especially for the trials that included referrals to outside specialist care. In the studies that included an exercise intervention component, the frequency of exercise sessions was generally one to three times per week, while the duration of the exercise interventions ranged widely, from 6 weeks^74^ to 12 months.^59,^ ^75,^ ^77,^ ^84,^ ^87^ Due to the nature of multifactorial interventions having potentially several types of referrals based on initial assessment risks, the total duration of the interventions beyond the initial assessment were rarely reported. When the intervention duration was reported, it reflected intervention components beyond the assessment and referral part of the intervention, such as periodic check-ins from a healthcare coordinator or continuing exercise and education classes. The vast majority of trials had interventions delivered individually. In a few cases, there was a group format for education or exercise sessions in addition to the individually directed intervention.^72,^ ^74,^ ^80,^ ^84,^ ^90^

Intervention adherence. In general, most trials reported, in various degrees of detail, the percentage of participants who were referred to specialty services based on the initial falls risk assessment. Seventeen trials reported that 20 to 99 percent of participants attended the recommended referrals and/or implemented changes recommended by the referrals.^49,^ ^56,^ ^59,^ ^62,^ ^63,^ ^69,^ ^70,^ ^75,^ ^77,^ ^78,^ ^80,^ ^82,^ ^84,^ ^86,^ ^87,^ ^89,^ ^90^ Most commonly, the adherence in trials to recommendations was in the 60- to 70-percent range for any individual recommendation or referral. In one large multifactorial trial, however, adherence to some interventions, including medication review and environmental referrals, were generally low: 3.2 percent of those eligible for environmental assessment actually received a home safety assessment and 4.3 percent of those who qualified completed a visit with a pharmacist for medication review.^47,^ ^66^ In the other large multifactorial trial, researchers found documented evidence of action for 36 percent of all treatments recommended in the multifactorial falls prevention intervention (e.g. referral to, or outcome of attendance at, other referrals).^49,^ ^51^ In the multifactorial trials that included an exercise referral for some or all participants, 23 to 74 percent attended some or all exercise classes or sessions.^49,^ ^59,^ ^63,^ ^80,^ ^84^

Control groups. The majority (19 of 28) of trial control groups received no intervention or usual care.^53,^ ^54,^ ^56–59,^ ^62,^ ^63,^ ^69,^ ^71–75,^ ^77,^ ^82,^ ^85,^ ^87,^ ^89,^ ^90^ The remaining nine trials compared their intervention to a control group that received usual care plus minimal or attention control (pamphlet, social visit, brief fall-risk advice, letter).^47,^ ^49,^ ^55,^ ^70,^ ^72,^ ^78,^ ^80,^ ^84,^ ^86^

##### Study Quality

Of the 28 trials, nine were rated good quality with low risk of bias in all domains (Appendix A Figure 1).^47,^ ^49,^ ^56,^ ^62,^ ^74,^ ^75,^ ^84,^ ^86,^ ^89^ Eighteen fair-quality trials^53,^ ^54,^ ^57–59,^ ^63,^ ^69–73,^ ^77,^ ^78,^ ^80,^ ^82,^ ^85,^ ^87,^ ^90^ had moderate risk of bias in one or two domains and one trial^55^ had moderate risk of bias in three domains. Five trials had moderate risk of bias for insufficient reporting of randomization or baseline confounding;^55,^ ^59,^ ^73,^ ^85,^ ^90^ five trials had moderate risk of bias for intervention deviations;^55,^ ^58,^ ^59,^ ^69,^ ^82^ and seven trials had moderate risk of bias for outcome measurement issues, typically recall of the falls outcome at longer than 1 month.^53,^ ^71,^ ^73,^ ^77,^ ^78,^ ^80,^ ^90^ Seven trials had high and/or differential attrition and missing data.^54,^ ^55,^ ^63,^ ^70,^ ^72,^ ^77,^ ^87^ The multifaceted and customized nature of these multifactorial interventions precluded analysis of intervention adherence rates. Nearly all trials used intention-to-treat analysis, where all randomized participants were included in the analysis regardless of their participation at the conclusion of the study. To ascertain falls, most trials (21 of 28 trials)^47,^ ^49,^ ^53,^ ^56–59,^ ^62,^ ^63,^ ^69,^ ^70,^ ^72–75,^ ^82,^ ^84–87,^ ^89^ had the patient prospectively record falls on a calendar or in a diary, with or without additional confirmation (e.g., medical records or 3- to 6-month recall telephone calls). Six trials recorded falls by the patient’s recall every 1 to 6 months,^54,^ ^55,^ ^71,^ ^77,^ ^78,^ ^80^ and one study^90^ recorded falls by the patient’s recall at longer than 6 months and in hospital discharge summaries—however, we did not include the people with falls outcomes from this trial and only used their hospital documented fall-related injuries outcome.

#### Detailed Results

##### Falls

Meta-analysis of 20 multifactorial trials^47,^ ^49,^ ^54–57,^ ^59,^ ^60,^ ^63,^ ^70,^ ^72–74,^ ^77,^ ^78,^ ^82,^ ^84,^ ^86,^ ^89^ (n=22,115) demonstrated a statistically significantly lower rate of falls in the multifactorial group versus the control group at the longest followup (6–28 months), although with substantial statistical heterogeneity (IRR, 0.84 [95% CI, 0.74 to 0.95]; I^2^=85.0%) (Figure 10; Appendix E Table 4). Absolute differences ranged from −6.77 falls per person-year (lower fall rate in the intervention group) to 1.31 falls per person-year (higher fall rate in the intervention group). In the control group, the rate of falls per person-year ranged from 0.38 to 7.68 events per person-year at the longest followup. Individual trials reported substantial variation in effect size, with wide confidence intervals and IRR point estimates, ranging from 0.39 (95% CI, 0.24 to 0.63)^54^ to 1.13 (95% CI, 0.98 to 1.30).^49^ Two trials particularly notable for much greater beneficial effect sizes were conducted by Close et al.^54^ and Logan et al.,^74^ with IRR point estimates of 0.39 and 0.45, respectively. These trials recruited participants from the ED^54^ or an ambulance^74^ following a fall; one had specific intervention protocols outlined in the publication,^54^ and the other included intensive interventions (six physical therapy sessions, 12 group sessions of supervised exercise or education on preventing falls, and up to 12 home sessions).^74^

Figure 10 Key Question 1: Pooled Analysis of the Number of Falls at the Longest Followup for Multifactorial Interventions (k=20, n=22,115)

Abbreviations: CI = confidence interval; CG = control group; IG = intervention group; IRR = incidence rate ratio; p-y = person-year.

Figure 10 shows a forest plot of the number of falls at the longest followup for multifactorial interventions (k=20, n=22,115). The pooled incidence rate ratio is 0.85 with a 95% confidence interval of 0.74 to 0.95.

We explored heterogeneity by examining the number of falls by country, date of publication, recruitment setting, fall rate of the control group, recruitment inclusion criteria of unselected or increased risk of falls, mean age, followup period, and study quality (Appendix E Table 5). We were unable to explain the high heterogeneity by any single variable. Visual examination of the funnel plot for the 20 pooled trials (not included in this report) did not suggest a publication bias, and the Egger’s test was not statistically significant (p=0.17).

##### People With a Fall and People With Recurrent Falls

Meta-analysis of the 26 multifactorial trials^47,^ ^49,^ ^53–59,^ ^62,^ ^63,^ ^69,^ ^70,^ ^72–75,^ ^77,^ ^78,^ ^80,^ ^82,^ ^84–87,^ ^89^ (n=23,626) reporting the number of people with a fall demonstrated no statistically significant difference at the longest followup (6–28 months) in the multifactorial group compared to the control group (RR, 0.96 [95% CI, 0.91 to 1.02]; I^2^=48.2%) (Figure 11; Appendix E Table 6). Three trials^54,^ ^74,^ ^78^ reported a statistically significant modest reduction in people experiencing a fall (RR range, 0.62 to 0.84). The remaining 23 trials^47,^ ^49,^ ^53,^ ^55–59,^ ^62,^ ^63,^ ^69,^ ^70,^ ^72,^ ^73,^ ^75,^ ^77,^ ^80,^ ^82,^ ^84–87,^ ^89^ showed no statistically significant difference in the number of people experiencing a fall, with one outlier study by Ciaschini et al.^53^ reporting a nonsignificant increased risk of experiencing a fall among intervention participants versus the control (RR, 1.51 [95% CI, 0.88 to 2.60]). This trial enrolled the youngest population (mean age, 71.9 years), which was recruited from the ED after a fall. Approximately 40 percent of the trials (10 of 26) showed point estimates greater than 1.0, indicating that the control group had fewer people experiencing a fall, although none of the point estimates were statistically significant.^53,^ ^59,^ ^62,^ ^63,^ ^75,^ ^77,^ ^82,^ ^84,^ ^87,^ ^89^ The percentage of people experiencing a fall in the control group ranged from 17.0 to 94.1 percent.

Figure 11 Key Question 1: Pooled Analysis of People With 1 or More Falls at the Longest Followup for Multifactorial Interventions (k=26, n=23,626)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 11 shows a forest plot of people with one or more falls at the longest followup for multifactorial interventions (k=26, n=23,626). The pooled relative risk is 0.96 with a 95% confidence interval of 0.91 to 1.02.

Similar to people with one or more falls, pooled analysis of people with two or more falls demonstrated no statistically significant difference between the multifactorial and control groups at 12 to 28 months (RR, 0.99 [95% CI, 0.94 to 1.04]; I^2^=0%; k=11; n=14,471) (Figures 11 and 12; Appendix E Table 6).

Figure 12 Key Question 1: Pooled Analysis of People With 2 or More Falls at the Longest Followup for Multifactorial Interventions (k=11, n=14,471)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 12 shows a forest plot of people with two or more falls at the longest followup for multifactorial interventions (k=11, n=14471). The pooled relative risk is 0.99 with a 95% confidence interval of 0.94 to 1.04.

##### Falls Resulting in Injury or Medical Care and Fall-Related Fractures

The association of multifactorial interventions with the risk of injurious falls and fall-related fractures was inconsistent among trials. Approximately 40 percent (k=12; n=10,563) of the 28 multifactorial trials reported falls resulting in injuries or resulting in medical care at 6 to 44 months (Figure 13; Appendix E Table 7).^47,^ ^59,^ ^62,^ ^72,^ ^73,^ ^75,^ ^77,^ ^84,^ ^86,^ ^89^ The definition of “injuries” varied among trials, with some capturing only serious injuries (e.g., fractures, lacerations requiring sutures, head injuries requiring hospitalization) or injuries requiring medical care, and others including minor injuries as well (e.g., soft tissue bruises). Pooled results of these 12 trials showed no statistically significant association between multifactorial interventions and the number of injurious falls (IRR, 0.92 [95% CI, 0.84 to 1.01]; I^2^=21.8%). The IRRs in these 12 trials ranged from 0.51 (95% CI, 0.13 to 2.05) to 1.09 (95% CI, 0.87 to 1.35). Seven trials reported number of fall-related fractures (n=15,211), showing no statistically significant association between multifactorial interventions and fall-related fractures (IRR, 1.01 [95% CI, 0.81 to 1.26]; I^2^=34.0%)). Individual IRRs ranged from 0.76 (95% CI, 0.35 to 1.64) to 1.50 (95% CI, 0.80 to 2.82) (Figure 14; Appendix E Table 8). Three trials^49,^ ^62,^ ^89^ reported a nonsignificant increase in fracture risk in the intervention group.

Figure 13 Key Question 1: Pooled Analysis of the Number of Falls Resulting in Injury or Medical Care at the Longest Followup for Multifactorial Interventions (k=12, n=10,563)

Abbreviations: CI = confidence interval; CG = control group; IG = intervention group; IRR = incidence rate ratio; n = number; p-y = person-year.

Figure 13 shows a forest plot of the number of falls resulting in injury or medical care at the longest followup for multifactorial interventions (k=12, n=10,563). The pooled incidence rate ratio is 0.92 with a 95% confidence interval of 0.84 to 1.01.

Figure 14 Key Question 1: Pooled Analysis of the Number of Fall-Related Fractures at the Longest Followup for Multifactorial Interventions (k=7, n=15,211)

Abbreviations: CI = confidence interval; CG = control group; IG = intervention group; IRR = incidence rate ratio; n = number; p-y = person-year.

Figure 14 shows a forest plot of the number of fall-related fractures at the longest followup for multifactorial interventions (k=7, n=15,211). The pooled incidence rate ratio is 1.01 with a 95% confidence interval of 0.81 to 1.26.

##### People With a Fall Resulting in Injury or Medical Care and Fall-Related Fracture

Meta-analysis of 13 trials^47,^ ^54–56,^ ^69,^ ^71,^ ^75,^ ^77,^ ^82,^ ^86,^ ^89,^ ^90^ (n=13,460) showed no difference in people with an injurious fall in the multifactorial group compared to the control group at the longest followup (9–28 months) (RR, 0.92 [95% CI, 0.83 to 1.02]; I^2^=47.3%) (Figure 15; Appendix E Table 9). Seven trials^47,^ ^49,^ ^53,^ ^57,^ ^80,^ ^82,^ ^85^ (n=13,912) reported the number of people with a fall-related fracture or any fracture at 6 to 44 months of followup (control group prevalence range, 0.7% to 22%). Overall, there was no statistically significant difference between the multifactorial and control groups and people with a fracture (RR, 0.86 [95% CI, 0.60 to 1.24]; I^2^=49.0%) (Figure 16; Appendix E Table 10). RR point estimates ranged from 0.52 to 1.27 in the seven trials with relatively few events, which made estimates unstable.^47,^ ^49,^ ^53,^ ^57,^ ^80,^ ^82,^ ^85^

Figure 15 Key Question 1: Pooled Analysis of People With a Fall Resulting in Injury or Medical Care at the Longest Followup for Multifactorial Interventions (k=13, n=13,460)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 15 shows a forest plot of people with a fall resulting in injury or medical care at the longest followup for multifactorial interventions (k=13, n=13,460). The pooled relative risk is 0.92 with a 95% confidence interval of 0.83 to 1.02.

Figure 16 Key Question 1: Pooled Analysis of People With Fall-Related Fractures at the Longest Followup for Multifactorial Interventions (k=7, n=13,912)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 16 shows a forest plot of people with fall-related fractures at the longest followup for multifactorial interventions (k=7, n=13,912). The pooled relative risk is 0.86 with a 95% confidence interval of 0.60 to 1.24.

##### Mortality

Pooled analysis of 24 trials^47,^ ^49,^ ^53,^ ^54,^ ^56,^ ^57,^ ^59,^ ^63,^ ^69–71,^ ^73–75,^ ^77,^ ^78,^ ^80,^ ^82,^ ^84–87,^ ^89,^ ^90^ (n=21,596) showed no difference in all-cause mortality at 6 to 42 months in the multifactorial group compared to the control group (RR, 1.01 [95% CI, 0.88 to 1.17]; I^2^=0%) (Figure 17). Individual study results varied widely, with RRs ranging from 0.6 to 8.3 and wide confidence intervals reflecting a relatively uncommon outcome with few events in most trials (Appendix E Table 11); not surprisingly, none of the relative comparisons were statistically significant as the trials were not intended nor powered to affect mortality outcomes.

Figure 17 Key Question 1: Pooled Analysis of Mortality at the Longest Followup for Multifactorial Interventions (k=24, n=21,596)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 17 shows a forest plot of mortality at the longest followup for multifactorial interventions (k=24, n=21,596). The pooled relative risk is 1.01 with a 95% confidence interval of 0.88 to 1.17.

##### Other Outcomes

Qualitative analysis demonstrates no effect on hospitalization, institutionalization, IADLs, or QOL, but these outcomes were reported in just a small proportion of multifactorial trials (Appendix E Tables 12–14).

##### Harms

In general, adverse events were sparsely reported. When reported, they were rare, minor, and associated with the exercise components of the multifactorial interventions. Five trials (n=4,199) reported harms associated with multifactorial interventions (Appendix E Table 15).^49,^ ^62,^ ^69,^ ^84,^ ^86^ One trial^69^ reported no adverse events in the intervention or control groups. Four trials^49,^ ^62,^ ^84,^ ^86^ reported adverse events in the intervention groups but did not provide data from the control group for comparison. One of these trials^84^ reported three falls without injuries during the exercise sessions of the interventions, one reported back pain that either restricted ADLs for two or more days or resulted in medical attention in two intervention participants,^62^ one reported musculoskeletal complaints in 10 intervention participants,^86^ and the other reported no adverse events in the intervention group.^49^

### Exercise Interventions

#### Summary of Results

We identified 37 trials (n=16,117) of exercise interventions to prevent falls in community-dwelling older adults (Figure 5). The trials generally included multiple exercise components, and the exercise interventions were primarily conducted in a supervised group setting. Fifty-eight percent of participants in these trials were determined to be at high risk for falls; fall history and hospital or ED admissions were the most common risk factor (alone or in combination) used for trial recruitment. Pooled analysis from 29 trials (n=14,475) demonstrated that exercise interventions were associated with a significant reduction in the rate of incident falls at the longest followup (6–24 months) (IRR, 0.85 [95% CI, 0.75 to 0.96]; I^2^=82.7%). Meta-analysis of 25 exercise RCTs (n=13,384) demonstrated that exercise is associated with a significantly reduced risk of people falling at the longest followup (6–24 months) (RR, 0.92 [95% CI, 0.87 to 0.98]; I^2^=24.3%). Exercise interventions were also associated with a reduction in the number of injurious falls, but people with an injurious fall and fall-related fractures did not show a statistically significant association. Pooled analysis of 15 RCTs (n=10,461) showed no significant association between exercise and all-cause mortality at longest followup (12–85 months) (RR, 0.87 [95% CI, 0.71 to 1.06]; I^2^=0.0%). Qualitative analysis demonstrates no effect on people with a hospitalization or ED visit (k=1), people institutionalized (k=3), IADLs (k=6), or QOL (k=13), but the outcomes are reported in a small proportion of the exercise trials. Conclusions about the harms of exercise interventions are limited by only half of the trials reporting harms (k=19; n=11,087), incomplete reporting of adverse events, and rare event rates. Seven trials reported no differences in serious harms. Harms, including musculoskeletal complaints associated with exercise, were generally minor.

#### Characteristics of Included Studies

We included 37 trials (in 70 articles) of exercise interventions (n=16,117).^22,^ ^49–51,^ ^64,^ ^92–156^ One trial from the previous review was excluded because the control group was considered too intense^157^ and two trials were excluded^158,^ ^159^ because falls were not cumulatively measured (e.g., only from 12 to 24 months, rather than from baseline to 24 months).

##### Study Characteristics

We identified 32 fair-quality^96,^ ^98,^ ^101–103,^ ^107–109,^ ^113,^ ^115,^ ^118–120,^ ^122–129,^ ^133,^ ^134,^ ^136–138,^ ^140,^ ^142,^ ^146,^ ^148,^ ^149,^ ^155^ and five good-quality^49,^ ^106,^ ^117,^ ^151,^ ^153^ RCTs with a primary or secondary aim of examining the effectiveness of exercise on reducing falls and/or fall-related injuries at 6 to 85 months of followup (Table 3; Appendix F Table 1). Trials were primarily conducted outside of the United States, with only five trials taking place in the United States,^98,^ ^103,^ ^120,^ ^126,^ ^146^ 20 in Europe,^49,^ ^107,^ ^109,^ ^113,^ ^115,^ ^117–119,^ ^122,^ ^123,^ ^125,^ ^128,^ ^133,^ ^136,^ ^138,^ ^140,^ ^142,^ ^148,^ ^149,^ ^151^ 11 in Australia or New Zealand,^96,^ ^101,^ ^102,^ ^106,^ ^108,^ ^124,^ ^129,^ ^134,^ ^137,^ ^153,^ ^155^ and one in Singapore.^127^ Trial sizes varied widely, ranging from 35^136^ to 6,502^49^ (participants randomized to exercise and control arms for our analysis). One very large trial was unusual in that it tested screening and exercise intervention; of those randomized into the active exercise arm, only those who screened as intermediate or high risk for falls actually received the exercise intervention.^49^

##### Population Characteristics

The most common target population ages for inclusion were 60 years or older^101,^ ^117,^ ^118,^ ^120,^ ^126,^ ^129,^ ^137,^ ^146,^ ^153^ or 65 years or older,^96,^ ^103,^ ^109,^ ^125,^ ^127,^ ^128,^ ^136,^ ^138,^ ^140,^ ^142,^ ^148,^ ^155^ although two trials did recruit participants from the oldest old age groups (≥80^102^ or ≥85^123^ years) (Table 3; Appendix F Tables 1 and 2). The mean age ranged from 68 years^117^ to 88 years.^123^ Ten of the trials were conducted exclusively with women,^102,^ ^103,^ ^107,^ ^113,^ ^115,^ ^117,^ ^118,^ ^125,^ ^133,^ ^151^ while in only three trials less than half of the participants were female.^109,^ ^119,^ ^128^ The majority of participants in the remaining trials were women.^49,^ ^96,^ ^98,^ ^101,^ ^106,^ ^108,^ ^120,^ ^122–124,^ ^126,^ ^127,^ ^129,^ ^134,^ ^136–138,^ ^140,^ ^142,^ ^146,^ ^148,^ ^149,^ ^153,^ ^155^ Only seven trials reported race and ethnicity, and in all but one of these trials,^120^ participants were almost exclusively White.^49,^ ^101,^ ^109,^ ^119,^ ^140^ Eighteen trials reported a measure of socioeconomic status—primarily education.^49,^ ^98,^ ^101,^ ^106,^ ^107,^ ^109,^ ^119,^ ^120,^ ^122,^ ^127,^ ^128,^ ^136,^ ^140,^ ^146,^ ^148,^ ^149,^ ^153,^ ^155^ Trials reported socioeconomic status differently, making it difficult to summarize this measure, but most participants who reported socioeconomic status had achieved at least a high school or equivalent education. All trials recruited community-dwelling adults. Nineteen trials recruited from a community or population-based setting only (e.g., population-based registries),^103,^ ^106–108,^ ^113,^ ^115,^ ^117,^ ^120,^ ^123,^ ^127,^ ^129,^ ^133,^ ^136,^ ^142,^ ^146,^ ^148,^ ^151,^ ^153,^ ^155^ 13 trials recruited from a clinic setting (with or without additionally using community-based recruitment),^49,^ ^96,^ ^101,^ ^102,^ ^109,^ ^119,^ ^122,^ ^125,^ ^126,^ ^134,^ ^138,^ ^140,^ ^149^ two trials recruited from a hospital or ED only,^118,^ ^137^ two trials recruited from insurance registries,^98,^ ^128^ and one trial recruited from a retirement village.^124^

Three trials recruited participants with mild to moderate cognitive impairment^101,^ ^109,^ ^119^ and one trial was limited to participants with established Alzheimer’s disease.^128^ Eighteen trials excluded participants with mild to severe cognitive impairment.^101,^ ^103,^ ^106,^ ^115,^ ^120,^ ^124,^ ^127,^ ^129,^ ^133,^ ^136,^ ^137,^ ^140,^ ^142,^ ^146,^ ^149,^ ^151,^ ^153,^ ^155^ Nine trials excluded participants who were not ambulatory without the use of an assistive device.^103,^ ^106,^ ^115,^ ^118,^ ^120,^ ^125,^ ^126,^ ^142,^ ^148,^ ^153,^ ^155^

Twenty trials required all participants to be at increased risk for falls.^96,^ ^103,^ ^107,^ ^115,^ ^118,^ ^122,^ ^123,^ ^125–128,^ ^136–138,^ ^140,^ ^142,^ ^146,^ ^148,^ ^149,^ ^151^ Fifteen trials^49,^ ^98,^ ^101,^ ^102,^ ^106,^ ^108,^ ^117,^ ^119,^ ^120,^ ^124,^ ^129,^ ^133,^ ^134,^ ^153,^ ^155^ included populations with 6 to 59 percent of participants at increased risk for falls. The definitions of increased risk for falls varied amongst the trials (Figure 18; Appendix F Table 2). Most of the trials (22 of 37 trials) included history of falls as either the sole criterion^108,^ ^119,^ ^120,^ ^124,^ ^129,^ ^134,^ ^151,^ ^153,^ ^155^ or one of several risk factors.^49,^ ^98,^ ^101,^ ^102,^ ^106,^ ^117,^ ^122,^ ^123,^ ^125,^ ^128,^ ^136,^ ^138,^ ^148^ Other common risk factors for falls included a hospital or ED visit,^126,^ ^137,^ ^146^ physical function testing thresholds,^49,^ ^96,^ ^107,^ ^122,^ ^123,^ ^128,^ ^136,^ ^138,^ ^140,^ ^148^ osteopenia or osteoporosis,^103,^ ^115,^ ^118,^ ^125,^ ^133^ and frailty.^127,^ ^128,^ ^142,^ ^148^ The baseline measures of health or functional status reported in the trials varied. The measures included living alone, experiencing a fall in the past year, physical function, ADL or IADL baseline score, QOL or self-reported health rating, number of medications, and other factors. Overall, at baseline, about 38 percent of participants in the included trials reported falling in the past year (k=12 reported people with one or more falls in the previous 12 months). Overall, among the 35 trials reporting the proportion of those at risk, 58 percent of participants were at increased risk of falling.

Figure 18 Baseline Fall Risk Ascertainment for Exercise Interventions

Abbreviations: ED = emergency department; NR = not reported.

Figure 18 shows baseline fall risk ascertainment for the exercise intervention trials. Fall risk factors include fall history, hospital/ED, physical function, osteoporosis/osteopenia, medications, frailty, fear of falling, other, and not reported.

##### Intervention Details

The 37 exercise interventions varied along several dimensions: supervision, individual versus group exercise, duration, frequency, and exercise components (Figures 19 and 20, Appendix F Table 3).

Figure 19 Delivery Mode for Exercise Interventions

Figure 19 shows delivery mode for exercise interventions. Modes of delivery include supervised group classes, supervised individual exercise, and unsupervised individual exercise.

Figure 20 Components of Exercise Interventions

Abbreviations: 3D = tai chi; PA = physical activity.

Figure 20 shows the components of exercise intervention trials. Components include gait, balance, functional training, strength/resistance, general physical activity, flexibility, endurance, Tai Chi, behavioral counseling, and cognitive task exercises. The majority of the exercise trials included gait, balance, functional training and/or strength and resistance training.

Supervision. Most of the intervention groups attended supervised group classes with an additional unsupervised individual component. Three trials,^101,^ ^106,^ ^155^ exceptionally, only utilized independent and unsupervised exercise sessions. Participants in the remaining 34 exercise trials were supervised during all or part of the intervention either in group classes,^96,^ ^98,^ ^103,^ ^107,^ ^108,^ ^113,^ ^115,^ ^117–120,^ ^122–124,^ ^126,^ ^127,^ ^136,^ ^138,^ ^140,^ ^146,^ ^148,^ ^151,^ ^153^ individual sessions,^49,^ ^102,^ ^109,^ ^125,^ ^134,^ ^137,^ ^142,^ ^149^ or both.^128,^ ^133^ Supervision was conducted by a specialized exercise instructor,^49,^ ^96,^ ^103,^ ^107,^ ^113,^ ^119,^ ^120,^ ^122,^ ^124,^ ^133,^ ^138,^ ^140,^ ^148,^ ^153^ physical or occupational therapist,^49,^ ^102,^ ^108,^ ^109,^ ^115,^ ^117–119,^ ^123,^ ^125,^ ^126,^ ^128,^ ^129,^ ^133,^ ^136–138,^ ^142,^ ^149,^ ^151^ health professional,^127,^ ^134,^ ^146^ or unspecified supervisor.^98^ Participants in the unsupervised trial were self-directed using a written program. One trial had entirely independently performed exercise programs with coaching via telephone followup.^155^

Format. Twenty-four interventions included group exercise alone or in combination with home-based exercise.^96,^ ^98,^ ^103,^ ^107,^ ^108,^ ^113,^ ^115,^ ^117–120,^ ^122–124,^ ^126–128,^ ^136,^ ^138,^ ^140,^ ^146,^ ^148,^ ^151,^ ^153^ Seven interventions included only supervised individual-based exercise.^49,^ ^102,^ ^109,^ ^125,^ ^134,^ ^142,^ ^149^ One trial’s exercise interventions (group and individual sessions) took place in a gym setting.^133^

Duration. Exercise programs ranged from 2 months^126^ to 30 months.^115^ The most common duration was 12 months in 15 trials.^96,^ ^102,^ ^109,^ ^113,^ ^119,^ ^120,^ ^124,^ ^125,^ ^128,^ ^134,^ ^137,^ ^140,^ ^142,^ ^149,^ ^155^

Frequency. Supervised exercise sessions were typically scheduled once to three times per week. The most common frequency was twice per week^117–120,^ ^122,^ ^124,^ ^127,^ ^128,^ ^133,^ ^140,^ ^142,^ ^151^ or three times per week.^98,^ ^103,^ ^113,^ ^125,^ ^126,^ ^136,^ ^146^

Exercise components. Most trials utilized multiple exercise components, including gait, balance, and functional training; strength and resistance; flexibility; tai chi/3-D training; general physical activity; and endurance (Figure 20; Appendix F Table 3). Nearly all exercise interventions included gait, balance, and functional training (30 of 37 trials). Two-thirds of the trials (25 of 37 trials)^49,^ ^96,^ ^98,^ ^101,^ ^102,^ ^108,^ ^109,^ ^113,^ ^115,^ ^117–119,^ ^125–128,^ ^133,^ ^134,^ ^137,^ ^138,^ ^140,^ ^142,^ ^146,^ ^149,^ ^151^ additionally included a strength and resistance training component and approximately one-fifth (8 of 37 trials)^102,^ ^107,^ ^108,^ ^117,^ ^123,^ ^126,^ ^136,^ ^142^ additionally included flexibility training. Thirteen trials^49,^ ^98,^ ^102,^ ^109,^ ^119,^ ^123,^ ^125,^ ^129,^ ^134,^ ^138,^ ^142,^ ^149,^ ^155^ included a general physical activity component. Six trials^96,^ ^98,^ ^102,^ ^119,^ ^128,^ ^142^ included an endurance component. Six trials^103,^ ^120,^ ^122,^ ^124,^ ^133,^ ^153^ included 3-D exercise like dance or tai chi. Thirteen^49,^ ^98,^ ^102,^ ^109,^ ^119,^ ^123,^ ^125,^ ^129,^ ^134,^ ^138,^ ^142,^ ^149,^ ^155^ of the trials employed general physical activity alone or in combination with another exercise component. Nine trials^102,^ ^109,^ ^119,^ ^129,^ ^137,^ ^138,^ ^140,^ ^149,^ ^155^ included lifestyle behavioral counseling including coaching and/or motivational interviewing.

Intervention adherence. In general, most of the participants were adherent to the exercise interventions. Thirty-five trials reported a measure of adherence or compliance with the exercise intervention, but the measures used to report adherence varied.^49,^ ^96,^ ^98,^ ^101–103,^ ^106,^ ^107,^ ^109,^ ^113,^ ^115,^ ^117–120,^ ^122–129,^ ^133,^ ^134,^ ^136–138,^ ^140,^ ^142,^ ^146,^ ^148,^ ^149,^ ^151,^ ^153^ Twelve trials reported 56 to 95 percent of sessions were attended. Three trials reported the mean number of sessions attended. The remaining 20 trials reported 42 to 94 percent were adherent based on varying definitions, such as the proportion attending all sessions, the proportion attending at least 50 percent of sessions, or those still exercising at 12 months.

Control groups. Control groups in the trials were instructed to maintain usual activity levels and/or received usual care, no intervention, minimal written information, or other minimal education about health or preventing falls, or a social visit.

##### Study Quality

Of the 37 trials, five were rated good quality with low risk of bias in all domains (Appendix A Figure 2).^49,^ ^106,^ ^117,^ ^151,^ ^153^ Thirty-two fair-quality trials had moderate risk of bias in one or two domains and three trials^102,^ ^109,^ ^123^ had moderate risk of bias in three domains. Twenty-one trials^96,^ ^98,^ ^102,^ ^107–109,^ ^113,^ ^115,^ ^118,^ ^124–126,^ ^128,^ ^129,^ ^133,^ ^134,^ ^136–138,^ ^146,^ ^149^ had moderate risk of bias due to insufficient reporting of randomization procedures or baseline characteristics differences. Two trials^102,^ ^123^ had moderate risk of bias for intervention deviations. Eight trials^103,^ ^109,^ ^119,^ ^123,^ ^127,^ ^136,^ ^140,^ ^142^ had moderate risk of bias for outcome measurement issues, typically recall of the falls outcome at longer than 1 month. Eighteen trials^96,^ ^98,^ ^101,^ ^102,^ ^107,^ ^109,^ ^115,^ ^120,^ ^122,^ ^123,^ ^126,^ ^134,^ ^138,^ ^140,^ ^146,^ ^148,^ ^149,^ ^155^ had high attrition, differential attrition, or missing data. To ascertain falls, most trials (24 of 36 trials)^49,^ ^98,^ ^102,^ ^106–109,^ ^117,^ ^122,^ ^124–126,^ ^128,^ ^129,^ ^133,^ ^134,^ ^137,^ ^138,^ ^146,^ ^148,^ ^149,^ ^151,^ ^153,^ ^155^ had the patient prospectively record falls on a calendar or in a diary or telephone text messaging, with or without additional confirmation (e.g., medical records or 3- to 6-month recall telephone calls). Twelve trials recorded falls by patient’s recall every 1 to 6 months,^96,^ ^101,^ ^103,^ ^115,^ ^118–120,^ ^123,^ ^127,^ ^136,^ ^140,^ ^142^ and two studies^113,^ ^133^ recorded falls resulting in injuries or fractures from administrative or hospital discharge records.

#### Detailed Results

##### Falls

Meta-analysis of 29 exercise trials (n=14,475) reporting the outcome of falls demonstrated a significant reduction in the rate of incident falls at the longest followup (6–24 months) in the exercise group compared to the control group, with substantial statistical heterogeneity (IRR, 0.85 [95% CI, 0.75 to 0.96]; I^2^=82.7%) (Figure 21; Appendix F Table 4).^49,^ ^96,^ ^102,^ ^103,^ ^106–109,^ ^115,^ ^118–120,^ ^122,^ ^124,^ ^125,^ ^128,^ ^129,^ ^134,^ ^136–138,^ ^140,^ ^142,^ ^146,^ ^149,^ ^153,^ ^155^ The baseline fall rate of control groups varied widely, from 0.26 per person-year^120^ to 5.0 per person-year.^103^ Individual trials reported substantial variation in effect and effect size, with IRR point estimates ranging from 0.47 in favor of the intervention group^102^ to 1.83 in favor of the control group.^149^

Figure 21 Key Question 1: Pooled Analysis of the Number of Falls at the Longest Followup for Exercise Interventions (k=29, n=14,475)

Abbreviations: CI = confidence interval; CG = control group; IG = intervention group; IRR = incidence rate ratio; n = number; p-y = person-year.

Figure 21 shows a forest plot of the number of falls at the longest followup for exercise interventions (k=29, n=14,475). The pooled incidence rate ratio is 0.85 with a 95% confidence interval of 0.75 to 0.96.

Two trials^137,^ ^149^ were notable for the statistically significantly higher fall rate in the exercise group compared to the control group (IRR, 1.43 [95% CI, 1.06 to 1.92] and 1.83 [95% CI, 1.23 to 2.74]). The first study^137^ recruited patients discharged from geriatric care, rehabilitation, and orthopedic wards at any of four public hospitals in Sydney, Australia. Participants had a mean age of 81 years, and the authors note that their recruited population was less healthy than those of other trials reporting a beneficial effect of exercise on falls. The intervention was an individually based program designed to improve balance; participants received instruction from a physical therapist and were asked to do the exercises at home six times a week. At 12 months, 57 percent were participating in exercise sessions and 29 percent were no longer exercising. The second trial^149^ was set in Sweden where recruitment required all participants to use walking aids and/or home help services; participants had a mean age of 83 years, and the control group falls rate was low relative to the other trials. The intervention was a 12-month independent home-based Otago Exercise Program with home visits and telephone support incorporating behavior change. The authors note that long winters could have affected the ability of older adults to take outdoor walks (only 52% of intervention participants were walking outdoors twice per week) and lessened the impact of the intervention. They also note their recruited population may have been more frail than other trials reporting a beneficial effect of the Otago Exercise Program on falls.

We explored heterogeneity by examining country where the trial took place, publication year, study quality, recruitment setting, selective recruitment for increased fall risk, control group event rate, mean age, duration of followup, specific exercise components (e.g., strength/resistance training), presence of a behavior change component as part of the intervention, presence of cognitive task exercises as part of the intervention, group versus individual exercise sessions, and intervention duration (Appendix F Table 5). However, we were unable to explain the high heterogeneity by any single variable after adjusting for multiple comparisons. Visual examination of the funnel plot for the 29 pooled trials (not included in this report) did not suggest a publication bias, and the Egger’s test was not statistically significant (p=0.68).

##### People With a Fall and People With Recurrent Falls

Meta-analysis of 25 exercise trials (n=13,384) reporting the number of people with a fall demonstrated a reduced risk of falling at the longest followup (6–24 months) in the exercise group compared to the control group (RR, 0.92 [95% CI, 0.87 to 0.98]; I^2^=24.3%) (Figure 22; Appendix F Table 6).^49,^ ^96,^ ^98,^ ^101,^ ^102,^ ^106–108,^ ^117,^ ^119,^ ^120,^ ^122,^ ^123,^ ^125–127,^ ^129,^ ^137,^ ^138,^ ^148,^ ^149,^ ^153,^ ^155^ Individual trials reported substantial variation in effect and effect size, with wide and overlapping confidence intervals and RR point estimates ranging from 0.40^117^ to 1.66.^120^ The results from two trials were consistent with a statistically significant reduction in the number of people with a fall in the exercise group compared to the control group (14% to 60% reduced risk).^107,^ ^117^ One trial^137^ reported a statistically significant increase in the number of people with a fall in the exercise group compared to the control group (RR, 1.38 [95% CI, 1.11 to 1.72]) and two reported a nonstatistically significant association between exercise and people with a fall.^101,^ ^120^ The remaining trials showed a nonsignificant benefit in terms of fewer people with a fall in the exercise group than in the control group.^49,^ ^96,^ ^98,^ ^102,^ ^106,^ ^108,^ ^119,^ ^122,^ ^123,^ ^125–127,^ ^133,^ ^138,^ ^148,^ ^149,^ ^153,^ ^155^

Figure 22 Key Question 1: Pooled Analysis of People With 1 or More Falls at the Longest Followup for Exercise Interventions (k=25, n=13,384)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 22 shows a forest plot of people with one or more falls at the longest followup for exercise interventions (k=25, n=13,384). The pooled relative risk is 0.92 with a 95% confidence interval of 0.87 to 0.98.

Nine trials (n=8,502) reporting people with recurrent falls (two or more falls) showed no statistically significant association between exercise interventions and the number of people experiencing recurrent falls (two or more falls) (RR, 0.77 [95% CI, 0.57 to 1.04]; I^2^=45.0%) (Figure 23; Appendix F Table 6).

Figure 23 Key Question 1: Pooled Analysis of People With 2 or More Falls at the Longest Followup for Exercise Interventions (k=9, n=8,502)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 23 shows a forest plot of people with two or more falls at the longest followup for exercise interventions (k=9, n=8,502). The pooled relative risk is 0.77 a 95% confidence interval of 0.57 to 1.04.

We explored heterogeneity by examining the country where the trial took place, publication year, study quality, recruitment setting, selective recruitment for increased fall risk, proportion of control group with a fall, mean age, duration of followup, specific exercise components (e.g., strength/resistance training), presence of a behavior change component as part of the intervention, presence of cognitive task exercises as part of the intervention, group versus unsupervised individual exercise sessions, and intervention duration (Appendix F Table 7). However, we were unable to explain the high heterogeneity by any single variable. Visual examination of the funnel plot for the 25 pooled trials (not included in this report) did not suggest a publication bias, and the Egger’s test was not statistically significant (p=0.12).

##### Falls Resulting in Injury or Medical Care and Fall-Related Fractures

Meta-analysis of 12 exercise trials (n=3,984) reporting the outcome of injurious falls demonstrated a significant reduction in the rate of injurious falls at the longest followup (6 to 60 months) in the exercise group compared to the control group (IRR, 0.84 [95% CI, 0.74 to 0.95]; I^2^=14.6%) (Figure 24; Appendix F Table 8).^96,^ ^106–108,^ ^113,^ ^129,^ ^134,^ ^137,^ ^138,^ ^149^ Specific definitions for fall-related injury outcomes were reported as falls resulting in injuries,^96,^ ^106,^ ^108,^ ^113,^ ^129,^ ^134,^ ^151^ fall-related injuries,^133,^ ^138,^ ^149^ falls resulting in serious injuries,^107^ and falls resulting in medical care.^137^ Four of the trials reported statistically significantly reduced rates of fall-related injuries,^106,^ ^113,^ ^138^ with significant effects ranging from 0.46 ^151^to 0.80.^113^ Two trials^137,^ ^149^ reported a nonstatistically significant increase in the rate of injuries among the intervention group compared to the control group (IRR, 1.14 [95% CI, 0.76 to 1.72] and 1.35 [95% CI, 0.76 to 2.42]).

Figure 24 Key Question 1: Pooled Analysis of the Number of Falls Resulting in Injury or Medical Care at the Longest Followup for Exercise Interventions (k=12, n=3,984)

Abbreviations: CI = confidence interval; CG = control group; IG = intervention group; IRR = incidence rate ratio; n = number; p-y = person-year.

Figure 24 shows a forest plot of falls resulting in injury or medical care at the longest followup for exercise interventions (k=12, n=3,984). The pooled incidence rate ratio is 0.84 with a with a 95% confidence interval of 0.74 to 0.95.

Eight trials (n=8,537) reporting fall-related fractures show no statistically significant difference between the intervention and control groups (IRR, 0.81 [95% CI, 0.57 to 1.15]; I^2^=39.1%) (Figure 25; Appendix F Table 9).^49,^ ^113,^ ^115,^ ^118,^ ^119,^ ^128,^ ^137^

Figure 25 Key Question 1: Pooled Analysis of the Number of Fall-Related Fractures at the Longest Followup for Exercise Interventions (k=8, n=8,537)

Abbreviations: CI = confidence interval; CG = control group; IG = intervention group; IRR = incidence rate ratio; n = number; p-y = person-year.

Figure 25 shows a forest plot of the number of fall-related fractures at the longest followup for exercise interventions (k=8, n=8,537). The pooled incidence rate ratio is 0.81 with a 95% confidence interval of 0.57 to 1.15.

##### People With a Fall Resulting in Injury or Medical Care and Fall-Related Fracture

Pooled results from nine trials (n=3,924) showed no statistically significant association between exercise interventions and a reduction in people experiencing an injurious fall at 6 to 60 months of followup (RR, 0.90 [95% CI, 0.79 to 1.02]; I^2^=26.7%) (Figure 26; Appendix F Table 10). Relative risks among the exercise group ranged from 0.61^113^ to 1.22.^149^

Figure 26 Key Question 1: Pooled Analysis of People With a Fall Resulting in Injury or Medical Care at the Longest Followup for Exercise Interventions (k=9, n=3,924)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 26 shows a forest plot of the number of people with a fall resulting in injury or medical care at the longest followup for exercise interventions (k=9, n=3,924). The incidence rate ratio is 0.90 with a 95% confidence interval of 0.79 to 1.02.

Four trials (n=7,994) showed mixed results for people with fall-related fractures, with two trials reporting nonsignificant increased risk (RR, 1.13 [95% CI, 0.84 to 1.51] and 1.95 [95% CI, 0.22 to 17.28]),^49,^ ^119^ one trial reporting a nonstatistically significant decreased risk (RR, 0.62 [95% CI, 0.38 to 1.01]),^133^ and one trial reporting statistically significant decreased risk (RR, 0.36 [95% CI, 0.15 to 0.89])^115^ at 6 to 30 months of followup (Appendix F Table 11).

##### Mortality

Pooled analysis of 15 trials (n=10,461) showed no significant association with all-cause mortality at longest followup (12–85 months) in the exercise group compared to the control group (RR, 0.87 [95% CI, 0.71 to 1.06]; I^2^=0.0%) (Figure 27; Appendix F Table 13). Individual study results showed no statistically significant differences, and RRs varied widely (0.16^96,^ ^134^ to 1.30^119^), with wide confidence intervals. The few deaths in most trials made estimates unstable.

Figure 27 Key Question 1: Pooled Analysis of Mortality at the Longest Followup for Exercise Interventions (k=15, n=10,461)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 27 shows a forest plot of mortality at the longest followup for exercise interventions (k=15, n=10,461). The incidence rate ratio is 0.87 with a 95% confidence interval of 0.71 to 1.06.

##### Other Outcomes

Qualitative analysis demonstrates no effect on people with a hospitalization or ED visit (k=1), people institutionalized (k=3), IADLs (k=6), or QOL (k=13). Of the 13 trials reporting QOL,^49,^ ^103,^ ^106,^ ^109,^ ^119,^ ^120,^ ^124,^ ^129,^ ^137,^ ^140,^ ^149,^ ^151,^ ^155^ five measured QOL using the SF-12 or SF-36,^49,^ ^103,^ ^120,^ ^124,^ ^137^ six measured QOL using the EuroQol 5D visual analog scale (EQ-5D VAS) or EuroQol 5D 3-levels (EQ-5D-3L),^106,^ ^109,^ ^119,^ ^129,^ ^140,^ ^149^ and two measured QOL using different scales (Liepad QOL^151^ and Australian QOL^155^). These trials demonstrated no association between exercise interventions and mean differences in QOL. The remaining outcomes were reported in a small proportion of the exercise trials and results are shown in the appendix (Appendix F Tables 14–16).

##### Harms

Half of the trials reported harms (19 of 37), with generally minor musculoskeletal side effects being most common; serious side effects were generally very rare. Overall, the description of harms ascertainment was sparse; measurement varied from capturing spontaneous, self-reported comments to repeated questionnaires asking about harms. Nineteen trials (n=6,985)^49,^ ^101,^ ^106,^ ^107,^ ^113,^ ^119,^ ^120,^ ^124,^ ^125,^ ^127,^ ^129,^ ^133,^ ^137,^ ^138,^ ^140,^ ^142,^ ^148,^ ^149,^ ^151^ reported on harms in the intervention groups at 6 to 24 months (Appendix F Table 16). Five of these trials^119,^ ^120,^ ^140,^ ^148,^ ^151^ also reported harms in the control group for comparison.

Seventeen trials^49,^ ^101,^ ^106,^ ^107,^ ^113,^ ^119,^ ^124,^ ^125,^ ^127,^ ^129,^ ^133,^ ^137,^ ^138,^ ^142,^ ^148,^ ^149,^ ^151^ reported any adverse events occurring during the exercise intervention sessions, ranging from 0 percent^49,^ ^124,^ ^125,^ ^138,^ ^148^ to 58 percent.^142^ These adverse events directly related to the exercise intervention were largely musculoskeletal discomfort and pain symptoms, particularly in the trial reporting high rates of adverse events (one trial^142^ reporting 58% in the intervention group and no adverse event reporting in the control group). Zero percent^149^ to 11 percent^142^ reported falls during the intervention exercise program. Serious adverse events related to the exercise intervention were measured in seven trials,^49,^ ^101,^ ^107,^ ^119,^ ^133,^ ^140,^ ^151^ with half of these trials^49,^ ^101,^ ^133,^ ^151^ reporting zero serious adverse events related to the intervention and one trial^119^ reporting less than 1 percent serious adverse events related to the exercise (2/281). One trial^107^ reported a fall-related wrist fracture (1/352). One trial reported angina pectoris-like chest pain (2/457) and pre-syncopal symptoms (2/457) during the intervention.^133^ Another trial^140^ reported overall adverse events as 18 percent in the intervention group and 12 percent in the control group; however, only one adverse event (1/334), a hip fracture, was attributed to the exercise session.

### Exercise + Education Interventions

#### Summary of Results

The evidence examining the effectiveness of exercise in combination with education interventions to prevent falls consists of four trials (n=1,047). In three of four trials, 100 percent of the participants were at increased risk for falling; in the fourth trial, 27 percent were at increased risk. Two trials recruited only participants with osteoporosis or osteopenia and the other two trials used fall^160^ or fracture history to determine risk. Qualitative analysis showed overall no effect on falls (IRR range, 0.61 [95% CI, 0.40 to 0.94] to 1.08 [95% CI, 0.70 to 1.67]), people with a fall (RR range, 0.87 [95% CI, 0.57 to 1.34] to 1.07 [95% CI, 0.57 to 2.00]), or falls resulting in injury or medical care (IRR range, 0.58 [95% CI, 0.33 to 1.01] to 1.02 [0.61 to 1.69]). The evidence on mortality was scant (RR, 0.67 [95% CI, 0.11 to 3.97] and 1.0 [95% CI, 0.06 to 15.72]). Conclusions about the harms of exercise plus education interventions are limited by the lack of control group comparison. While musculoskeletal pain was common, serious adverse events were very rare. Overall, the evidence is limited by few trials, imprecision demonstrated by wide confidence intervals, and largely insufficient evidence.

#### Characteristics of Included Studies

We included four trials (in four articles) of exercise plus education interventions (n=1,047).^160–166^ Of the four trials, one was included in the previous review^160^ and three were newly identified.^161,^ ^162,^ ^166^

##### Study Characteristics

We identified one fair-quality^166^ and three good-quality^160–162^ RCTs (n=1,047) examining the effectiveness of exercise plus educational interventions on reducing falls and/or fall-related injuries at 12 to 18 months of followup (Table 3; Appendix G Table 1). One trial was conducted in the United States,^160^ two in Australia,^161,^ ^162^ and one in the Netherlands.^166^ Trial sizes ranged from 96^166^ to 453^160^ participants randomized to exercise plus education and control arms (for our analysis).

##### Population Characteristics

All trials recruited community-dwelling adults ages 60 to 65 years or older (Table 3; Appendix G Tables 1 and 2). The mean age ranged from 67 years^162^ to 78 years.^161^ The majority of the trials’ participants were women, ranging from 73 percent^162^ to 94 percent.^166^ Only one trial reported race and ethnicity and participants were almost exclusively White.^160^ The trials did not report measures of socioeconomic status. One trial recruited participants from hospitals;^161^ two trials recruited from the community through advertisements;^160,^ ^162^ and one trial had multiple strategies to identify those with osteoporosis/osteopenia through rheumatology departments, the Osteoporosis Patient Council, and local newspapers.^166^

Three of the four trials solely recruited participants at increased risk for falls with the risk factors being history of fracture and/or osteopenia/osteoporosis (Figure 28; Appendix G Table 2).^161,^ ^162,^ ^166^ The fourth trial did not exclusively recruit based on fall risk; however, 27 percent of the participants in that trial reported experiencing a fall in the previous 3 months.^160^ The baseline measures of health or functional status reported in the trials demonstrated a wide variation. For example, the number of medications and comorbidities varied widely; the number of mean medications varied from 2.5^166^ to 6.5.^161^

Figure 28 Baseline Fall Risk Ascertainment for Other Intervention Groups

Figure 28 shows baseline fall risk ascertainment for other intervention groups. The figure is sorted by intervention category and the fall risk factors include fall history, hospital/emergency department, physical function, osteoporosis/osteopenia, medications, frailty, fear of falling, other, and not reported.

##### Intervention Details

The four exercise plus education interventions varied along several dimensions: supervision, individual versus group exercise, duration, frequency, exercise components, and inclusion of behavioral counseling (Appendix G Table 3). All included exercise plus education and two of these trials additionally included a behavioral counseling component with health coaching and/or motivational interviewing.^161,^ ^162^ One trial also communicated results with the participants’ primary care providers.^160^

Education intervention. The educational components of these programs typically included multiple sessions focused on fall prevention with or without education about osteoporosis. The educational components varied in intensity and included: a one-hour education class each month for 12 months;^160^ three educational seminars over 18 months;^162^ seven two-hour group education sessions over 12 months;^161^ and 11 sessions over 5.5 weeks.^166^

Exercise supervision/individual versus group. Three of the trials^160,^ ^162,^ ^166^ had supervised group sessions, while one trial^161^ had supervised individual sessions plus self-directed prescribed exercise. Supervision was conducted by a specialized exercise instructor,^160,^ ^162^ physical therapist,^161^ or occupational therapist.^166^

Exercise frequency and duration. Supervised exercise sessions were scheduled two^166^ to three^160,^ ^162^ times per week,^160,^ ^162^ with durations ranging from 1 month^166^ to 18 months.^162^

Exercise components. All trials included gait, balance, and functional training as well as strength/resistance training. Two of the trials additionally included flexibility^160,^ ^162^ and two trials included general physical activity.^160,^ ^166^

Control Groups. Control groups received usual care^161,^ ^166^ or a minimal intervention.^160,^ ^162^

##### Study Quality

Three exercise plus education trials were good quality, with low risk of bias in all domains (Appendix A Figure 3).^160–162^ One trial had a low risk of bias in all domains except was rated to have a moderate risk of bias in the randomization/confounders domain based on scant baseline characteristics reporting.^166^ All four trials used calendar diaries for falls ascertainment.

#### Detailed Results

##### Falls

Only one of the trials—a 1-month intervention in participants with osteopenia/osteoporosis—showed a statistically significant association between the intervention and reduction in the number of falls (IRR, 0.61 [95% CI, 0.40 to 0.94]) (Figure 29; Appendix G Table 4).^166^ The remaining three trials reported nonsignificant results with wide confidence intervals and IRRs ranging from 0.75 (95% CI, 0.52 to 1.09)^160^ to 1.08 (95% CI, 0.70 to 1.67).^162^

Figure 29 Key Question 1: Pooled Analysis of the Number of Falls at the Longest Followup for Other Interventions

Abbreviations: CI = confidence interval; CG = control group; Edu = education; IG = intervention group; IRR = incidence rate ratio; n = number; p-y = person-year.

Figure 29 shows a forest plot of the number of falls at the longest followup for other interventions. For education (k=1), the incidence rate ratio (IRR) is 0.68 with a 95% confidence interval of 0.57 to 0.83. For environment (k=6), the pooled IRR is 0.83 with a 95% confidence interval of 0.59 to 1.18. For exercise+education (k=4), the IRRs range from 0.75 to 1.08, with 95% confidence intervals ranging from 0.52 to 1.09 to 0.70 to 1.67, respectively. For exercise+environment (k=3), the IRRs range from 0.81 to 0.99, with 95% confidence intervals ranging from of 0.60 to 0.90 to 0.82 to 1.19, respectively. For medication review/modification (k=1), the IRR is 1.01 with a 95% confidence interval of 0.81 to 1.26. For psychological interventions (k=2), the IRRs are 0.86 and 0.86, with 95% confidence intervals of 0.65 to 1.13 and 0.65 to 1.14, respectively.

##### People With a Fall and People With Recurrent Falls

None of the four trials reported a statistically significant association between the intervention and people with one or more falls. Confidence intervals were wide and point estimates for the RRs ranged from 0.87 (95% CI, 0.57 to 1.34)^166^ to 1.07 (95% CI, 0.57 to 2.00) (Figure 30; Appendix G Table 5).^162^

Figure 30 Key Question 1: Pooled Analysis of People With 1 or More Falls at the Longest Followup for Other Interventions

Abbreviations: CG = control group; CI = confidence interval; Edu = education; IG = intervention group; n = number; RR = relative risk.

Figure 30 shows a forest plot of the number of people with one or more falls at the longest followup for other interventions. For education (k=1), the relative risk (RR) is 0.90 with a 95% confidence interval of 0.73 to 1.10. For environment (k=6), the pooled RR is 0.94 with a 95% confidence interval of 0.83 to 1.07. For exercise+education (k=4), the RRs range from 0.87 to 1.07 with 95% confidence intervals ranging from 0.57 to 1.34 and 0.57 to 2.00, respectively. For exercise+environment (k=3), the RRs range from 0.81 to 0.99 with 95% confidence intervals ranging from 0.60 to 1.08 and 0.82 to 1.19, respectively. For medication review/ modification (k=3), the RRs range from 1.02 to 1.16, with a 95% confidence intervals ranging from 0.79 to 1.31 and 0.55 to 2.41, respectively. For psychological (k=2), the RRs are 0.71 and 0.96, with 95% confidence intervals of 0.58 to 0.90 and 0.80 to 1.15, respectively.

Two trials reported people experiencing recurrent falls,^161,^ ^162^ with no significant differences between the intervention and control groups (RR, 1.00 [95% CI, 0.65 to 1.53] and 1.59 [95% CI, 0.67 to 3.79]) (Figure 31; Appendix G Table 5).

Figure 31 Key Question 1: Forest Plot of People With 2 or More Falls at the Longest Followup for Other Interventions

Abbreviations: CG = control group; CI = confidence interval; Edu = education; IG = intervention group; n = number; RR = relative risk.

Figure 31 shows a forest plot of the number of people with two or more falls at the longest followup for other interventions. For education (k=1), the relative risk (RR) is 0.74 with a 95% confidence interval of 0.52 to 1.04. For environment (k=4), the RRs range from 0.36 to 1.04 with 95% confidence intervals ranging from 0.07 to 1.75 to 0.89 to 1.22, respectively. For exercise+education (k=2), the RRs are 1.00 and 1.59, with 95% confidence intervals of 0.65 to 1.53 and 0.67 to 3.79, respectively. For exercise+environment (k=2), the RRs are 0.68 and 0.73, with 95% confidence intervals of 0.46 to 1.01 to 0.54 to 0.99, respectively. For medication review/modification (k=2), the RRs are 1.16 and 2.10, with 95% confidence intervals of 0.79 to 1.71 and 0.56 to 7.83, respectively. For psychological (k=2), the RRs are 0.59 and 0.89, with 95% confidence intervals of 0.65 to 1.19 and 0.43 to 0.81, respectively.

##### Falls Resulting in Injury or Medical Care and Fall-Related Fractures

Three trials reported falls resulting in injuries or medical care, showing no significant differences, with IRRs ranging from 0.58 (95% CI, 0.33 to 1.01) to 1.02 (95% CI, 0.61 to 1.69)^160,^ ^161,^ ^166^ (Figure 32; Appendix G Table 5). Two trials^161,^ ^166^ reported fall-related fractures, also showing no significant differences between the intervention and control groups (IRR, 0.64 [95% CI, 0.30 to 1.35] and 0.32 [95% CI, 0.03 to 3.07]) (Appendix G Table 6).

Figure 32 Key Question 1: Forest Plot of the Number of Falls Resulting in Injury or Medical Care at the Longest Followup for Other Interventions

Abbreviations: CI = confidence interval; CG = control group; IG = intervention group; IRR = incidence rate ratio; n = number; p-y = person-year.

Figure 32 shows a forest plot of the number of falls resulting in injury or medical care at the longest followup for other interventions. For environment (k=2), the incidence rate ratios (IRRs) are 0.97 and 1.06, with 95% confidence intervals of 0.75 to 1.26 and 0.93 to 1.21, respectively. For exercise+education (k=3), the RRs range from 0.58 to 1.02, with 95% confidence intervals ranging from 0.33 to 1.01 to 0.61 to 1.69, respectively. For exercise+environment (k=2), the RRs are 0.88 and 1.18 with 95% confidence intervals of 0.67 to 1.15 and 0.76 to 1.83 to 0.99, respectively. For medication review/modification (k=1), the RR is 0.87 with 95% confidence interval of 0.62 to 1.24. For psychological (k=2), the RRs are 0.78 and 1.42, with 95% confidence intervals of 0.45 to 1.35 and 0.96 to 2.10, respectively.

##### People With a Fall Resulting in Injury or Medical Care and Fall-Related Fracture

No trials reported people with a fall resulting in injury, medical care, or fracture.

##### Mortality

Two of the trials^160,^ ^162^ reported no statistically significant differences in mortality, with RRs of 0.67 (95% CI, 0.11 to 3.97) and 1.00 (95% CI, 0.06 to 15.72), with wide confidence intervals. The few deaths in most trials made estimates imprecise (Figure 33; Appendix G Table 7).

Figure 33 Key Question 1: Forest Plot of Mortality at the Longest Followup for Other Interventions

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number; RR = relative risk.

Figure 33 shows a forest plot of mortality at the longest followup for other interventions. For environment (k=1), the relative risk (RR) is 1.87 with 95% confidence interval of 0.87 to 4.01. For exercise+education (k=2), the RRs range from 0.67 to 1.00, with 95% confidence intervals ranging from 0.11 to 3.97 to 0.06 to 15.72, respectively. For exercise+environment (k=1), the RR is 0.34 with a 95% confidence interval of 0.09 to 1.23. For medication review/modification (k=2), the RRs are 0.40 and 1.50, with 95% confidence intervals of 0.10 to 1.55 and 0.26 to 8.77, respectively. For psychological (k=2), the RRs are 0.98 and 1.01, with 95% confidence intervals of 0.36 to 2.81 and 0.77 to 1.25, respectively.

##### Other Outcomes

One trial (N=336) reported no statistically significant effect of the exercise plus education trials on falls requiring hospitalizations.^161^ IADLs, institutionalizations, and QOL were not reported in any of these trials (Appendix G Table 8).

##### Harms

All four trials (n=522 analyzed in the intervention group only) reported adverse events associated with the intervention but none reported adverse events in the control group for comparison^160–162,^ ^166^ (Appendix G Table 9). Two trials reported no adverse events.^160,^ ^166^ The most common complaints in the other two trials were musculoskeletal^161,^ ^162^ (foot, knee, shoulder pain) and many were related to pre-existing injuries.^162^ A total of one compression fracture,^161^ one fracture complication,^161^ and one wrist fracture^162^ were the most serious, yet rare, events that occurred.

### Exercise + Environment Interventions

#### Summary of Results

We identified three trials (n=935) examining the effectiveness of interventions combining exercise and an environment assessment with or without modifications (i.e., a single home visit to reduce home hazards) in older adults of varying risk. There is limited evidence based on the three trials whether exercise plus environment interventions reduce falls and fallers, and meta-analysis was not possible. There appeared to be no statistically significant effect of the interventions on people with a fall (RR range, 0.81 [95% CI, 0.60 to 1.08] to 0.99 [95% CI, 0.82 to 1.19]). The evidence was inconclusive for the number of falls (IRR, 0.73 [95% CI, 0.60 to 0.90] and 0.78 [95% CI, 0.57 to 1.07]), injurious falls or falls resulting in medical care (IRR, 0.88 [95% CI, 0.67 to 1.15] and 1.18 [95% CI, 0.76 to 1.83]), people with an injurious fall (RR, 0.63 [95% CI, 0.40 to 0.98]), people with fall-related fracture (RR, 1.08 [95% CI, 0.45 to 2.59]), people hospitalized or who visited the hospital/ED (RR, 1.46 [95% CI, 0.81 to 2.64]), mortality (RR 0.34 [95% CI, 0.09 to 1.23]), QOL, and harms. No trials reported the number of fall-related fractures, people transitioning to institutional care, or IADLs.

#### Characteristics of Included Studies

We included three trials (in four articles) of interventions combining exercise and an environment assessment with or without modifications (i.e., a single home visit to reduce home hazards).^105,^ ^108,^ ^167,^ ^168^ These interventions are hereafter described as exercise plus environment. Of the three included trials, one was included in the previous review^108^ and two were newly identified.^167,^ ^168^

##### Study Characteristics

We identified one good-quality^167^ and two fair-quality^108,^ ^168^ RCTs (n=935) with a primary or secondary aim of examining the effectiveness of exercise plus environment assessment interventions on falls, fall-related injuries, or both (Table 3; Appendix H Table 1). Two trials were conducted in Australia^108,^ ^168^ and one in Singapore.^167^ Trials were small, with the number of randomly allocated participants to relevant groups ranging from 272^168^ to 354.^167^ Followup time ranged from 6 to 18 months.

##### Population Characteristics

Two trials recruited participants age 65 years or older;^167,^ ^168^ one trial recruited participants age 70 years or older (Table 3; Appendix G Tables 1 and 2).^108^ The mean age ranged from 76 years^108^ to 82 years.^168^ The proportion of women ranged from 49^168^ to 77^167^ percent. Only one study conducted in Singapore reported race and ethnicity; 83 percent of participants were of Chinese ethnicity.^167^ Measures of socioeconomic status were reported in two trials.^167,^ ^168^ One study^168^ excluded patients with severe cognitive impairment.

All three trials recruited community-dwelling adults. Trials recruited participants from a population-based register,^108^ the ED,^167^ or health-related services, including elder care, memory and cognitive disorders clinics, and dementia-specific day centers.^168^ All three trials recruited patients at increased risk for falls, defined as either a history of falls (in the previous month or 12 months)^108,^ ^168^ or presentation to the ED for a fall or fall-related injury (Figure 28; Appendix G Table 2).^167^ Measures of health or functional status at baseline in the trials varied and included comorbid conditions, number of medications, and cognitive impairment. Two trials reported mean number of medications as 3.4^108^ and 5.6.^168^ One trial^167^ reported that nearly one-half (47%) of participants had multiple comorbidities and another trial^168^ reported that the mean number of comorbidities was 3.5.

##### Intervention Details

All trials included an intervention combining an environmental assessment with an exercise component—which was delivered in a group, individual, or a combination format (Appendix H Table 3). One trial included 15 weeks of group strength, balance, and flexibility classes supervised by a physiotherapist.^108^ Classes were supplemented by daily home exercises and a home visit to modify hazards. Home hazard modifications were completed either by the participants or through a city program.^108^ Another trial included 24 weeks of group strength and balance exercise classes twice per week for participants with adequate physical performance (i.e., SPPB score >6) and progressive home-based exercises (12 sessions three times per week for 3 months) led by a physical therapist for participants with lower physical performance (i.e., SPPB score>7).^167^ Physical therapists also assessed the participants’ homes for environmental hazards and provided brief advice and educational materials on falls prevention. The third trial included an individually tailored, home-based strength and balance exercise program as well as home safety visits to modify hazards.^168^ Occupational therapists assessed participants’ homes and provided home safety recommendations and modifications (90- to 120-minute sessions).^168^

Intervention adherence. Adherence was variably reported among the three trials. Adherence to the exercise portion of the intervention ranged from 60 percent^108^ (those attending at least half the sessions) to 98 percent^167^ (participants completing the prescribed number of events). Adherence to the environment modifications was reported in two studies, with 55 percent fully completing home safety recommendations in one trial^168^ and 76 percent receiving help to make modifications for home hazards in the second.^108^

Control group. In all three trials, the control groups received usual care from their healthcare providers.^108,^ ^167,^ ^168^ In one trial,^108^ the control group received a delayed intervention. In another trial, the control group received educational materials on falls prevention.^167^

##### Study Quality

One of the three trials was rated good quality, with low risk of bias across all assessed domains (Appendix A Figure 3).^108^ The remaining two trials were rated fair quality, with moderate risk in at least one of the assessed domains.^167,^ ^168^ In one trial,^168^ there was differential attrition between the intervention and control groups; this trial was rated to have moderate risk of bias due to missing data. The other fair-quality trial did not report baseline characteristics by study group and was rated moderate risk due to confounding.^108^ In all three trials, participants used diaries or calendars to record the outcomes of falls prospectively. Two trials also used telephone calls to verify falls or followup with participants who failed to return their calendars.^167,^ ^168^

#### Detailed Results

##### Falls

Two exercise plus environment intervention trials (n=581)^108,^ ^168^ showed inconclusive results in the reduction in number of falls at the longest followup (9–18 months) (Figure 29; Appendix H Table 4). One trial (n=272)^108^ reported a statistically significant reduction in falls at the 18-month followup (IRR, 0.73 [95% CI, 0.60 to 0.90]). The other trial (n=309) also reported a reduction in the number of falls for the intervention compared to the control group at 12 months of followup, but the relative effect was not statistically significant (IRR, 0.78 [95% CI, 0.57 to 1.07]).^168^

##### People With a Fall and People With Recurrent Falls

Three exercise plus environment trials (n=935)^108,^ ^167,^ ^168^ reported the number of people with one or more falls and showed no differences between the intervention groups and the control groups at the longest followup (9–18 months) (RR range, 0.81 [95% CI, 0.60 to 1.08] to 0.99 [95% CI, 0.82 to 1.19]) (Figure 30; Appendix H Table 5). Two trials (n=581)^108,^ ^168^ reported people experiencing two or more falls, but only one showed a statistically significant reduction at 12 months (RR, 0.73 [95% CI, 0.54 to 0.99]) (Figure 31; Appendix H Table 5).

##### Falls Resulting in Injury or Medical Care and Fall-Related Fractures

Two trials reported falls resulting in injuries or falls requiring medical attention at 12 and 18 months.^108,^ ^168^ One trial (n=272)^108^ reported a nonstatistically significant reduction in falls resulting in injuries (IRR, 0.88 [95% CI, 0.67 to 1.15]), while the other trial^168^ reported a nonstatistically significant increase in falls resulting in medical attention (IRR, 1.18 [95% CI, 0.76 to 1.83]) (Figure 32; Appendix H Table 6). No exercise plus environment trials reported fractures.

##### People With a Fall Resulting in Injury or Medical Care and Fall-Related Fracture

One trial (n=354)^167^ reported a statistically significant reduction in people experiencing an injurious fall at 9 months (RR, 0.63 [95% CI, 0.40 to 0.98]). One trial (n=309)^168^ reported people with a fall-related fracture, but there was no difference between the intervention group and control groups at the 12-month followup (RR, 1.08 [95% CI, 0.45 to 2.59]) (Appendix H Table 7).

##### Mortality

One exercise plus environment trial (n=309)^168^ reported mortality, but there was no difference between the intervention group and control group at the 12-month followup (RR, 0.34 [95% CI, 0.09 to 1.23]) (Figure 33; Appendix H Table 8).

##### Other Outcomes

One trial (n=309)^168^ reported people with a fall-related presentation or hospitalization, but there was no difference between the intervention group and control group at 12 months (Appendix H Table 7). The same trial (n=309)^168^ reported no difference in QOL at 12-month followup (Appendix H Table 9). No exercise plus environment trials reported on IADLs or people transitioning to institutional care.

##### Harms

One trial (IG n=153)^168^ reported four falls attributed to the exercise plus environment intervention. One fall occurred while a participant was descending the stairs during an occupational therapy home assessment and three participants fell during an exercise session.^168^ No significant injuries were associated with these falls.

### Environment Assessment (With or Without Modifications) Interventions

#### Summary of Results

We identified six trials (n=4,162) that examined the effect of an environment assessment with or without modifications (i.e., a single home visit to reduce home hazards) on falls in older adults. All but one study was conducted outside of the United States. In pooled analysis, there was no statistically significant effect on falls (IRR, 0.83 [95% CI, 0.59 to 1.18]; I^2^=82.2%) or people with a fall (RR, 0.94 [95% CI, 0.83 to 1.07]; I^2^=20.3%) The results were inconclusive for the remaining outcomes, where only one or two trials reported the outcome: falls resulting in injury or medical care (IRR, 0.97 [95% CI, 0.75 to 1.26] and 1.06 [95% CI, 0.93 to 1.21]), mortality (RR, 1.87 [95% CI, 0.87 to 4.01]), falls resulting in hospitalization (IRR, 0.67 [95% CI, 0.38 to 1.21]), QOL, and IADLs. In the two trials reporting harms, there were no adverse events or serious adverse events.

#### Characteristics of Included Studies

We included six trials (in 10 articles) with a primary or secondary aim of examining the effectiveness of environment assessment with or without modification interventions on falls and/or fall-related injuries.^105,^ ^108,^ ^169–176^ Three were included in the previous review^108,^ ^173,^ ^176^ and three were newly identified.^169,^ ^170,^ ^174^

##### Study Characteristics

We identified three good-quality RCTs^170,^ ^173,^ ^174^ and three fair-quality RCTs^108,^ ^169,^ ^176^ that examined the effect of environment interventions on falls (n=4,162) (Table 3; Appendix I Table 1). One trial was conducted in the United States,^174^ while the remainder were conducted in Hong Kong (k=1),^169^ Australia (k=2),^108,^ ^176^ and Great Britain (k=2).^170,^ ^173^ The size of the trials ranged from 165^173^ to 1,879^176^ randomly assigned participants. Followup time ranged from 6 to 18 months.

##### Population Characteristics

All trials recruited community-dwelling older adults at least age 65 or 70 years (Table 3; Appendix I Table 1). The mean age ranged from 75^174^ to 80^170^ years. The majority of participants were women (ranging from 52%^176^ to 78%^174^). Only one study reported race and ethnicity at baseline,^174^ noting that 56 percent of participants were Black. Two trials reported level of education; for one study,^174^ the mean level of education was 13.7 years, while another study reported that 36 percent of participants had an education level of 6 years or less.^169^ Baseline measures of health or functional status reported in the trials varied. The number of mean medications per day ranged from 3.4^108^ to 7.5.^174^ No trials reported frailty or comorbidities. Three trials required that all participants had fallen at least once in the past 12 months^170,^ ^173,^ ^174^ and one trial required presentation to an ED primarily due to a fall (Figure 28; Appendix I Table 2).

##### Intervention Details

A nurse,^176^ home-maintenance staff member,^108^ or physical or occupational therapist^169,^ ^170,^ ^173,^ ^174^ conducted an assessment of the participant’s home to identify environment hazards that could contribute to a fall and recommended modifications (Appendix I Table 3). When possible, modifications within the home were made during the assessment.^170,^ ^173,^ ^176^ In two trials, modifications were made through a city program (which paid up to $100)^108^ or a government-funded program for participants living in public housing.^169^ In the latter trial, participants randomized to the intervention group and who resided in government-funded housing had their home modifications paid for; however, those residing in private housing were required to pay for the modifications themselves.^169^ For hazards not modified during the assessor’s visit or for participants living in private housing, the participant was responsible for making changes or hiring someone to complete the work.^169,^ ^173,^ ^174^

Control groups. Participants in the control group in four trials were not given any intervention but could continue to receive usual care.^170,^ ^173,^ ^174,^ ^176^ One trial offered a delayed intervention^108^ and one trial received an attention control.^169^

Intervention adherence. Participants’ adherence to the intervention was variably reported. In one study, 76 percent received help to make the home modifications.^108^ Approximately 50 percent^170^ to 91 percent^174^ of participants partially or fully adhered to the recommendations. One study reported that several hazards (e.g., unsafe steps, rugs, or mats; rooms with trailing cords; rooms with an unsafe favorite chair) were significantly reduced.^176^

##### Study Quality

Three studies were rated as good quality, with low risk of bias for all assessed domains (Appendix A Figure 3).^170,^ ^173,^ ^174^ Three studies were rated as fair quality, with higher risk of bias in one or more domain.^108,^ ^169,^ ^176^ All three of these trials had moderate risk of bias due to randomization procedures.^108,^ ^169,^ ^176^ Five trials measured falls data by participants’ diaries or calendars,^108,^ ^170,^ ^173,^ ^174,^ ^176^ which were collected monthly. For one trial,^169^ participants self-reported falls by telephone every 2 weeks. All trials reported adequate retention of participants during followup with minor differences between the intervention and control groups in attrition.

#### Detailed Results

##### Falls

Six environment trials (n=3,956) demonstrated no difference in the rate of falls in the environment group compared to the control group at the longest followup (12 to 18 months) (IRR, 0.83 [95% CI, 0.59 to 1.18]; I^2^=82.2%) (Figure 29; Appendix I Table 4).

##### People With a Fall and People With Recurrent Falls

Five trials (n=2,242)^108,^ ^169,^ ^170,^ ^173,^ ^174^ showed no statistically significant difference in people with a fall at 12 to 18 months (RR, 0.94 [95% CI, 0.83 to 1.07]; I^2^=20.3%) (Figure 30; Appendix I Table 4). Four trials (n=2,077)^108,^ ^169,^ ^170,^ ^174^ reported people experiencing two or more falls and found similar nonstatistically significant results (RR range, 0.36 [95% CI, 0.07 to 1.75] to 1.04 [95% CI, 0.89 to 1.22]) (Figure 31; Appendix I Table 5).

##### Falls Resulting in Injury or Medical Care and Fall-Related Fractures

Two trials captured falls resulting in injury or medical care (n=1,580).^108,^ ^170^ There were no statistically significant differences in the environment group versus the control group at 12 to 18 months (IRR, 1.06 [95% CI, 0.93 to 1.21] and 0.97 [95% CI, 0.75 to 1.26]) (Figure 32; Appendix I Table 6). One trial additionally reported fractures,^170^ but events were rare and there was no statistically significant difference at 12 months for hip fractures (IRR, 1.69 [95% CI, 0.45 to 6.30]) or fall-related fractures (IRR, 0.83 [95% CI, 0.46 to 1.47]) (Appendix I Table 6).

##### People With a Fall Resulting in Injury or Medical Care and Fall-Related Fracture

One trial (n=1,331)^170^ reported people with a fall-related fracture. There was no significant difference between the intervention and control groups at the 12-month followup (RR, 0.88 [95% CI, 0.50 to 1.56]) (Appendix I Table 7).

##### Mortality

One trial (n=1,201)^170^ reported mortality, but there was no significant difference between the environment group and control group at the 12-month followup (RR, 1.87 [95% CI, 0.87 to 4.01]) (Figure 33; Appendix I Table 8).

##### Other Outcomes

One environment trial (n=1,580) reported no statistically significant difference between the intervention group and the control group in fall-related overnight hospitalizations at 12 months (IRR, 0.67 [95% CI, 0.38 to 1.21]) (Appendix I Table 6).^170^ One trial (n=198)^169^ reported no statistically significant difference in people with a fall-related hospitalization (RR, 0.72 [95% CI, 0.21 to 2.48]) and people with a fall-related ED visit at 12 months (RR, 0.70 [95% CI, 0.37 to 1.34]) (Appendix I Table 7). Qualitative analysis showed no effect on QOL outcomes in three trials^170,^ ^173,^ ^174^ (using the EuroQol and SF-12) (Appendix I Table 9). One trial (n=198)^169^ reported no significant difference from baseline to 12 months between the intervention and control groups in IADLs (Appendix I Table 10). No environment trials reported people transitioning to institutional care.

##### Harms

One trial^170^ reported no serious adverse events were attributed to the intervention (n=430 in intervention group) and a second trial^174^ noted that no adverse events were reported during the trial (n=275).

### Medication Review/Modification Interventions

#### Summary of Results

Four RCTs were included (n=1,052) that examined the effectiveness of a medication review with or without modification in older adults, three of which were limited to older adults at increased risk of falls. Meta-analysis was not possible due to few trials. At 6- to 12-month followup, these trials reported no difference between the intervention and control groups in people with a fall (k=3; n=846; RR range, 1.02 [95% CI, 0.79 to 1.31] to 1.16 [95% CI, 0.55 to 2.41]). Evidence was limited for the remaining outcomes due to only one or two trials reporting each outcome: falls (IRR, 1.01 [95% CI, 0.81 to 1.26]), falls resulting in injury or medical care (IRR, 0.87 [95% CI, 0.62 to 1.24]), people with a fall resulting in injury or medical care (RR range, 0.67 [95% CI, 0.36 to 1.26] to 1.69 [95% CI, 1.00 to 2.85]), mortality (RR, 0.40 [95% CI, 0.10 to 1.55] and 1.50 [95% CI, 0.26 to 8.77]), and QOL. There were no trials that reported on harms of the intervention.

#### Characteristics of Included Studies

We included four trials (in eight articles) of medication review with or without modification interventions (n=1,052).^177–184^ Two trials were included in the previous review^177,^ ^181^ and two were newly identified.^178,^ ^184^

##### Study Characteristics

We identified two fair-quality^177,^ ^181^ and two good-quality^178,^ ^184^ RCTs with a primary or secondary aim of examining the effectiveness of medication review interventions (n=1,052) (Table 3; Appendix J Table 1). Three were conducted in the United States^177,^ ^181,^ ^184^ and one in the Netherlands.^178^ Trial sizes (participants randomized to medication review and control arms for our analysis) varied, ranging from 80^181^ to 612^178^ participants.

##### Population Characteristics

Three RCTs recruited participants age 65 years or older,^177,^ ^178,^ ^181^ while one had a slightly older requirement of 70 years or older (Table 3; Appendix J Tables 1 and 2).^184^ Mean age ranged from 75 to 83 years, and the majority of participants across trials were female (ranged from 62% to 79%). Race and ethnicity were only reported in two trials, where participants were predominantly White (ranging from 89% to 99%).^177,^ ^181^ Measures of socioeconomic status were variably reported. Two trials excluded people with moderate or severe dementia.^177,^ ^184^

Recruitment setting varied across trials. From the U.S. trials, one trial recruited participants from a community pharmacy chain’s central electronic database,^177^ one trial recruited participants from a fall-prevention workshop,^181^ and one trial recruited from an ED.^178^ All of these trials recruited people at high risk for falls based on fall history or combination of fall history and other criteria.^177,^ ^178,^ ^181^ The other study recruited from a family physician’s office and had no fall-risk criteria for inclusion eligibility.^184^

All participants were community-dwelling older adults, but two trials excluded participants with moderate/severe or significant dementia.^177,^ ^184^ Baseline cognitive impairment was reported in two trials, both reporting no significant cognitive impairment (mean MMSE score, 27.0^178^ and mean Clinical Dementia Rating [CDR] score, 2.4^184^) among participants. Comorbidities were variably reported across the trials. One study reported the mean number of high-risk conditions as 1.62,^177^ another reported the mean Charlson Comorbidity Index score as 1.9,^178^ and one study reported the mean cumulative illness rating scale summary score as 16.7.^184^ The remaining study reported that approximately 88 percent of participants self-reported their overall health to be “good, very good, or excellent.”

Measures of baseline medication usage at recruitment were reported in all trials. The mean number of drugs currently taken ranged from 6.4^178^ to 9.8.^184^ In one trial, the proportion of participants taking at least one fall-risk–increasing drug (FRID) was 35 percent.^181^ Another trial reported the proportion of participants using three or more FRIDs as 71 percent.^178^ One trial reported a mean of 14 high-risk medication prescriptions filled in the year prior to the study.^177^

Three of the four trials recruited participants at increased risk for falling (Figure 28; Appendix J Table 2). Criteria for increased risk always included a fall history component. Additionally, one trial’s criteria also recruited participants who had a fear of falling,^181^ another also required participants to present to the ED after a fall,^178^ and the final also recruited participants who were taking four or more long-term prescription medications (of which one or more was a central nervous system medication [e.g., benzodiazepines, antidepressants, anticonvulsants, sedative-hypnotics, narcotic analgesics, antipsychotics, skeletal muscle relaxants]).^177^

##### Intervention Details

All trials included a medication review or modification intervention that included an in-person assessment and consultation (Appendix J Table 3). Two of the trials were conducted in the pharmacy, with a face-to-face medication consultation.^177,^ ^181^ The pharmacist either contacted the prescriber to approve the medication changes^177^ or developed an action plan with prescriber communication only when deemed necessary.^181^ The other two trials were both conducted in a clinical setting by a geriatrician. One trial’s intervention consisted of a systematic fall-related medication assessment combined with drug modification or withdrawal if it could be done safely.^178^ Another trial provided a comprehensive geriatric assessment and medication review, followed by the assessing geriatrician consulting the participants’ primary provider briefly to summarize findings and, if needed, suggest changes to the drug regimen.^184^

Intervention adherence. Three of the trials reported adherence to the intervention. One trial reported that of the 1,940 prescriptions for high-risk medications filled in the following year, 50 percent of these refills were filled by the patients in the intervention group.^177^ Another trial reported that of the six medication-related problems identified, each resulted in recommendations.^181^ Of these, approximately 50 percent of the recommendations were communicated by the pharmacist to the patient in person, 31 percent were communicated by the patient to the prescribing physician, and 19 percent were faxed by the pharmacist directly to the prescribing physician.^181^ The third trial found that a medication change was deemed not possible or unnecessary for 40 percent of all FRIDs identified.^178^ Additionally, in the same trial, 35 percent of all attempted FRID withdrawals were unsuccessful.^178^

Control Group. The control group for all included trials received usual care.^177,^ ^178,^ ^181,^ ^184^

##### Study Quality

Of the four trials, two were rated good quality, with low risk of bias in all domains (Appendix A Figure 3).^178,^ ^184^ The two remaining trials, which were previously included in the prior review, had moderate risk of bias in at least one domain, both with moderate risk due to missing data^177,^ ^181^ and one with additional risk due to randomization procedures.^177^ All trials recorded falls by using calendars that were turned in monthly and by participating in telephone interviews every 1 to 3 months.^177,^ ^178,^ ^181,^ ^184^

#### Detailed Results

##### Falls

One trial reported no difference in the rate of falls between the medication management group and the control group (IRR, 1.01 [95% CI, 0.81 to 1.26]) (Figure 29; Appendix J Table 4).^177^

##### People With a Fall and People With Recurrent Falls

Four trials^177,^ ^178,^ ^181,^ ^184^ reported the number of people with one or more falls at 6 to 12 months of followup. Results were inconclusive and none of the individual study comparisons were statistically significant. Individual RRs ranged from 1.02 (95% CI, 0.79 to 1.31) to 1.16 (95% CI, 0.55 to 2.41) in three trials and one trial reported an odds ratio of 0.75 (95% CI, 0.35 to 1.60) (Figure 30; Appendix J Table 5). Two trials^178,^ ^181^ also reported no difference in the number of people who fell more than twice at 6 and 12 months (RR, 1.16 [95% CI, 0.79 to 1.71] and 2.10 [95% CI, 0.56 to 7.83]) (Figure 31; Appendix J Table 5).

##### Falls Resulting in Injury or Medical Care and Fall-Related Fractures

One trial reported a nonstatistically significant reduction in injurious falls between the intervention and control groups at 12 months (IRR, 0.87 [95% CI, 0.62 to 1.24]) (Figure 32; Appendix J Table 6).^177^ No trials reported fall-related fractures.

##### People With a Fall Resulting in Injury or Medical Care and Fall-Related Fracture

One trial reported no statistically significant difference in people with an injurious fall at 12 months (RR, 0.69 [95% CI, 0.46 to 1.04]) (Appendix J Table 7).^178^

##### Mortality

Two trials^177,^ ^184^ (n=344) reported no statistically significant difference in mortality between the intervention and control groups (RR, 0.40 [95% CI, 0.10 to 1.55] and 1.50 [95% CI, 0.26 to 8.77]) (Figure 33; Appendix J Table 8).

##### Other Outcomes

One trial reported people with a hospitalization (RR, 1.69 [95% CI, 1.00 to 2.85]) and one trial reported people with an ED visit (RR, 0.67 [95% CI, 0.36 to 1.26]) (Appendix J Table 7). Two trials^178,^ ^184^ reported no statistically significant difference in QOL between the intervention and control groups at 6 to 12 months (Appendix J Table 9).

##### Harms

No study reported harms.

### Psychological Interventions

#### Summary of Results

Three RCTs of cognitive behavioral interventions, which targeted community-dwelling older adults at high risk of falling, were included (n=979). Due to few trials, the evidence base is considered inconclusive for the effect of psychological interventions on falls and fall-related outcomes. Two trials showed nonstatistically significant reductions in falls at 12- and 14-month followup (IRR, 0.86 [95% CI, 0.65 to 1.13] and 0.86 [95% CI, 0.65 to 1.14]). Only one of the three trials showed a statistically significant reduction in people with a fall (RR, 0.72 [95% CI, 0.58 to 0.90]; RR, 0.96 [95% CI, 0.80 to 1.15]; odds ratio, 1.40 [95% CI, 0.45 to 4.37]). Only one trial reported a statistically significant reduction in people with two or more falls (RR, 0.59 [95% CI, 0.43 to 0.81] and 0.89 [95% CI, 0.67 to 1.19]). Trial results for falls resulting in injury were not statistically significant in either trial (RR, 0.78 [95% CI, 0.45 to 1.35] and 1.42 [95% CI, 0.96 to 2.10]). No study reported fall-related fractures or people with a fall resulting in injury. Trial results showed no difference in mortality between the intervention and control groups (RR, 0.98 [95% CI, 0.77 to 1.25] and 1.01 [95% CI, 0.36 to 2.81]). No differences were found in IADL outcomes between the intervention and control groups. One study reported no adverse events.

#### Characteristics of Included Studies

We identified three RCTs (reported in six articles) that used cognitive behavioral interventions for reducing fear of falling (n=929).^185–190^ Two trials were included in the previous review^186,^ ^190^ and one trial was newly identified.^189^

##### Study Characteristics

The three fair-quality RCTs (n=979) aimed to reduce fear of falling and activity avoidance or to address concerns about falls in community-dwelling older adults (Table 3; Appendix K Table 1).^186,^ ^189,^ ^190^ Two trials were conducted in the Netherlands^186,^ ^190^ and one was conducted in Australia.^189^

##### Population Characteristics

All included trials targeted community-dwelling older adults with concerns or fear of falling, and two trials also recruited community-dwelling older adults who perceived their general health as fair or poor^186^ or who had poor confidence in their balance^189^ (Table 3; Appendix K Tables 1 and 2). Two trials recruited participants older than age 70 years,^189,^ ^190^ while one trial recruited older adults older than age 65 years.^186^ The mean age ranged from 74 to 78 years and the percent female ranged from 70 to 72 percent. In the previous 6 months prior to the trials starting, more than half of participants (61%) in one trial^186^ and one-third of participants (35%) in another trial^190^ had fallen at least once, and 44 percent of participants in the remaining trial had experienced at least one fall in the previous year^189^ (Figure 28; Appendix K Table 2). Race and ethnicity were not reported for any of the included trials and measures of socioeconomic status were minimal.^186,^ ^190^

##### Intervention Details

The three included trials all used a cognitive behavioral intervention designed to reduce fear of falling. Two of the trials were delivered in person and facilitated by a nursing professional,^186,^ ^190^ while the remaining trial was delivered virtually with self-directed online modules^189^ (Appendix K Table 3). One trial delivered the intervention in group format and was comprised of eight weekly 2-hour sessions with the purpose of addressing misconceptions on fall risks, setting realistic goals for safe activity, reducing home hazards, and promoting physical exercise to increase strength and balance.^190^ Six of the eight sessions included 15 minutes of low-intensity physical exercise.^190^ The other in-person trial used an individual approach, with seven total sessions (three 60- to 75-minute home visits, four 35-minute telephone contacts) over 16 weeks, which aimed to address concerns about falls, thoughts about falling, physical exercise, asserting oneself, overcoming personal barriers, safe behavior, and managing concerns about falls.^186^ The remaining trial delivered an intervention consisting of three modules from the myCompass program, which is a self-help online cognitive behavioral therapy program.^189^ Participants were given access to three skill-building modules that were relevant to fear of falling (Managing Fear and Anxiety, Taking Charge of Worry, and Solving Problems) for 6 weeks and were completed using a mobile device or a home computer.^189^

Intervention adherence. All trials reported adherence to the psychological intervention. One trial reported 58 percent of participants attended five of the eight sessions.^190^ In another trial, participant use of the action plans decreased towards the end of the trial, starting at 70 percent in initial sessions and dropping to 51 percent in the latter sessions.^186^ In the online program intervention, the study reported that all intervention participants completed two out of the three required modules.^189^

Control groups. The control group for the two trials delivering an in-person intervention received usual care.^186,^ ^190^ The remaining trial delivered a minimal intervention to the control group, which consisted of all participants receiving two general health education booklets.^189^

##### Study Quality

All trials were rated fair quality with moderate or high risk of bias in at least one domain (Appendix A Figure 3).^186,^ ^189,^ ^190^ Randomization was adequate, with no concerns that the groups differed at baseline. Data on falls were measured by participants’ diaries, which were collected monthly^186,^ ^189^ or every 3 months.^190^ However, there was differential attrition between the intervention and control groups for all trials, which resulted in a higher risk of bias due to missing data.

#### Detailed Results

##### Falls

Both trials^186,^ ^190^ reported the same nonstatistically significant lower rates of falls compared to the control group at 12 to 14 months of followup (IRR, 0.86 [95% CI, 0.65 to 1.13] and 0.86 [95% CI, 0.65 to 1.14]) (Figure 29; Appendix K Table 4).

##### People With a Fall and People With Recurrent Falls

Only one of the three trials found a statistically significant reduction in people with one or more falls (RR, 0.96 [95% CI, 0.80 to 1.15];^186^ RR, 0.72 [95% CI, 0.58 to 0.90];^190^ odds ratio, 1.40 [95% CI, 0.45 to 4.37]^189^) (Figure 30; Appendix K Table 5). This same trial also reported a statistically significant reduction in people with two or more falls (RR, 0.59 [95% CI, 0.43 to 0.81]^190^ and 0.89 [95% CI, 0.67 to 1.19]^186^) (Figure 31; Appendix K Table 5).

##### Falls Resulting in Injury or Medical Care and Fall-Related Fractures

The trial results for falls resulting in injury or medical care were mixed. At 12 to 14 months, one trial^190^ showed a nonstatistically significant reduction in fall-related injuries resulting in medical care in the intervention group compared to the control group (IRR, 0.78 [95% CI, 0.45 to 1.35]), but the other trial^186^ showed a nonsignificant increase in fall-related injuries (IRR, 1.42 [95% CI, 0.96 to 2.10]) (Figure 32; Appendix K Table 6). Neither trial reported fall-related fractures.

##### People With a Fall Resulting in Injury or Medical Care and Fall-Related Fracture

Neither trial reported these outcomes.

##### Mortality

There was no difference in the number of participants who died between the intervention and control groups in either trial at longest followup (RR, 0.98 [95% CI, 0.77 to 1.25] at 7 years; RR, 1.01 [95% CI, 0.36 to 2.81] at 12 months) (Figure 33; Appendix K Table 7).

##### Other Outcomes

Both trials found no differences in IADLs between the intervention and control group over 12 to 14 months of followup (Appendix K Table 8).

##### Harms

One trial reported no adverse events or side effects in the trial,^190^ while the other did not report these outcomes.^186^

### Education Interventions

#### Summary of Results

One trial that examined the effectiveness of a group education intervention in older adults at high risk of falls was included. This trial showed a statistically significant reduction in falls in the intervention group at 14 months (IRR, 0.68 [95% CI, 0.57 to 0.83]). No statistically significant difference was found between groups for people with a fall, people with recurrent falls, and QOL. No other relevant outcomes were reported.

#### Characteristics of Included Studies

We identified one trial (in one article) with a primary or secondary aim of examining the effectiveness of an educational intervention on falls or fall-related outcomes (n=310).^191^ This trial was previously included; no new trials were identified.

##### Study Characteristics

We identified one fair-quality RCT (n=310) conducted in Australia that examined the effectiveness of a group education intervention to prevent falls in adults age 70 years or older at increased risk for falling (Table 3; Appendix L Table 1).^191^

##### Population Characteristics

This trial recruited community-dwelling adults age 70 years or older (Table 3; Appendix L Tables 1 and 2).^191^ The mean age was 78, and approximately three-quarters of participants were female (74%). All participants were at increased risk for falling, based on personal concerns related to falling or fall history. Those with cognitive impairment were excluded. Race and ethnicity and measures of socioeconomic status were not reported. Twenty percent of participants were currently using psychotropic drugs at the time of recruitment, and per inclusion criteria, all participants had a fall in the previous 12 months or reported concerns about falling (Figure 28).^191^

##### Intervention Details

The trial implemented the Stepping On program, which aimed to improve fall self-efficacy, encourage behavior change, and reduce falls (Appendix L Table 3).^191^ This program offered a combination of group classes in the community and a followup home visit. Facilitated by an occupational therapist, approximately 15.5 hours of education sessions were delivered. Content of the Stepping On program curriculum included covering such topics as balance and strength exercises, how to cope with vision loss, encouraging medication management, and recommendations for environmental and behavioral home safety, and community safety. Additionally, each session provided an opportunity for action planning and homework for the next week. The individual home visit aimed to support follow through of fall-prevention strategies and activities.^191^

Intervention adherence. At the end of the trial, 59 percent of intervention participants were still doing their exercise routinely, 72 percent of those who needed a vision assessment initiated one, and 70 percent of program participants adhered to at least half of the environment recommendations.

Control groups. This trial included an attention control for the comparison group.^191^ Participants randomized to the control group received up to two social visits from an occupational therapy student. Visits were conducted at the same time as the Stepping On intervention and students leading the social visits were instructed not to discuss falls or falls prevention with participants.^191^

##### Study Quality

The trial was rated fair quality, with low risk of bias in all but one domain (Appendix A Figure 3).^191^ The trial was found to have moderate risk of bias due to randomization procedures and confounding, as authors reported statistically significant baseline differences between the intervention and control groups. Despite being controlled for some of these differences in the analyses, this may overestimate any benefit from the intervention. Study participants used diaries to record falls prospectively.

#### Detailed Results

##### Falls

The included trial showed statistically significant reductions in falls in the intervention group compared to the control group (IRR, 0.68 [95% CI, 0.57 to 0.83]) (Figure 29; Appendix L Table 4).^191^

##### People With a Fall and People With Recurrent Falls

The trial showed no difference at 14 months of followup (RR, 0.90 [95% CI, 0.73 to 1.10]).^191^ Additionally, the trial reported a nonstatistically significant reduction in the number of people who had had two or more falls (RR, 0.74 [95% CI, 0.52 to 1.04]) (Figures 30 and 31; Appendix L Table 5).^191^

##### Falls Resulting in Injury or Medical Care and Fall-Related Fractures

The trial did not report these outcomes.

##### People With a Fall Resulting in Injury or Medical Care and Fall-Related Fractures

The trial did not report these outcomes.

##### Mortality

The trial did not report mortality.

##### Other Outcomes

The included trial (n=258) reported on QOL at 14 months using the SF-36 physical and mental health components.^191^ No statistically significant mean differences between the intervention and control group were found (Appendix L Table 6).^191^

##### Harms

The trial did not report harms.