# Chapter 2 Methods

## Scope and Purpose

This current review is an update of the 2018 review^36,^ ^37^ that supported the 2018 USPSTF recommendation^1^ to prevent falls among older adults. The USPSTF will use this report to update its recommendation. While no substantive changes were made to the key questions (KQs) and analytic framework, compared to the 2018 review, this update excludes interventions of vitamin D supplementation and allows for the inclusion of participants with mild dementia, osteoporosis, osteoarthritis, and sarcopenia.

## Key Questions and Analytic Framework

With input from the USPSTF, we developed an Analytic Framework (Figure 2) and two KQs to guide the literature search, data abstraction, and data synthesis.

Figure 2 Analytic Framework

Figure 2 is the analytic framework that depicts the two Key Questions to be addressed in the systematic review. The figure illustrates how fall prevention in community-dwelling older adults age 65 years or older unselected or at increased risk for falls (Key Question 1a) may result in a decrease in falls, fall-related morbidity, and/or all-cause mortality (Key Question 1). There is also a question related to adverse effects of screening (Key Question 2).

### Key Questions

1. Do interventions to prevent falls in unselected- or increased-risk community-dwelling older adults reduce falls, fall-related morbidity, or mortality?
  a. How is “increased risk” defined in the included trials?
2. Do interventions to prevent falls in unselected- or increased-risk community dwelling older adults result in any adverse effects?

## Data Sources and Searches

In addition to re-evaluating all studies included in the 2018 review,^36,^ ^37^ we searched the following databases for relevant English-language literature published between January 1, 2016, and May 8, 2023: MEDLINE, Cumulative Index for Nursing and Allied Health Literature, and Cochrane Central Register of Controlled Clinical Trials. A research librarian developed and executed the search, which was peer reviewed by a second research librarian (Appendix A). We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We also searched ClinicalTrials.gov for ongoing trials and have conducted ongoing surveillance for relevant literature for all bodies of evidence through March 22, 2024. We imported the literature from these sources directly into EndNote® X9 (Thomson Reuters, New York, NY).

## Study Selection

We developed specific criteria to guide our study selection (Appendix A Table 1). Two independent reviewers independently screened all records in the updated searches based on the titles and abstracts, using the inclusion and exclusion criteria as a guide. Subsequently, at least two reviewers assessed the full text of potentially relevant studies, including all the previously included studies. Disagreements were resolved through discussion and consensus. We kept detailed records of all included and excluded studies, including the reason for exclusion.

### Population

We included trials of community-dwelling older adults age 65 years or older. Participants could be unselected for their risk of falling or selected due to their increased risk of falling. We excluded trials recruiting populations living in specialized settings, such as people living in long-term care facilities. We further excluded older adults with moderate to severe dementia (or major neurocognitive disorder) but did include trials recruiting those with mild dementia or mild cognitive impairment. If we were unable to determine the severity of cognitive impairment among participants, the study was excluded. We also included trials that recruited participants with osteopenia/osteoporosis, osteoarthritis, or sarcopenia.

### Interventions and Comparators

We included interventions that were feasible to conduct in or refer from primary care. Specifically, we included the following categories of interventions, delivered alone or in combination:

- Multifactorial assessment and intervention (hereafter referred to as multifactorial intervention)
- Exercise (supervised or unsupervised, individual or group)
- Environmental assessment/modification
- Medication review/modification
- Psychological (individual or group)
- Education

We excluded interventions in social marketing and policy (out of scope for the USPSTF); surgery (e.g., cataract extraction, pacemaker placement, podiatry surgery), fluid or nutrition therapy, management of urinary incontinence, and assistive technology (these interventions are performed as treatment of medical conditions); and vitamin D or other supplements (vitamin D has been included in another USPSTF evidence review^38^). We also excluded interventions that are considered disease management, such as osteoporosis pharmacotherapy, joint replacement, and cognitive function interventions. Trials of multifactorial interventions that incorporated any of the excluded intervention categories as one part of their assessment, referral, or treatment components were included; trials of multiple interventions (where all participants received all interventions) where an excluded intervention was a major category of intervention were excluded.

We captured the components of exercise interventions according to taxonomy developed by ProFaNE.^39^ These categories included: gait, balance, and functional training; strength/resistance; flexibility; 3D (e.g., tai chi or dance); general physical activity; and endurance.

We required a minimal control or usual care comparison group. Any study with an active comparison group or a relatively intense comparison group was excluded.

### Outcomes

Trials were required to report at least one fall or a fall-related injury outcome. We abstracted the following outcomes: falls, people with a fall, mortality, fall-related injuries (mild injuries, serious injuries, injuries resulting in medical care), people with fall-related injuries (people with mild injuries, serious injuries, or injuries resulting in medical care), hospitalizations or ED visits (fall-related hospitalizations/ED visits were preferentially abstracted when available, otherwise all hospitalizations/ED visits were abstracted), people with hospitalizations or ED visits, fractures, people with fractures, institutionalizations, people institutionalized, instrumental activities of daily living (IADLs), quality of life, and any harms outcomes as reported in the trials. We did not include basic ADLs, as community-dwelling older adults are typically still functional in their basic ADLs and we would not expect to see an improvement in this outcome over a relatively short intervention duration.

We allowed any instrument measuring IADLs. For quality of life (QOL), we required overall or component scores (e.g., SF-36 mental component score). Falls and fall injuries could be measured using a falls diary, recall under 6 months, or via the use of administrative records. We required a minimum followup of 6 months. All outcomes had to capture the outcome starting at baseline; we excluded trials that reported only a segment of followup (e.g., only 12 to 24 months post-baseline).

### Study Design

We included randomized, controlled trials (RCTs) and cluster RCTs. All intervention harms were restricted to trials included for KQ1. Trials were required to have a primary or secondary aim of preventing falls or an aim related to fall prevention (e.g., fear of falling) and falls measured as a primary or secondary outcome.

## Quality Assessment

We quality rated all studies for potential risks of bias that may impact the reported effects and assigned each study a quality rating of “good,” “fair,” or “poor.” We applied signaling questions from the Cochrane Risk of Bias (RoB 2)^40^ tool along with the USPSTF-design specific criteria. Appendix A Table 2 lists the criteria applied. We quality rated the trials with a focus on the falls outcomes (Appendix A Figures 1–3), and because the preferred measurement method is to use self-reported falls diaries, blinding of the outcome assessor was not possible. Therefore, we did not use that signaling question. For new evidence, two independent reviewers rated each study. For the previously included studies, one investigator reviewed the previous risk of bias assessments and assigned domain ratings to those studies. If needed, domains were reassessed.

Discordant quality ratings were reviewed and discussed; a third reviewer adjudicated as needed.

Good-quality studies were those that met nearly all specified quality criteria. We rated a study as good quality if comparable groups were assembled initially and maintained throughout the study, reliable and valid measurement instruments were used and applied equally to the groups, procedures for maintaining fidelity to the intervention were in place, followup was adequate (i.e., ≥80% retention overall) and not differential between groups, data were complete, and there was no evidence of selective reporting. Fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study.

Studies rated as poor-quality had several important risks of potential bias or one critical flaw and were excluded from this review. Potential risk of bias for intervention trials resulting in poor-quality ratings included very high risk of bias due to confounding and imbalances in baseline characteristics between groups, high or differential rates of attrition between groups, or no information on the number of participants with complete data or reasons for missing data, falls outcome ascertainment validity concerns (i.e., recall >6 months), and evidence of possible selective reporting.

## Data Abstraction

One reviewer extracted key elements for each included study into standardized abstraction forms in DistillerSR. A second reviewer checked the data for accuracy.

We abstracted general characteristics of the study (e.g., study design, country), clinical and demographic characteristics of the sample and setting (e.g., recruitment strategy and setting, age, race and ethnicity, baseline clinical characteristics), intervention details (e.g., type, provider, frequency, duration), methods to collect information on falls, and relevant outcomes. A study in which participants prospectively collected information (e.g., onto calendars, postcards, or diaries) about their falls and sent the information to the research team was referred to as “diary” collection. When multiple intervention and/or control groups were available, we abstracted the most intense and comprehensive intervention group and the control group most similar to no intervention or usual care.

## Data Synthesis and Analysis

We synthesized data separately for each KQ. Many outcomes did not allow for quantitative pooling due to the limited number of contributing studies (k<5), so those data are summarized narratively. For outcomes with enough contributing studies, we ran random-effects meta-analyses with a Knapp-Hartung adjustment^41^ to calculate the pooled relative risks. When available, we favored the author-reported relative risks or incidence rate ratios over those we calculated for the analysis and data tables. When authors did not report relative risks or incidence rate ratios, we calculated a crude effect estimate and this unadjusted effect is presented in figures and tables. Within each study, we selected the longest followup available for pooled analyses and figures. Data from other followup times are presented in tables. As noted above, only one intervention and one control arm for each intervention category were abstracted and included in the analysis.

We grouped our outcomes as follows: number of falls, number of falls resulting in injury or medical care (also referred to as injurious falls), number of fall-related fractures, number of hospitalizations or ED visits, people with a fall, people with a fall resulting in injury or medical care (also referred to as people with an injurious fall), people with a fracture, people with a hospitalization or ED visit, people transitioning to institutionalized care, people hospitalized, mortality, QOL, and IADLs.

All fall and fall-related injury outcomes were reported either as an incident event (where a person could contribute more than one event to the analysis [e.g., falls, fractures]) or the number of persons experiencing the event (where a person could contribute only once to an analysis, regardless of the number of times the event occurred [e.g., people experiencing a fall, people experiencing an injurious fall]). For injurious fall outcomes, we included minor or severe injuries resulting from a fall, falls resulting in medical care, or any fall-related outcome the author categorized as injurious. The most inclusive outcome was used in meta-analysis if multiple outcomes in that injury category were reported (e.g., fall-related injuries instead of fall-related hospital admissions). For studies that did not report a composite injury outcome, we used the most prevalent outcome (e.g., falls leading to an ED visit was selected over falls leading to hospital admission). The number of injurious falls analyzed in the forest plots included both the number of fall-related injuries and the number of falls resulting in injury as reported in the trials. For fracture outcomes, we first selected fall-related fractures, but if that outcome was not available, we included data on hip fractures and overall fractures, even if the study may not have reported if the fracture was associated with a fall.

In cases where a cluster RCT was used but the authors did not account for the nested nature of the data, we adjusted for the clustering effect by applying a design effect, which was based on an estimated average cluster size (i.e., the total number of randomized participants divided by the total number of clusters) and multiplied by an estimated intraclass correlation. We estimated the intraclass correlation to be 0.05.

We examined statistical heterogeneity among the pooled studies by applying standard χ^2^ tests and estimated the proportion of total variability in point estimates by using the I^2^ statistic.^42^ We applied the Cochrane Collaboration’s rules of thumb for interpreting heterogeneity^43^: less than 40 percent likely represents unimportant heterogeneity; 30 to 65 percent, moderate heterogeneity; 50 to 90 percent, substantial heterogeneity; and more than 75 percent, considerable heterogeneity. In addition, we generated funnel plots to evaluate small-study effects (a possible indication of publication bias) and ran the Egger test to assess the statistical significance of imbalance in study size and findings that suggest a pattern.^44^

We investigated whether the heterogeneity among the main results (the outcome of falls and the outcome of people with one or more fall) was associated with any prespecified population or intervention characteristics of the studies. First, we used visual displays and tables grouped or sorted by these potentially important characteristics. For visual displays that suggested a difference between groups or a pattern in sorted results, we conducted meta regression.

Specifically, we examined the publication year, study quality, recruitment setting, duration of followup, mean age, percentage female, recruitment for increased fall risk, and fall rate or the percent falling in the control group as they related to the effect estimates. For exercise interventions, we also examined the presence of a behavior change component, presence of cognitive task exercises, individual exercise components (e.g., balance, flexibility, strength), and format (group, individual, or both). We used Stata version 16.1 (Stata Corp LP, College Station, TX) for all quantitative analyses. All significance testing was two-sided. Results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ to reflect our confidence in the findings. We adapted the Evidence-based Practice Center (EPC) approach,^45^ which is based on a system developed by the Grading of Recommendations Assessment, Development, and Evaluation Working Group.^46^ Our method explicitly addresses four of the five EPC-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias, and study limitations. We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., whether the evidence links the interventions directly to a health outcome).

Consistency was rated as consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as precise, imprecise, or not applicable (e.g., no evidence). The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., suspected reporting bias, lack of replication of interventions, nonreporting of outcomes).

We graded the overall strength of evidence as high, moderate, low, or insufficient.^45^ These grades reflect our level of confidence in the estimate of effect (direction and magnitude) for benefit or harm—equating to our judgement as to how much the evidence reflects a true effect and our assessment of the level of deficiencies in the body of evidence and our belief in the stability of the findings. The strength of evidence grade does not reflect the actual magnitude of the effect (e.g., a “small” effect, “low” sensitivity).

“High” indicates high confidence that the evidence reflects the true effect, and that further research is very unlikely to change our confidence in the estimate of effect. “Moderate” suggests moderate confidence that the evidence reflects the true effect, and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect, and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. We developed our overall strength of evidence grade based on consensus discussion involving at least two reviewers.

## Race and/or Ethnicity Terminology

For consistency, in this report we use the following default terminology:

1. Black and White (in capitals) as descriptors for populations rather than nouns
2. Black persons as opposed to African Americans
3. Hispanic/Latino persons as opposed to Hispanic, Latine, or Latinx persons

We realize there are no perfect or universally preferred terms for many of these categorizations and concepts; however, we have tried to stay away from terms that are inaccurate or perceived as marginalizing. In select instances, when using nonpreferred terms referenced by the source material, we note this using quotation marks (e.g., “diverse populations”).

## Contextual Questions

In addition to the systematically reviewed questions (KQs 1 and 2), we also addressed a contextual question (CQ) to aid with the broader interpretation of the evidence. CQs are important considerations that may not be readily answerable from the KQ evidence or RCT literature. One CQ was prespecified in our Research Plan:

1. What is the prognostic accuracy of falls risk assessment tools that are feasible for administration in primary care?

The CQ was not systematically reviewed. Evidence for the CQ was identified based on literature retrieved for the systematic search for KQs as well as targeted searches and scanning bibliographies of relevant articles. A best evidence approach was used to identify the most recent, applicable, and robust evidence. The CQ is addressed in the Introduction and in Table 1.

## Expert Review and Public Comment

The draft Research Plan was posted from April 21 to May 19, 2022. In response to public comment, fall prevention trials recruiting older adults with osteopenia/osteoporosis, osteoarthritis, and sarcopenia were included. The population designation “average-risk” was also replaced with “unselected-risk.” The intervention name “medication management” was also changed to “medication modification/review” to better reflect our intended inclusion criteria.

A draft version of this report was reviewed by three invited experts and four USPSTF federal partners. Experts were selected based on their expertise in fundamental methodologic and content aspects of the review and were selected to obtain diverse informed perspectives. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report. All expert comments were considered, and the report was updated to improve clarity, ensure accuracy, and address scientifically relevant concerns.

In addition, the draft evidence report was posted on the USPSTF website for public comment from December 5, 2023, through January 8, 2024. In response to comments received, we provided some additional information and clarification in the introduction and evaluated studies suggested for possible inclusion but found that none met our inclusion criteria.

## USPSTF and AHRQ Involvement

We worked with USPSTF members at key points throughout this review, particularly when determining the scope and methods and developing the Analytic Framework and KQs. The USPSTF members approved the final Analytic Framework, KQs, and inclusion and exclusion criteria after revisions reflecting the public comment period. AHRQ staff provided oversight for the project, coordinated systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.