# Chapter 1 Introduction

## Purpose

The Agency for Healthcare Research and Quality (AHRQ) has requested an updated evidence report on interventions to prevent falls in older adults. This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2018 recommendation.^1^

## Prevalence and Burden

People age 65 years or older constitute the fastest-growing segment of the U.S. population. The U.S. Census Bureau projects that the number of people age 65 years or older will be 95 million in 2060, almost double the estimated population of 49 million in 2016.^2^ The number of people age 85 years or older is expected to increase from 6.5 million in 2016 to 11.8 million in 2035, and nearly triple to 19 million by 2060.^2^

Falls—unexpected events in which a person comes to rest on the ground, floor, or lower level—are the leading cause of injury-related morbidity and mortality among older adults in the United States.^3^ In 2018, 27.5 percent of community-dwelling people age 65 years or older reported at least one fall in the past year (714 falls per 1,000 older adults) and 10.2 percent reported a fall-related injury (170 fall-related injuries per 1,000 older adults).^4^ The Centers for Disease Control and Prevention (CDC) estimates that, in 2018, there were 3 million emergency department (ED) visits and 950,000 hospitalizations or transfers to another facility due to falls. Further, between 1999 and 2020, 478,214 deaths from falls occurred among adults age 65 years or older, increasing from 10,097 in 1999 to 36,508 in 2020.^5^ The risk of falling or experiencing a fall-related injury increases with age. In 2018, 25.9 percent of older adults ages 65 to 74 years reported falling and 9.3 percent reported fall-related injuries. Among adults age 85 years or older, 33.8 percent reported falling and 13.9 percent reported fall-related injuries.^4^ Since 2001, the age-adjusted fall-related death rate has been steadily increasing for older adults, increasing by 41 percent in the most recent 10 years (55.3/100,000 in 2012 to 78.0/100,000 in 2021). Most fall-related deaths occur in those age 85 years or older—this group also has the fastest growing death rate (Figure 1).^6^

Figure 1 Unintentional Fall Death Rate From 2001 to 2020, by Age Group

Note: Data on unintentional fall deaths from the Centers for Disease Control and Prevention Web-based Injury Statistics Query and Reporting System. https://www.cdc.gov/injury/wisqars/index.html. Accessed 10.23.2023.^3^

Figure 1 shows the unintentional fall death rate from 2001 to 2020 by the following age groups: 65-69 years, 75-79 years, 80-84 years, and 85+ years. Older adults age 85 years or older have the highest unintentional fall death rate compared with other age groups, and rates continue to increase over time.

Disparities in falls exist by sex, race and ethnicity (terminology used for race and ethnicity in this report described in the Methods chapter), and geographic location. Women are more likely to experience nonfatal falls and fall-related injuries than men (29.1% of women versus 25.5% of men report a fall; 11.9% of women versus 7.9% men experience a fall-related injury).^4^ However, after adjustment for age, men have a higher rate of fall-related deaths than women (73.2 per 100,000 men versus 54 per 100,000 women).^7^ In 2018, American Indian/Alaska Native older adults reported more falls (32.2%) compared to White (28.3%), Black (22.5%), Hispanic/Latino (28.1%), Asian/Pacific Islander (15.6%), and multiracial or other race (29.6%) older adults. In addition, American Indian/Alaska Native older adults age 65 years or older had a higher percentage of fall-related injuries (15.2%) compared to White older adults age 65 years or older (10.2%).^4^ Some hypotheses to explain these racial differences have been postulated related to cultural differences, home support, and engagement in outdoor activity.^4^ In the same year, older adults living in rural areas reported a higher percentage of falls compared to those living in urban areas (29.5% versus 27.0%, respectively). However, when stratified by age group, this was only true for persons ages 65 to 74 years.^4^

Falls predict quality of life, disability, admission to long-term care facilities, and death. Between 20 and 30 percent of those who fall incur moderate to severe injuries, such as fractures, lacerations, and head trauma (including traumatic brain injury), that result in decreased mobility and potentially reduced independence.^8^ In a 2017 analysis^9^ conducted in the United Kingdom of 6,800 non-spinal fractures, the most common fall-related fractures among adults ages 60 to 90 years or older included the upper arm, forearm, hip, and ankle. Among the very elderly (i.e., 90 years or older), 50 percent of fall-related fractures occurred in the hip.^9^ For people who are admitted to a hospital after a fall, the length of stay is longer and referral to long-term care facilities is significantly higher among older adults age 65 years or older than for younger people. Moreover, older adults age 65 years or older with hip fractures are three to four times more likely to die within one year after surgery than the general population.^10,^ ^11^ Between 25 and 75 percent of older adults age 65 years or older who lived independently before their hip fracture do not recover their pre-injury functional status.^12,^ ^13^

Falls represent a significant economic burden on the U.S. healthcare system. A 2018 analysis^14^ estimated that the combined medical costs of fatal and nonfatal falls in 2015 was approximately $50 billion. Overall medical spending for fatal falls was estimated to be $754 million, and more than $49.5 billion for medically treated, nonfatal fall-related injuries.^14^ In 2017, an average of $9,389 was spent per fall for fall-related injuries among U.S. Medicare beneficiaries.^15^

## Etiology and Natural History

Falls are caused by complex interactions among multiple risk factors, including long-term or short-term predisposing factors. Interactions between these factors may be modified by age, disease, and environment. A single fall may have multiple causes or contributors, and repeated falls are typically due to multiple (intrisic and extrinsic) contributors.

## Risk Factors

Risk factors for falls can be classified as intrinsic (within an individual) or extrinsic (external to an individual). Intrinsic (i.e., patient-related) risk factors include age; cognitive and sensory deficits; gait, strength, and balance deficits; acute and chronic conditions; and behaviors. Extrinsic factors include environmental hazards or hazardous activities, medications, footwear, assistive devices, home or neighborhood features, alcohol and drugs, and physical support provided by caregivers. Certain risk factors may be modifiable through interventions: gait, strength, balance, and sensory deficits; behaviors; medications; footwear; assistive devices; home environment; alcohol or drug use; and physical support provided by caregivers.

A person’s functional capacity may decrease with aging because of physical and cognitive alterations that lead to impairments in balance, gait, and strength. A 2021 systematic review and meta-analysis^16^ of 22 studies concluded that older adults with markers of frailty in balance and mobility were associated with a 33 percent increased risk of recurrent falls (95% CI, 1.11 to 1.60; p = 0.007). In addition to balance and mobility, medication (relative risk (RR),1.53 [95% CI, 1.11 to 2.10), psychological (RR, 1.35 [95% CI, 1.03 to 1.78]), and sensory and neuromuscular (RR, 1.51 [95% CI, 1.18 to 1.92) risk factor domains were the greatest predictors of recurrent falls.^16^

As people age, they may also develop more than one risk factor. Appreciating the interaction and probable synergism among multiple risk factors is important in making a clinical assessment. The risk for injuries that results from falling increases dramatically as the number of risk factors increases.

## Fall Risk Screening Tools Feasible for Primary Care

Fall risk screening tools and fall risk assessment tools are important in identifying older adults at risk of falling and implementing appropriate interventions to prevent falls. Fall risk screening tools are standardized tools that are designed to quickly identify individuals at risk of falling and may be used to identify individuals who may benefit from a comprehensive fall risk assessment, which may include a one- to three-item fall-risk questionnaire (e.g., history of falls, feeling unsteady, and/or worry about falling or balance) to discriminate those at increased risk for falls from those at average risk. Older adults with positive screening questionnaires may or may not then complete a brief physical function assessment of strength, gait, and balance prior to referral to a single fall-prevention intervention or multiple interventions, as needed. Alternatively, both a questionnaire and an assessment of physical function could be administered to all older adults; results indicating a high risk of falls would trigger interventions aimed at reducing this risk. Again, these risk reduction interventions may include immediate advice and referrals or may involve an in-depth multifactorial risk assessment with subsequent individualized advice and referrals.

Several fall risk screening tools are available for use in primary care settings (Table 1). Risk tools that are feasible for primary care need to account for time, space, and personnel limitations. Ideally, fall risk tools would take less than 5 minutes to complete with no requirement for expensive equipment, much space beyond a clinic room or hallway, or additional training for implementation. Physical function tests feasible for use in primary care focus on assessing lower extremity strength, endurance, balance, and/or mobility. These tests vary in their ability to predict future falls, and many were originally intended for research purposes rather than primary care practice.

Table 1 Fall Risk Screening Tools Feasible for Primary Care^*^

Screening tool | Brief description of screening tool | K | N | Cutoff score | AUC, range^†^ | Sensitivity, range | Specificity, range
Timed Up and Go test (TUG) | Participants are asked to stand up from a chair, walk 3 meters, turn, walk 3 meters back, and sit down again. The time taken to perform this task indicates high or low risk of falls. | 12 | 5,240 | Varied | 0.46 to 0.89 | 0.10 to 0.83^†^ | 0.28 to 0.97^‡^
Gait Speed test (4 m) | Participants are asked to walk 4 meters at their usual pace. The time taken to complete the task is recorded, and Gait Speed is calculated (m/s). | 1 | 541 | NR | 0.54 to 0.68 | NR | NR
Gait Speed test (4 m) | Participants are asked to walk 4 meters at their usual pace. The time taken to complete the task is recorded, and Gait Speed is calculated (m/s). | 2 | 118 | 0.67 m/s to ≥18 s | NR | 0.38 to 1.0 | 0.24 to 0.85
Berg Balance Scale (BBS) | Participants are asked to perform a variety of sitting, transferring, and standing positions. | 1 | 187 | ≤52 | 0.47 | NR | NR
Berg Balance Scale (BBS) | Participants are asked to perform a variety of sitting, transferring, and standing positions. | 2 | 312 | ≤45 to ≤54 | 0.59 to 0.68 | 0.25 to 0.69 | 0.53 to 0.87
Performance Oriented Mobility Assessment – Balance (POMA-B) | Participants are asked to perform nine different movements to assess balance. | 4 | 442 | <8 to 10 | NR | 0.23 to 0.89 | 0.47 to 0.91
Performance Oriented Mobility Assessment - Gait (POMA-G) | Participants are asked to perform six different movements to assess gait. It is recommended to conduct this test in a corridor. | 2 | 252 | 9 | NR | 0.21 to 0.64 | 0.62 to 0.95
Functional Reach test (FR) | Participants are asked to hold their arms in front of them at an angle of 90 degrees, stretch forward as far as possible and return to the starting position. The distance between the starting position and the stretched position is used as an indicator of the risk of falling. | 2 | 1,544 | NR | 0.509 to 0.60 | NR | NR
Functional Reach test (FR) | | 1 | 50 | 8 in | NR | 0.73 | 0.88
Falls History | Definition varies. Most commonly, participants are asked if they have had one or more falls in the previous year. | 4 | 1,603 | ≥1 fall in the previous year | 0.71^§^ | 0.39 to 0.69 | 0.63 to 0.82
Falls History | Definition varies. Most commonly, participants are asked if they have had one or more falls in the previous year. | 1 | 449 | History of multiple falls | 0.64 | NR | NR
STEADI 12-question tool | 12 questions addressing a variety of fall risk factors, including fall history, balance, worry about falling, leg strength, urinary urgency, foot numbness, medications, and symptoms of depression. | 3 | 2,120 | ≥4 | NR | 0.53 to 0.78 | 0.61 to 0.88
STEADI 3-key question tool | Feeling unsteady, being worried about falling, and recent fall history. | 3 | 2,120 | Yes to any question | NR | 0.69 to 0.94 | 0.35 to 0.75

* Adapted from Meeks, 2021^17^ and Lin, 2022.^24^

† The reported area under the curve (AUC) for all tools included prospective falls ascertainment 6 months to 108 months after the tool’s administration.

‡ Reported in 8 studies.

§ Reported in 1 study.

Abbreviations: AUC = area under the curve; m = meter; NR = not reported; s = second.

A 2021 systematic review (k=27, N=8,660)^17^ examined the performance of fall risk screening tools for predicting falls in community-dwelling adults. Seven primary care feasible tools with performance outcomes were identified: Timed Up and Go (TUG) test, Gait Speed test, Berg Balance Scale, Performance Oriented Mobility Assessment-Balance (POMA-B), Performance Oriented Mobility Assessment-Gait (POMA-G), Functional Reach test, and falls history. Most of the identified studies captured fall risk among older adults over a period of 12 months (mean duration of followup, 15 months; range of followup, 6 months to 9 years). Results showed that none of the tools performed adequately; however, falls history performed equally to or better than any other tool (Table 1). The reported area under the curve (AUC) for all tools included prospective falls ascertainment 6 months to 108 months after the tool’s administration. The AUCs typically ranged from 0.5 to 0.7 and were considered inadequate for discrimination.^17^ More specifically, for the TUG, which provides a quick assessment of an individual’s strength, mobility capacity, and dynamic balance, 12 studies (N=5,240) reported an AUC that ranged from 0.46 to 0.89; sensitivity and specificity (k=8, N=1,433) ranged from 10 to 83.3 percent and 28.4 to 96.6 percent, respectively. For the Gait Speed Test, which measures the time it takes an individual to walk a set distance at their usual pace, one study (N=541) reported AUCs ranging from 0.54 to 0.68 for various followup periods; sensitivity and specificity (k=2, N=118) ranged from 38.4 to 100 percent and 23.9 to 84.7 percent, respectively. For the Berg Balance Scale, which provides a standardized assessment of balance, one study (N=187) reported an AUC of 0.59 while another study (N=98) reported an AUC of 0.47; sensitivity and specificity were reported in two studies (N=312) at various cut-off scores and varied widely. For the Tinetti POMA-B, which measures nine different movements to assess balance, four studies (N=442) reported sensitivities of 7.6 to 64 percent and specificities of 66.1 to 91 percent for cut-offs ranging from ≤8 to ≤10. For the Tinetti POMA-G, which measures six different movements to assess gait, two studies (N=252) reported sensitivities of 21 and 64 percent and specificities of 62.5 and 95 percent for a cut-off score of 9. For the Functional Reach test, which assesses balance and mobility, two studies (N=1,544) reported AUCs of 0.509 and 0.60; one study (N=50) reported a sensitivity of 73 percent and a specificity of 88 percent. For falls history, which assesses fall risk by asking older adults if they had fallen in the previous year, two studies (N=811) reported AUCs of 0.64 and 0.71; sensitivity and specificity were reported in three studies (N=1,411) and ranged from 39 to 69 percent and 63 to 82 percent, respectively. The lack of conclusive evidence to identify fall risk assessment tools with adequate predictive performance and accuracy are consistent with other systematic reviews.^17–19^ Additional attempts to examine other screening tools or develop new risk screening tools have had similar results.^20,^ ^21^ One large trial that included a mailed questionnaire including history and number of falls in the past 12 months, problems with balance while walking, and difficulty with activities of daily living (ADLs) reported an AUC of 0.66 (95% CI, 0.64 to 0.68) for a single fall, 0.72 (95% CI, 0.69 to 0.74) for repeat falls, and 0.60 (95% CI, 0.55 to 0.64) for fracture.^22^ Researchers have argued that future studies should focus on the effectiveness of fall risk assessment tools in the reduction of falls and injuries using a randomized trial design rather than on prognostic accuracy.^20^

While current literature shows that all prognostic tools have inadequate discrimination, some experts have recommended an expert-guided approach to risk assessment.^23^ However, research is limited. For example, the CDC’s Stopping Elderly Accidents, Deaths, and Injuries (STEADI) initiative provides healthcare professionals with a standardized fall risk screening protocol (i.e., a 12-question screening tool and comprehensive fall risk assessment) and a comprehensive list of recommended interventions based on individualized risk factors. A 2022 systematic review^24^ synthesized findings from three prospective studies (N=4,025) examining the predictive validity of the STEADI questionnaires. The three identified studies were small and only one study (N=77) reported the sensitivity and specificity of the STEADI algorithm for predicting falls in the next 6 months (68.4% and 44.9%, respectively). All three studies, however, reported the predictive validity of the 12-question screening tool alone, with sensitivity ranging from 52.6 to 77.7 percent and specificity ranging from 61.2 to 88.0 percent for 6- to 12-month prospective falls. Using three key questions from the tool resulted in increased sensitivity (range, 68.7% to 93.9%), but lower specificity (range, 34.7% to 75%).^24^ An additional small study (N=95) reported AUCs of 0.87 to 0.91 when only two to three questions from the STEADI tool were administered.^25^ While results showed fair predictive ability, large-scale studies are needed to further examine the effectiveness of the STEADI in clinical settings.

## Treatment Approaches

Interventions to prevent falls in older adults are varied and complex, with multiple components involving multidisciplinary teams in different implementation settings. Interventions can be delivered alone, in combination, or as part of an individualized multifactorial assessment and intervention. Depending on the risk factors identified, patients may need to receive interventions for multiple risk factors, and this is often referred to as a multifactorial assessment and intervention. Interventions to reduce falls may include exercise (including physical therapy), reduction or alteration of medications to reduce fall risk, occupational therapy to assist with identifying home hazards, referrals to specialists for visual impairment or podiatric issues, and treatment of comorbidities, including conditions like osteoporosis, which increases fracture risk after falls.^26^

## Current Clinical Practice in the United States and Recent Recommendations

There are many reported barriers to implementation of fall-prevention interventions in current U.S. clinical practice, including competing demands, clinician education, and logistical issues (limitations in patient transportation, mobility). Furthermore, fewer than half of patients who experience a fall mention it to their doctor.^27^ A 2018 survey of primary care providers found that 87 percent believed fall risk assessments could be effective in reducing fall risk among their older patients; 96 percent believed that older adults should be assessed for fall risk. However, only 52 percent of providers felt they had the expertise to conduct risk assessment for falls.^28^

After an initial risk assessment in the context of a primary care visit or an annual prevention or wellness visit, primary care clinicians may elect to refer all patients identified as being at high risk of falls to individual or multiple services for further risk assessment and tailored intervention or interventions (e.g., home health, physical therapy, occupational therapy). Alternatively, where available, clinicians can refer a patient at high risk of falls to a “falls clinic.” These clinics are not widely available in the United States and vary substantially in personnel staffing, content of the visit, and duration of the intervention. A falls clinic may have a single or multiple specialties staffed by advanced registered-nurse practitioners, physical therapists, occupational therapists, and/or a variety of physician specialists (e.g., geriatrician, physical medicine and rehabilitation physician, ophthalmologist, otolaryngologist, neurologist, orthopedist). The clinic can provide multicomponent risk assessments in a patient encounter lasting between 30 minutes to 3 hours and generate tailored referrals. It may also provide ongoing interventions to prevent falls.

The Centers for Medicare & Medicaid Services (CMS) sponsors the Initial Preventive Physical Examination (IPPE, known as the “Welcome to Medicare Preventive Visit”), a one-time benefit for all new Medicare beneficiaries within the first 12 months of their first Medicare Part B coverage period, along with the Annual Wellness Visit. As part of these visits, healthcare providers collect the plan member’s medical history, including risk factors for depression and other mood disorders, and review the beneficiary’s functional ability and level of safety. Appropriate screening questions and standardized questionnaires are used to review functional elements, including the risk of falls, hearing impairment, ADLs, and home safety.

To help incentivize primary care physicians to perform fall risk assessment and intervention, CMS also provides a five-star quality rating to insurance plans that measure the percentage of plan members with a risk of falling who discussed this risk with their physicians and received a fall-prevention intervention.^29,^ ^30^ Despite efforts, implementation and utilization of annual wellness visits are suboptimal. A 2018 analysis^31^ of Medicare claims data from 2008 to 2015 concluded that roughly half of primary care practices offer annual wellness visits and less than 20 percent of eligible Medicare beneficiaries receive them. Results also highlighted disparities among demographic and geographic characteristics. For example, annual wellness visit rates in rural practices were lower compared to metropolitan practices (8.1% versus 24.4%, respectively). Further, Black, Asian, “Hispanic,” “North American Native” or other race individuals, patients with dual enrollment in Medicare and Medicaid, and patients with higher medical risk were less likely to receive an annual wellness visit compared to other patients (i.e., White individuals, patients with low medical risk) in the same practice.

Healthcare providers can also use the CDC STEADI toolkit, which was designed to help providers incorporate fall risk assessments and individualized fall interventions into current clinical practice.^32^ The Royal Australian College of General Practitioners recommends assessment of risk for falls in older adults and, if indicated, a complete physical examination, medical history, and cognitive and functional assessments. Recommended first-line interventions include: exercise programs, medication review, and other multicomponent lifestyle modifications.^33^ The U.S. Department of Health and Human Services’ activity guidelines recommend that older adults get at least 150 minutes of moderate-intensity or 75 minutes of vigorous-intensity aerobic physical activity per week, as well as muscle-strengthening activities twice per week.^34^ Balance training three or more days per week for older adults at risk of falls due to a recent fall or difficulty walking is also recommended.^34^ The National Institute on Aging outlines several interventions for falls: exercise for strength and balance, monitoring for environmental hazards, regular medical care to ensure optimized hearing and vision, and medication management.^35^

Recommendations from other professional societies or organizations are listed in Table 2. While all endorse interventions to prevent falls among older adults, the recommended interventions vary.

Table 2 Society and Professional Organization Recommendations on Falls Prevention in Community-Dwelling Older Adults

Society or Professional Organization | Year | Age, years | Recommendation
World Falls Guideline^203^ | 2022 | NR | Recommends that all older adults should be advised on falls prevention and physical activity. Opportunistic case finding for falls risk is recommended for community-dwelling older adults. Those considered at high risk should be offered a comprehensive multifactorial falls risk assessment with a view to co-design and implement personalised multidomain interventions. Other recommendations cover details of assessment and intervention components and combinations, and recommendations for specific settings and populations.
Centers for Disease Control and Prevention^32^ | 2021 | ≥65 | Recommends STEADI, a coordinated approach to implementing the AGS/BGS clinical practice guidelines for fall prevention that consists of three core elements: screen to identify fall risk, assess modifiable risk factors, and intervene using effective clinical and community strategies to reduce the identified risk.; Clinical strategies include but are not limited to physical therapy and medication management. Community strategies include but are not limited to evidence-based exercise programs and home modification.
The Royal Australian College of General Practitioners^33^ | 2018 | ≥65 | Recommend assessing risk of falls and if indicated by the screening questions, determine multifactorial fall risk and obtain relevant medical history, conduct a complete physical examination, and perform cognitive and functional assessments.; Recommended interventions: exercise programs; medication review; vitamin D supplementation; podiatry intervention if indication; discuss dangers of bifocal and multifocal glasses when walking outdoors and recommend single lens glasses when outdoors; identify cataracts; and occupational therapy home assessment (if history of recent falls).
U.S. Department of Health and Human Services^34^ | 2021 | NR | Recommends that older adults get at least 150 minutes of moderate-intensity or 75 minutes of vigorous-intensity aerobic physical activity per week, as well as muscle-strengthening activities twice per week.; Recommend balance training 3 or more days per week for older adults at risk of falls due to a recent fall or difficulty walking.
The National Institute of Aging^35^ | 2017 | NR | Outlines several interventions for falls: exercise for strength and balance, monitoring for environmental hazards, regular medical care to ensure optimized hearing and vision, and medication management.
National Institute for Health and Care Excellence^204^ | 2013 | ≥65 | Older adults in contact with health professionals should be asked routinely whether they have fallen in the past year and asked about the frequency, context, and characteristics of the fall(s).; Older people at risk of falling should be observed for balance and gait defects and considered for their ability to benefit from interventions to improve strength and balance.; Older adults who present for medical attention because of a fall, or report recurrent falls in the past year, or demonstrate abnormalities of gait and/or balance should be offered a multifactorial falls risk assessment.; Recommended interventions: Multifactorial interventions; strength and balance training; exercise in extended care settings; home hazard and safety intervention; psychotropic medication review; and cardiac pacing.
American Geriatrics Society/British Geriatrics Society^*^,^205^ | 2011 | NR | Recommend a multifactorial fall risk assessment for all older adults who present with a fall or who have gait and balance problems. Also recommend a multifactorial falls risk assessment for individuals who simply report difficulties with gait or balance. A falls risk assessment is not considered necessary for older persons reporting only a single fall without reported or demonstrated difficulty or unsteadiness.; Recommend that assessments include examination of the feet and footwear, functional assessment (assessment of activity of daily living skills, including use of adaptive equipment and mobility aids, as appropriate); assessment of the individual’s perceived functional ability and fear related to falling; and environmental assessment, including home safety.; Recommended components of multifactorial interventions: exercise, specifically programs that include balance, gait, and strength training, such as tai chi or physical therapy, in group programs or as individual programs at home; environmental adaptation or modification; medication reduction or withdrawal; assessment and treatment of postural hypotension; cataract surgery on the first eye should be expedited in older persons in which the surgery is indicated; dual-chamber cardiac pacing when indicated; and vitamin D supplementation.

* The AGS considers guidelines 5 years old and older to be no longer active. These inactive guidelines or recommendations have not been reviewed or updated by the AGS and the conclusions and recommendations in the guideline may not be current.

Abbreviations: AGS = American Geriatric Society; BGS = British Geriatrics Society; NR = not reported; STEADI = Stopping Elderly Accidents, Deaths, and Injuries.

## Previous USPSTF Recommendation

The USPSTF recommends exercise interventions to prevent falls in community-dwelling adults age 65 years or older who are at increased risk for falls (B recommendation). The USPSTF recommends that clinicians selectively offer multifactorial interventions to prevent falls to community-dwelling adults age 65 years or older who are at increased risk for falls. Existing evidence indicates that the overall net benefit of routinely offering multifactorial interventions to prevent falls is small. When determining whether this service is appropriate for an individual, patients and clinicians should consider the balance of benefits and harms based on the circumstances of prior falls, presence of comorbid medical conditions, and the patient’s values and preferences (C recommendation). The USPSTF recommends against vitamin D supplementation to prevent falls in community-dwelling adults age 65 years or older (D recommendation).