# Appendix References

1 Vespa J, Medina L, Armstrong DM. Demographic Turning Points for the United States: Population Projections for 2020 to 2060. Current Population Reports, P25-1144. Washington, DC: U.S. Census Bureau,; 2020.
2 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force: Procedure Manual. 2021.
3 Bruce J, Hossain A, Lall R, . Fall prevention interventions in primary care to reduce fractures and falls in people aged 70 years and over: the PreFIT three-arm cluster RCT. Health Technol Assess. 2021;25(34):1–114. PMID: 34075875. 10.3310/hta25340 34075875
4 Bhasin S, Gill TM, Reuben DB, . A Randomized Trial of a Multifactorial Strategy to Prevent Serious Fall Injuries. N Engl J Med. 2020;383(2):129–40. PMID: 32640131. 10.1056/NEJMoa2002183 32640131
5 Ciaschini PM, Straus SE, Dolovich LR, . Community-based intervention to optimise falls risk management: a randomised controlled trial. Age Ageing. 2009;38(6):724–30. PMID: 19767629. 10.1093/ageing/afp176 19767629
6 Close J, Ellis M, Hooper R, . Prevention of falls in the elderly trial (PROFET): a randomised controlled trial. Lancet. 1999;353(9147):93–7. PMID: 10023893. 10.1016/S0140-6736(98)06119-4 10023893
7 Cohen MA, Miller J, Xiaomei S, . Prevention Program Lowered The Risk Of Falls And Decreased Claims For Long-Term Services Among Elder Participants. Health Affairs. 2015;34(6):971–7. PMID: 26056202. 10.1377/hlthaff.2014.1172 26056202
8 Conroy S, Kendrick D, Harwood R, . A multicentre randomised controlled trial of day hospital-based falls prevention programme for a screened population of community-dwelling older people at high risk of falls. Age Ageing. 2010;39(6):704–10. PMID: 20823124. 10.1093/ageing/afq096 20823124
9 Davison J, Bond J, Dawson P, . Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention--a randomised controlled trial. Age Ageing. 2005;34(2):162–8. PMID: 15716246. 10.1093/ageing/afi053 15716246
10 de Vries OJ, Peeters GM, Elders PJ, . Multifactorial intervention to reduce falls in older people at high risk of recurrent falls: a randomized controlled trial. Arch Intern Med. 2010;170(13):1110–7. PMID: 20625015. 10.1001/archinternmed.2010.169 20625015
11 Elley CR, Robertson MC, Garrett S, . Effectiveness of a falls-and-fracture nurse coordinator to reduce falls: a randomized, controlled trial of at-risk older adults. J Am Geriatr Soc. 2008;56(8):1383–9. PMID: 18808597. 10.1111/j.1532-5415.2008.01802.x 18808597
12 Fairhall N, Sherrington C, Lord SR, . Effect of a multifactorial, interdisciplinary intervention on risk factors for falls and fall rate in frail older people: a randomised controlled trial. Age Ageing. 2014;43(5):616–22. PMID: 24381025. 10.1093/ageing/aft204 24381025
13 Ferrer A, Formiga F, Sanz H, . Multifactorial assessment and targeted intervention to reduce falls among the oldest-old: a randomized controlled trial. Clin Interv Aging. 2014;9:383–93. PMID: 24596458. 10.2147/CIA.S57580 24596458
14 Hendriks MR, Bleijlevens MH, van Haastregt JC, . Lack of effectiveness of a multidisciplinary fall-prevention program in elderly people at risk: a randomized, controlled trial. J Am Geriatr Soc. 2008;56(8):1390–7. PMID: 18662214. 10.1111/j.1532-5415.2008.01803.x 18662214
15 Hogan DB, MacDonald FA, Betts J, . A randomized controlled trial of a community-based consultation service to prevent falls. CMAJ. 2001;165(5):537–43. PMID: 11563205.11563205
16 Imhof L, Naef R, Wallhagen MI, . Effects of an advanced practice nurse in-home health consultation program for community-dwelling persons aged 80 and older. J Am Geriatr Soc. 2012;60(12):2223–31. PMID: 23194103. 10.1111/jgs.12026 23194103
17 La Porta F, Lullini G, Caselli S, . Efficacy of a multiple-component and multifactorial personalized fall prevention program in a mixed population of community-dwelling older adults with stroke, Parkinson’s Disease, or frailty compared to usual care: The PRE.C.I.S.A. randomized controlled trial. Front Neurol. 2022;13:943918. PMID: 36119666. 10.3389/fneur.2022.943918 36119666
18 Lightbody E, Watkins C, Leathley M, . Evaluation of a nurse-led falls prevention programme versus usual care: a randomized controlled trial. Age Ageing. 2002;31(3):203–10. PMID: 12006310. 10.1093/ageing/31.3.203 12006310
19 Logan PA, Coupland CA, Gladman JR, . Community falls prevention for people who call an emergency ambulance after a fall: randomised controlled trial. BMJ. 2010;340:c2102. PMID: 20460331. 10.1136/bmj.c2102 20460331
20 Lord SR, Tiedemann A, Chapman K, . The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(8):1296–304. PMID: 16078954. 10.1111/j.1532-5415.2005.53425.x 16078954
21 Moller UO, Kristensson J, Midlov P, . Effects of a one-year home-based case management intervention on falls in older people: a randomized controlled trial. J Aging Phys Act. 2014;22(4):457–64. PMID: 24152667. 10.1123/japa.2013-0101 24152667
22 Palvanen M, Kannus P, Piirtola M, . Effectiveness of the Chaos Falls Clinic in preventing falls and injuries of home-dwelling older adults: a randomised controlled trial. Injury. 2014;45(1):265–71. PMID: 23579066. 10.1016/j.injury.2013.03.010 23579066
23 Perula LA, Varas-Fabra F, Rodriguez V, . Effectiveness of a multifactorial intervention program to reduce falls incidence among community-living older adults: a randomized controlled trial. Arch Phys Med Rehabil. 2012;93(10):1677–84. PMID: 22609117. 10.1016/j.apmr.2012.03.035 22609117
24 Russell MA, Hill KD, Day LM, . A randomized controlled trial of a multifactorial falls prevention intervention for older fallers presenting to emergency departments. J Am Geriatr Soc. 2010;58(12):2265–74. PMID: 21143436. 10.1111/j.1532-5415.2010.03191.x 21143436
25 Salminen MJ, Vahlberg TJ, Salonoja MT, . Effect of a risk-based multifactorial fall prevention program on the incidence of falls. J Am Geriatr Soc. 2009;57(4):612–9. PMID: 19392952. 10.1111/j.1532-5415.2009.02176.x 19392952
26 Spice CL, Morotti W, George S, . The Winchester falls project: a randomised controlled trial of secondary prevention of falls in older people. Age Ageing. 2009;38(1):33–40. PMID: 18829689. 10.1093/ageing/afn192 18829689
27 Tinetti ME, Baker DI, McAvay G, . A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331(13):821–7. PMID: 8078528. 10.1056/NEJM199409293311301 8078528
28 van Haastregt JC, Diederiks JP, van Rossum E, . Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321(7267):994–8. PMID: 11039967. 10.1136/bmj.321.7267.994 11039967
29 Vind AB, Andersen HE, Pedersen KD, . An outpatient multifactorial falls prevention intervention does not reduce falls in high-risk elderly Danes. J Am Geriatr Soc. 2009;57(6):971–7. PMID: 19507291.19507291
30 Wagner EH, LaCroix AZ, Grothaus L, . Preventing disability and falls in older adults: a population-based randomized trial. Am J Public Health. 1994;84(11):1800–6. PMID: 7977921. 10.2105/ajph.84.11.1800 7977921
31 Barnett A, Smith B, Lord SR, . Community-based group exercise improves balance and reduces falls in at-risk older people: a randomised controlled trial. Age Ageing. 2003;32(4):407–14. PMID: 12851185.12851185
32 Buchner DM, Cress ME, de Lateur BJ, . The effect of strength and endurance training on gait, balance, fall risk, and health services use in community-living older adults. J Gerontol A Biol Sci Med Sci. 1997;52(4):M218–M24. PMID: 9224433. 10.1093/gerona/52a.4.m218 9224433
33 Callisaya ML, Jayakody O, Vaidya A, . A novel cognitive-motor exercise program delivered via a tablet to improve mobility in older people with cognitive impairment - StandingTall Cognition and Mobility. Exp Gerontol. 2021;152:111434. PMID: 34098009. 10.1016/j.exger.2021.111434 34098009
34 Campbell AJ, Robertson MC, Gardner MM, . Randomised controlled trial of a general practice programme of home based exercise to prevent falls in elderly women. BMJ. 1997;315(7115):1065–9. PMID: 9366737.9366737
35 Chyu MC, James CR, Sawyer SF, . Effects of tai chi exercise on posturography, gait, physical function and quality of life in postmenopausal women with osteopaenia: a randomized clinical study. Clinical Rehabilitation. 2010;24(12):1080–90. PMID: 20702512. 10.1177/0269215510375902 20702512
36 Delbaere K, Valenzuela T, Lord SR, . E-health StandingTall balance exercise for fall prevention in older people: results of a two year randomised controlled trial. BMJ. 2021;373:n740. PMID: 33824131. 10.1136/bmj.n740 33824131
37 El-Khoury F, Cassou B, Latouche A, . Effectiveness of two year balance training programme on prevention of fall induced injuries in at risk women aged 75-85 living in community: Ossebo randomised controlled trial. BMJ. 2015;351:h3830. PMID: 26201510. 10.1136/bmj.h3830 26201510
38 Fitzharris MP, Day L, Lord SR, . The Whitehorse NoFalls trial: effects on fall rates and injurious fall rates. Age Ageing. 2010;39(6):728–33. PMID: 20817936. 10.1093/ageing/afq109 20817936
39 Goldberg SE, van der Wardt V, Brand A, . Promoting activity, Independence and stability in early dementia (PrAISED): a, multisite, randomised controlled, feasibility trial. BMC Geriatrics. 2019;19(1):353. PMID: 31842828. 10.1186/s12877-019-1379-5 31842828
40 Karinkanta S, Kannus P, Uusi-Rasi K, . Combined resistance and balance-jumping exercise reduces older women’s injurious falls and fractures: 5-year follow-up study. Age Ageing. 2015;44(5):784–9. PMID: 25990940. 10.1093/ageing/afv064 25990940
41 Korpelainen R, Keinanen-Kiukaanniemi S, Heikkinen J, . Effect of impact exercise on bone mineral density in elderly women with low BMD: a population-based randomized controlled 30-month intervention. Osteoporos Int. 2006;17(1):109–18. PMID: 15889312. 10.1007/s00198-005-1924-2 15889312
42 Kovacs E, Prokai L, Meszaros L, . Adapted physical activity is beneficial on balance, functional mobility, quality of life and fall risk in community-dwelling older women: a randomized single-blinded controlled trial. Eur J Phys Rehabil Med. 2013;49(3):301–10. PMID: 23486300.23486300
43 Kronhed AG, Hallberg I, Odkvist L, . Effect of training on health-related quality of life, pain and falls in osteoporotic women. Adv Physiother. 2009;11(3):154–65. 10.1080/14038190902896659
44 Lamb SE, Mistry D, Alleyne S, . Aerobic and strength training exercise programme for cognitive impairment in people with mild to moderate dementia: the DAPA RCT. Health Technology Assessment (Winchester, England). 2018;22(28):1–202. PMID: 29848412. 10.3310/hta22280 29848412
45 Lipsitz LA, Macklin EA, Travison TG, . A Cluster Randomized Trial of Tai Chi vs Health Education in Subsidized Housing: The MI-WiSH Study. Journal of the American Geriatrics Society. 2019;67(9):1812–9. PMID: 31116883. 10.1111/jgs.15986 31116883
46 Logghe IH, Zeeuwe PE, Verhagen AP, . Lack of effect of Tai Chi Chuan in preventing falls in elderly people living at home: a randomized clinical trial. J Am Geriatr Soc. 2009;57(1):70–5. PMID: 19054193. 10.1111/j.1532-5415.2008.02064.x 19054193
47 Luukinen H, Lehtola S, Jokelainen J, . Pragmatic exercise-oriented prevention of falls among the elderly: a population-based, randomized, controlled trial. Prev Med. 2007;44(3):265–71. PMID: 17174387. 10.1016/j.ypmed.2006.09.011 17174387
48 Merom D, Mathieu E, Cerin E, . Social Dancing and Incidence of Falls in Older Adults: A Cluster Randomised Controlled Trial. PLoS Medicine / Public Library of Science. 2016;13(8):e1002112. PMID: 27575534. 10.1371/journal.pmed.1002112 27575534
49 Miko I, Szerb I, Szerb A, . Effect of a balance-training programme on postural balance, aerobic capacity and frequency of falls in women with osteoporosis: A randomized controlled trial. J Rehabil Med. 2018;50(6):542–7. PMID: 29767227. 10.2340/16501977-2349 29767227
50 Morgan RO, Virnig BA, Duque M, . Low-intensity exercise and reduction of the risk for falls among at-risk elders. J Gerontol A Biol Sci Med Sci. 2004;59(10):1062–7. PMID: 15528779. 10.1093/gerona/59.10.m1062 15528779
51 Ng TP, Feng L, Nyunt MS, . Nutritional, Physical, Cognitive, and Combination Interventions and Frailty Reversal Among Older Adults: A Randomized Controlled Trial. Am J Med. 2015. PMID: 26159634. 10.1016/j.amjmed.2015.06.017 26159634
52 Ohman H, Savikko N, Strandberg T, . Effects of Exercise on Functional Performance and Fall Rate in Subjects with Mild or Advanced Alzheimer’s Disease: Secondary Analyses of a Randomized Controlled Study. Dement Geriatr Cogn Disord. 2016;41(3–4):233–41. PMID: 27160164. 10.1159/000445712 27160164
53 Oliveira JS, Sherrington C, Paul SS, . A combined physical activity and fall prevention intervention improved mobility-related goal attainment but not physical activity in older adults: a randomised trial. J Physiother. 2019;65(1):16–22. PMID: 30581138. 10.1016/j.jphys.2018.11.005 30581138
54 Rikkonen T, Sund R, Koivumaa-Honkanen H, . Effectiveness of exercise on fall prevention in community-dwelling older adults: a 2-year randomized controlled study of 914 women. Age & Ageing. 2023;52(4):01. PMID: 37097767. 10.1093/ageing/afad059 37097767
55 Robertson MC, Devlin N, Gardner MM, . Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls. 1: Randomised controlled trial. BMJ. 2001;322(7288):697–701. PMID: 11264206. 10.1136/bmj.322.7288.697 11264206
56 Rosado H, Bravo J, Raimundo A, . Effects of two 24-week multimodal exercise programs on reaction time, mobility, and dual-task performance in community-dwelling older adults at risk of falling: a randomized controlled trial. BMC Public Health. 2021;21(Suppl 2):408. PMID: 34758759. 10.1186/s12889-021-10448-x 34758759
57 Sherrington C, Lord SR, Vogler CM, . A post-hospital home exercise program improved mobility but increased falls in older people: a randomised controlled trial. PLoS ONE. 2014;9(9):e104412. PMID: 25180702. 10.1371/journal.pone.0104412 25180702
58 Siegrist M, Freiberger E, Geilhof B, . Fall Prevention in a Primary Care Setting. Dtsch. 2016;113(21):365–72. PMID: 27504699. 10.3238/arztebl.2016.0365 27504699
59 Stathi A, Greaves CJ, Thompson JL, . Effect of a physical activity and behaviour maintenance programme on functional mobility decline in older adults: the REACT (Retirement in Action) randomised controlled trial. Lancet Public Health. 2022;7(4):e316–e26. PMID: 35325627. 10.1016/S2468-2667(22)00004-4 35325627
60 Suikkanen S, Soukkio P, Aartolahti E, . Effect of 12-Month Supervised, Home-Based Physical Exercise on Functioning Among Persons With Signs of Frailty: A Randomized Controlled Trial. Archives of Physical Medicine & Rehabilitation. 2021;102(12):2283–90. PMID: 34283997. 10.1016/j.apmr.2021.06.017 34283997
61 Tomita M, Fisher N, Ramsey D, . Effects of Virtual-Group Exercise at Home (V-GEAH) on Adherence and Fall Risks in Older Adults with a History of Falling. Gerontology Geriatr Res. 2016;2(3):1018.
62 Trombetti A, Hars M, Herrmann FR, . Effect of music-based multitask training on gait, balance, and fall risk in elderly people: a randomized controlled trial. Arch Intern Med. 2011;171(6):525–33. PMID: 21098340. 10.1001/archinternmed.2010.446 21098340
63 Tuvemo Johnson S, Anens E, Johansson AC, . The Otago Exercise Program With or Without Motivational Interviewing for Community-Dwelling Older Adults: A 12-Month Follow-Up of a Randomized, Controlled Trial. J Appl Gerontol. 2021;40(3):289–99. PMID: 32114877. 10.1177/0733464820902652 32114877
64 Uusi-Rasi K, Patil R, Karinkanta S, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 2015;175(5):703–11. PMID: 25799402. 10.1001/jamainternmed.2015.0225 25799402
65 Voukelatos A, Cumming RG, Lord SR, . A randomized, controlled trial of tai chi for the prevention of falls: the Central Sydney tai chi trial. J Am Geriatr Soc. 2007;55(8):1185–91. PMID: 17661956. 10.1111/j.1532-5415.2007.01244.x 17661956
66 Voukelatos A, Merom D, Sherrington C, . The impact of a home-based walking programme on falls in older people: the Easy Steps randomised controlled trial. Age Ageing. 2015;44(3):377–83. PMID: 25572426. 10.1093/ageing/afu186 25572426
67 Daly RM, Gianoudis J, Kersh ME, . Effects of a 12-Month Supervised, Community-Based, Multimodal Exercise Program Followed by a 6-Month Research-to-Practice Transition on Bone Mineral Density, Trabecular Microarchitecture, and Physical Function in Older Adults: A Randomized Controlled Trial. Journal of Bone & Mineral Research. 2020;35(3):419–29. PMID: 31498937. 10.1002/jbmr.3865 31498937
68 Sherrington C, Fairhall N, Kirkham C, . Exercise to Reduce Mobility Disability and Prevent Falls After Fall-Related Leg or Pelvic Fracture: RESTORE Randomized Controlled Trial. Journal of General Internal Medicine. 2020;35(10):2907–16. PMID: 32016702. 10.1007/s11606-020-05666-9 32016702
69 Shumway-Cook A, Silver I, Mary L, . Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. J Gerontol A Biol Sci Med Sci. 2007;62(12):1420–7. PMID: 18166695. 10.1093/gerona/62.12.1420 18166695
70 Smulders E, Weerdesteyn V, Groen BE, . Efficacy of a short multidisciplinary falls prevention program for elderly persons with osteoporosis and a fall history: a randomized controlled trial. Arch Phys Med Rehabil. 2010;91(11):1705–11. PMID: 21044715. 10.1016/j.apmr.2010.08.004 21044715
71 Sherrington C, Fairhall N, Kirkham C, . Exercise and fall prevention self-management to reduce mobility-related disability and falls after fall-related lower limb fracture in older people: protocol for the RESTORE (Recovery Exercises and STepping On afteR fracturE) randomised controlled trial. BMC Geriatrics. 2016;16:34. PMID: 26838998. 10.1186/s12877-016-0206-5 26838998
72 Matchar DB, Duncan PW, Lien CT, . Randomized Controlled Trial of Screening, Risk Modification, and Physical Therapy to Prevent Falls Among the Elderly Recently Discharged From the Emergency Department to the Community: The Steps to Avoid Falls in the Elderly Study. Archives of Physical Medicine & Rehabilitation. 2017;98(6):1086–96. PMID: 28202383. 10.1016/j.apmr.2017.01.014 28202383
73 Taylor ME, Wesson J, Sherrington C, . Tailored Exercise and Home Hazard Reduction Program for Fall Prevention in Older People With Cognitive Impairment: The i-FOCIS Randomized Controlled Trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2021;76(4):655–65. PMID: 32949456. 10.1093/gerona/glaa241 32949456
74 Chu MM, Fong KN, Lit AC, . An Occupational Therapy Fall Reduction Home Visit Program for Community-Dwelling Older Adults in Hong Kong After an Emergency Department Visit for a Fall. Journal of the American Geriatrics Society. 2017;65(2):364–72. PMID: 27858951. 10.1111/jgs.14527 27858951
75 Cockayne S, Pighills A, Adamson J, . Home environmental assessments and modification delivered by occupational therapists to reduce falls in people aged 65 years and over: the OTIS RCT. Health Technol Assess. 2021;25(46):1–118. PMID: 34254934. 10.3310/hta25460 34254934
76 Pighills AC, Torgerson DJ, Sheldon TA, . Environmental assessment and modification to prevent falls in older people.[Erratum appears in J Am Geriatr Soc. 2011 Apr;59(4):776]. J Am Geriatr Soc. 2011;59(1):26–33. PMID: 21226674. 10.1111/j.1532-5415.2010.03221.x 21226674
77 Stark S, Keglovits M, Somerville E, . Home Hazard Removal to Reduce Falls Among Community-Dwelling Older Adults: A Randomized Clinical Trial. JAMA netw. 2021;4(8):e2122044. PMID: 34463746. 10.1001/jamanetworkopen.2021.22044 34463746
78 Stevens M, Holman CD, Bennett N, . Preventing falls in older people: outcome evaluation of a randomized controlled trial. J Am Geriatr Soc. 2001;49(11):1448–55. PMID: 11890582. 10.1046/j.1532-5415.2001.4911236.x 11890582
79 Blalock SJ, Casteel C, Roth MT, . Impact of enhanced pharmacologic care on the prevention of falls: a randomized controlled trial. Am J Geriatr Pharmacother. 2010;8(5):428–40. PMID: 21335296. 10.1016/j.amjopharm.2010.09.002 21335296
80 Boye ND, van der Velde N, de Vries OJ, . Effectiveness of medication withdrawal in older fallers: results from the Improving Medication Prescribing to reduce Risk Of FALLs (IMPROveFALL) trial. Age & Ageing. 2017;46(1):142–6. PMID: 28181639. 10.1093/ageing/afw161 28181639
81 Mott DA, Martin B, Breslow R, . Impact of a medication therapy management intervention targeting medications associated with falling: Results of a pilot study. J Am Pharm Assoc (2003). 2016;56(1):22–8. PMID: 26802916. 10.1016/j.japh.2015.11.001 26802916
82 Romskaug R, Skovlund E, Straand J, . Effect of Clinical Geriatric Assessments and Collaborative Medication Reviews by Geriatrician and Family Physician for Improving Health-Related Quality of Life in Home-Dwelling Older Patients Receiving Polypharmacy: A Cluster Randomized Clinical Trial. JAMA Intern Med. 2020;180(2):181–9. PMID: 31617562. 10.1001/jamainternmed.2019.5096 31617562
83 Dorresteijn TA, Zijlstra GA, Ambergen AW, . Effectiveness of a home-based cognitive behavioral program to manage concerns about falls in community-dwelling, frail older people: results of a randomized controlled trial.[Erratum appears in BMC Geriatr. 2016;16:108; PMID: 27220990]. BMC Geriatr. 2016;16:2. PMID: 26739339. 10.1186/s12877-015-0177-y 26739339
84 Lim ML, Tran M, van Schooten KS, . A Self-Guided Online Cognitive Behavioural Therapy to Reduce Fear of Falling in Older People: a Randomised Controlled Trial. Int J Behav Med. 2022;02:02. PMID: 35655058. 10.1007/s12529-022-10105-6 35655058
85 Zijlstra GA, van Haastregt JC, Ambergen T, . Effects of a multicomponent cognitive behavioral group intervention on fear of falling and activity avoidance in community-dwelling older adults: results of a randomized controlled trial. J Am Geriatr Soc. 2009;57(11):2020–8. PMID: 19793161. 10.1111/j.1532-5415.2009.02489.x 19793161
86 Clemson L, Cumming RG, Kendig H, . The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J Am Geriatr Soc. 2004;52(9):1487–94. PMID: 15341550. 10.1111/j.1532-5415.2004.52411.x 15341550