# Appendix M Ongoing Studies

Appendix M Table 1 Ongoing Studies

Trial Identifier | Study Name | Country | N | Aim | Relevant Outcome(s) | Status 2023
NCT 04993781 (https://clinicaltrials.gov/ct2/show/NCT04993781?recrs=abdf&type=Intr&cond=Fall+Injury&age=2&draw=3&rank=19) | Electronic Strategies for Tailored Exercise to Prevent FallS (eSTEPS) | US | 8353 | Test the efficacy of a tailored fall prevention exercise (eSTEPS) intervention on falls and injurious falls in patients over age 65 at high risk for falls. | Falls; injurious falls | Recruiting; Estimated completion date: December 2025
NCT 05807724 (https://clinicaltrials.gov/ct2/show/NCT05807724?recrs=abdf&type=Intr&cond=Fall+Injury&age=2&draw=2&rank=1) | Geriatric Emergency Department (ED) Fall Injury Prevention Project | US | 1600 | Assess whether certain ED patients at high risk of recurrent falls and injuries related to falls will benefit from the recommendations of the Centers for Disease Control and Prevention’s Stopping Elderly Accidents, Deaths and Injuries (STEADI) program. | Recurrent fall requiring ED revisit; injurious falls; fall-related mortality | Recruiting; Estimated completion date: September 2024
NCT 05691166 (https://clinicaltrials.gov/ct2/show/NCT05691166?recrs=abdf&type=Intr&cond=Fall+Injury&age=2&draw=2&rank=78) | Reducing Falls with Progressive Resistance Training (ReFit) for the Oldest Old Adults With Sarcopenia. A 12-month Randomized Controlled Trial | US | 240 | Investigate the effects of 12 mo of high-intensity progressive resistance training compared with a control group on fall-rate in older adults with sarcopenia. | Falls | Recruiting; Estimated completion date: December 2025
NCT 05016141 (https://clinicaltrials.gov/ct2/show/NCT05016141?term=05016141&recrs=abdf&type=Intr&age=2&draw=2&rank=1) | Health in Motion- A Pragmatic Clinical Trial-Home | US | 120 | Evaluate the use of a digital solution that translates evidence-based fall prevention programs (such as Otago Exercise Program and Matter of Balance) to a digital solution (Health in Motion Fall Prevention Platform), as an alternative to home-based fall prevention programs that is affordable, scales to the millions of older adults across the country at risk for falls, and is sustainable for the older adult’s life. | Falls | Active; Estimated completion date: July 2023
NCT 03963570 (https://clinicaltrials.gov/ct2/show/NCT03963570) | The Effectiveness of a Self-managed Digital Exercise Program to Prevent Falls in Older Community-dwelling People (SafeStepRCT) | SWE | 1628 | Evaluate the effectiveness of a digital self-management exercise program in preventing falls in community-dwelling older people. | Falls | Completed, no results posted; Estimated completion date: May 2022
NCT 05694494 (https://clinicaltrials.gov/ct2/show/record/NCT05694494?recrs=abdf&type=Intr&cond=Fall+Injury&age=2&draw=2&rank=30) | Training- and Cost-effectiveness of an Internet-based Lifestyle-integrated Functional Exercise Program (iLiFE) | HK | 322 | Compare the effectiveness of an internet-based LiFE program in reducing subsequent falls and promoting exercise adherence in community-dwelling older adults. | Falls | Enrolling by invitation; Estimated completion date: November 2024
NCT 05406323 (https://clinicaltrials.gov/ct2/show/NCT05406323?recrs=abdf&type=Intr&cond=Fall+Injury&age=2&draw=3&rank=16) | The Effect of a Web-Based Fall Prevention Program on Fall, Fall Risk and Fall Fear Among Elderly | TR | 72 | Assess the effect of Web-Based Fall Prevention Program on falling, fall risk, and fear of fall. | Falls | Not yet recruiting; Estimated completion date: July 2023
NCT 04787432 (https://clinicaltrials.gov/ct2/show/NCT04787432) | Salutogenic Frailty Prevention Program for Women Aged 55 Years and Over (SAFRAPP) | TR | 84 | Examine the effectiveness of Salutogenic Model-Based Frailty Prevention Program (SAFRAPP) for pre-frail women. | Falls | Unknown; Estimated Study Completion Date: January 2022
NCT 05615077 (https://clinicaltrials.gov/ct2/show/study/NCT05615077) | Effectiveness of Comprehensive Intervention for the Prevention of Fall in Older Adults; a Randomized Controlled Trial | KOR | 484 | Demonstrate the effect of combined exercise-education intervention in old adults with fall risk. This study will be conducted with prospectively randomized controlled trial comparing outcome of combined exercise-education intervention with conventional medical care. | Falls, injurious falls | Recruiting; Estimated completion date: May 2026
NCT 05192408 (https://clinicaltrials.gov/ct2/show/NCT05192408?recrs=abdf&type=Intr&cond=Fall+Injury&age=2&draw=3&rank=17) | Multi-component Intervention for Reducing Fear of Falling in Community-dwelling Older Adults | SGP | 420 | Compare the effectiveness of a multi-component intervention comprising exercise recommendations, cognitive behavioral therapy components, and motivational interviewing-based telephone review against usual care for reducing fear of falling and falls in community-dwelling older adults. | Falls | Recruiting; Estimated completion date: May 2023
NCT 04801316 (https://clinicaltrials.gov/ct2/show/NCT04801316) | Steady Feet | SGP | 290 | Evaluate the effects of a strength and balance intervention (Steady Feet) among older adults age 60 years or older who are at high risk of falls. | Injurious falls | Recruiting; Estimated completion date: December 2022
DRKS 00016609 (https://www.uniklinik-freiburg.de/entaier-studie.html) | A multi-centre, parallel-group, randomized controlled trial to assess the efficacy and safety of eurythmy therapy and tai chi in comparison with standard care in chronically ill elderly patients with increased risk of falling (ENTAiER) | DEU | 550 | Determine whether eurythmy therapy and tai chi can reduce the risk of falling (i.e., experiencing at least one fall), which usually marks the beginning of dependency and the decline of mobility. | Falls | NR; Registered: July 2019
NCT 04911179 (https://clinicaltrials.gov/ct2/show/NCT04911179?term=04911179&recrs=abdf&type=Intr&age=2&draw=2&rank=1) | Combined Exercise and Cognitive Stimulation for Falls Prevention | ESP | 310 | Investigate the effect of the combined intervention (exercise and cognitive intervention) in frail older participants living in the community and at risk of falling. | Falls; fall-related hospitalizations; fall-related factures; fall-related death | Recruiting; Estimated completion date: April 2024
NCT 05449470 (https://clinicaltrials.gov/ct2/show/NCT05449470?recrs=abdf&type=Intr&cond=Fall+Injury&age=2&draw=2&rank=50) | Falls Prevention Improvement Through Developing a Computerized Clinical Support System: Effectiveness of Individualized Medication Withdrawal | NLD | 800 | Assess whether of the use of a clinical decision support system and a patient portal for communicating medication-related fall risk to fall clinic patients may improve joint medication management between patients and physicians and reduce the incidence of injurious falls. | Falls; injurious falls | Recruiting; Estimated completion date: June 2024
NCT 04717258 (https://clinicaltrials.gov/ct2/show/NCT04717258?recrs=abdf&type=Intr&cond=Fall+Injury&age=2&draw=2&rank=40) | Safe and Well Visits by the Fire and Rescue Service to Prevent Falls and Improve Quality of Life in Older People (FIREFLI) | UK | 1156 | Assess whether Safe and Well Visits delivered by the Fire and Rescue Service will lead to a reduction in the number of falls and an improvement in health-related quality of life in older people. | Falls; injurious falls; people experiencing a fall | Recruiting; Estimated completion date: September 2024
NCT04313062 (https://clinicaltrials.gov/ct2/show/NCT04313062?term=04313062&draw=2&rank=1) | Older People Self-Caring Through a Comprehensive Model Based on House Calls and Oriented Towards Falling Prevention (PM ACTIVAS) | CHL | 220 | Design, implement, and evaluate a comprehensive model based on house calls and oriented towards falling prevention (PM ACTIVAS’ model), with the hypothesis that people who received the educational intervention following the PM ACTIVAS’ model will: fall less frequently, improve their management on falls risk factors present at home, and have a higher falls risk perception than the control group. | Falls | Completed, no results posted; Estimated completion date: April 2022
NCT 05533333 (https://clinicaltrials.gov/ct2/show/NCT05533333) | Self-administered Dual-task Training for Reducing Falls Among the Older Adults | HK | 190 | Evaluate the effectiveness and cost-effectiveness of self-administered dual-task training for preventing falls among older adults. | Falls | Recruiting; Estimated completion date: December 2024

Abbreviations: AUS = Australia; CHL = Chile; ESP = Spain; DEU = Germany; HK = Hong Kong; KOR = South Korea; NLD = Netherlands; NR = Not reported; SGP = Singapore; SWE = Sweden; TR = Turkey; US = United States.