# Appendix L Education Interventions: Additional Evidence Tables

Appendix L Table 1 Education Interventions: Study and Population Characteristics

Appendix L Table 2 Education Interventions: Fall Risk and Comorbidities

Appendix L Table 3 Education Interventions: Intervention Components

Appendix L Table 4 Education Interventions: Falls

Appendix L Table 5 Education Interventions: People With a Fall

Appendix L Table 6 Education Interventions: Quality of Life