# Appendix K Psychological Interventions: Additional Evidence Tables

Appendix K Table 1 Psychological Interventions: Study and Population Characteristics

Appendix K Table 2 Psychological Interventions: Fall Risk and Comorbidities

Appendix K Table 3 Psychological Interventions: Intervention Components

Appendix K Table 4 Psychological Interventions: Falls

Appendix K Table 5 Psychological Interventions: People With a Fall

Appendix K Table 6 Psychological Interventions: Injurious Falls

Appendix K Table 7 Psychological Interventions: Mortality

Appendix K Table 8 Psychological Interventions: IADLs