# Appendix J Medication Review/Modification Interventions: Additional Evidence Tables

Appendix J Table 1 Medication Review/Modification Interventions: Study & Participant Characteristics

Appendix J Table 2 Medication Review/Modification Interventions: Fall Risk and Comorbidities

Appendix J Table 3 Medication Review/Modification Interventions: Intervention Components

Appendix J Table 4 Medication Review/Modification Interventions: Falls

Appendix J Table 5 Medication Review/Modification Interventions: People With a Fall

Appendix J Table 6 Medication Review/Modification Interventions: Injurious Falls

Appendix J Table 7 Medication Review/Modification Interventions: People With a Fall Resulting in Medical Care, Hospitalization, or ED Visit

Appendix J Table 8 Medication Review/Modification Interventions: Mortality

Appendix J Table 9 Medication Review/Modification Interventions: Quality of Life