# Appendix I Environmental Interventions: Additional Evidence Tables

Appendix I Table 1 Environmental Interventions: Study and Population Characteristics

Appendix I Table 2 Environmental Interventions: Fall Risk and Comorbidities

Appendix I Table 3 Environmental Interventions: Intervention Components

Appendix I Table 4 Environmental Interventions: Falls

Appendix I Table 5 Environmental Interventions: People With a Fall

Appendix I Table 6 Environmental Interventions: Injurious Falls (Including Fracture) and Fall-Related Hospitalization

Appendix I Table 7 Environmental Interventions: People With a Fall Resulting in Injuries or Hospitalization

Appendix I Table 8 Environmental Interventions: Mortality

Appendix I Table 9 Environmental Interventions: Quality of Life

Appendix I Table 10 Environmental Interventions: IADLs