# Appendix H Exercise + Environment Interventions: Additional Evidence Tables

Appendix H Table 1 Exercise + Environment Interventions: Study and Population Characteristics

Appendix H Table 2 Exercise + Environment Interventions: Fall Risk and Comorbidities

Appendix H Table 3 Exercise + Environment Interventions: Intervention Components

Appendix H Table 4 Exercise + Environment Interventions: Falls

Appendix H Table 5 Exercise + Environment Interventions: People With a Fall

Appendix H Table 6 Exercise + Environment Interventions: Injurious Falls (Including Fracture) and Fall-Related Hospitalization

Appendix H Table 7 Exercise + Environment Interventions: People With a Fall Resulting in Injuries or Hospitalization

Appendix H Table 8 Exercise + Environment Interventions: Mortality

Appendix H Table 9 Exercise + Environment Interventions: Quality of Life