# Appendix G Exercise + Education Interventions: Additional Evidence Tables

Appendix G Table 1 Exercise + Education Interventions: Study and Population Characteristics

Appendix G Table 2 Exercise + Education Interventions: Fall Risk and Comorbidities

Appendix G Table 3 Exercise + Education Interventions: Intervention Components

Appendix G Table 4 Exercise + Education Interventions: Falls

Appendix G Table 5 Exercise + Education Interventions: People With a Fall

Appendix G Table 6 Exercise + Education Interventions: Injurious Falls (Including Fracture) and Fall-Related Hospitalization

Appendix G Table 7 Exercise + Education Interventions: Mortality

Appendix G Table 8 Exercise + Education Interventions: Quality of Life

Appendix G Table 9 Exercise + Education Interventions: Harms