# Appendix F Exercise Interventions: Additional Evidence Tables

Appendix F Table 1 Exercise Interventions: Study and Population Characteristics

Appendix F Table 2 Exercise Interventions: Fall Risk and Comorbidities

Appendix F Table 3 Exercise Interventions: Intervention Components

Appendix F Table 4 Exercise Interventions: Falls

Appendix F Table 5 Exercise Interventions: Falls, Exploring Heterogeneity

Appendix F Table 6 Exercise Interventions: People With a Fall

Appendix F Table 7 Exercise Interventions: People With a Fall, Exploring Heterogeneity

Appendix F Table 8 Exercise Interventions: Injurious Falls

Appendix F Table 9 Exercise Interventions: Fractures

Appendix F Table 10 Exercise Interventions: People With a Fall Resulting in Injuries or Medical Care

Appendix F Table 11 Exercise Interventions: People With a Fall-Related Fracture

Appendix F Table 12 Exercise Interventions: Mortality

Appendix F Table 13 Exercise Interventions: People With a Fall Resulting in Hospitalization/ED Visit or People With Institutionalization

Appendix F Table 14 Exercise Interventions: IADLs

Appendix F Table 15 Exercise Interventions: Quality of Life

Appendix F Table 16 Exercise Interventions: Harms