# Appendix E Multifactorial Interventions: Additional Evidence Tables

Appendix E Table 1 Multifactorial Interventions: Study and Population Characteristics

Appendix E Table 2 Multifactorial Interventions: Fall Risk and Comorbidities

Appendix E Table 3 Multifactorial Interventions: Intervention Components

Appendix E Table 4 Multifactorial Interventions: Falls

Appendix E Table 5 Multifactorial Interventions: Falls, Exploring Heterogeneity

Appendix E Table 6 Multifactorial Interventions: People With a Fall

Appendix E Table 7 Multifactorial Interventions: Injurious Falls

Appendix E Table 8 Multifactorial Interventions: Fractures

Appendix E Table 9 Multifactorial Interventions: People With a Fall Resulting in Injuries or Medical Care

Appendix E Table 10 Multifactorial Interventions: People With a Fall-Related Fracture

Appendix E Table 11 Multifactorial Interventions: Mortality

Appendix E Table 12 Multifactorial Interventions: People With a Fall Resulting in Hospitalization or ED Visit

Appendix E Table 13 Multifactorial Interventions: IADLs

Appendix E Table 14 Multifactorial Interventions: Quality of Life

Appendix E Table 15 Multifactorial Interventions: Harms