# Appendix D Excluded Studies

Reason for Exclusion^*^
E1. Aim/relevant
E1a. Falls prevention not primary or secondary aim
E2. Study design
E3. Setting
E3a. Not a very high HDI country
E3b. Not primary care referable/feasible (e.g., intervention setting not accessible to general population, pre-existing social ties)
E4. Population
E4a. Adults <65 years
E4b. Adults not representative of general primary care population (e.g., Parkinson’s, moderate to severe dementia, adults living in long-term care)
E5. No relevant outcomes
E5a. No additional relevant data (primary article included)
E5b. Only intermediate outcomes reported
E6. Intervention
E6a. <6 months followup
E6b. Comparative effectiveness trial
E6c. Not an included intervention type
E6d. Not minimal control group
E7. Publication
E7a. Publication type not included (correction, abstract)
E7b. Publication type not included (non-English)
E8. Full Text Unavailable
E9. Primary article excluded
E9a. Primary was poor quality
E10. Study quality

* Assigned at full-text phase

1 Adnan, M, Anjum, H, . Effectiveness of Physical Activity in Geriatric Population to Decrease the Risk of Fall a Randomized Control Trial. Pakistan journal of medical and health sciences. 16(12): 589–591. 2022. PMID: NONE.. 10.53350/pjmhs20221612589 KQ1E3a; KQ2E3a
2 Agarwal, G, Angeles, R, . Evaluation of a community paramedicine health promotion and lifestyle risk assessment program for older adults who live in social housing: a cluster randomized trial. CMAJ Canadian Medical Association Journal. 190(21): E638–E647. 2018. PMID: 29807936. 10.1503/cmaj.170740 KQ1E5; KQ2E529807936
3 Aibar-Almazan, A, Martinez-Amat, A, . Effects of Pilates on fall risk factors in community-dwelling elderly women: A randomized, controlled trial. European Journal of Sport Science EJSS : Official Journal of the European College of Sport Science. 19(10): 1386–1394. 2019. PMID: 30990762. 10.1080/17461391.2019.1595739 KQ1E5b; KQ2E5b30990762
4 Ailliaud, A, Moulis, É, . Assessment in the home of the elderly following a first fall with Samu intervention. Soins Gerontol. 27(153): 23–25. 2022. PMID: NONE. 10.1016/j.sger.2021.11.008 KQ1E7b; KQ2E7b
5 Alakare, Janne, Kemp, Kirsi, . Systematic geriatric assessment for older patients with frailty in the emergency department: a randomised controlled trial. BMC Geriatr. 21(1): 1–11. 2021. PMID: NONE. 10.1186/s12877-021-02351-2 KQ1E3; KQ2E333388045
6 Allison, SJ, Brooke-Wavell, K, . High and odd impact exercise training improved physical function and fall risk factors in community-dwelling older men. Journal of Musculoskeletal Neuronal Interactions. 18(1): 100–107. 2018. PMID: 29504585. KQ1E2; KQ2E229504585
7 Altamirano, Guerrero O, Balarezo, Garcia Mg, . Effectiveness of a preventive program for the reduction of falls in older adults. NeuroQuantology. 20(13): 287–292. 2022. KQ1E3a; KQ2E3a
8 Althomali, MM, Vallis, LA, . Can older adults’ balance and mobility improve with visual attention training?. Eur J Appl Physiol. 119(7): 1649–1661. 2019. PMID: 31055677. 10.1007/s00421-019-04153-2 KQ1E5; KQ2E531055677
9 Amaha, K, Arimoto, T. IFFAS-S13 03 Randomized control study of toe exercise for prevention from fall in elderly people. Foot Ankle Surg. 23(): 22-. 2017. PMID: NONE. 10.1016/j.fas.2017.07.1107 KQ1E7a; KQ2E7a
10 Anderson, ML, Allen, KD, . Fall Risk and Utilization of Balance Training for Adults With Symptomatic Knee Osteoarthritis: Secondary Analysis From a Randomized Clinical Trial. Journal of Geriatric Physical Therapy. 42(2): E39–E44. 2019. PMID: 30407270. 10.1519/JPT.0000000000000213 KQ1E5b; KQ2E5b30407270
11 Anonymous, . E-health StandingTall balance exercise for fall prevention in older people: results of a two year randomised controlled trial. BMJ. 374(): n1908. 2021. PMID: 34404632. 10.1136/bmj.n1908 KQ1E7a; KQ2E7a34404632
12 Ansai, JH, Aurichio, TR, . Effects of two physical exercise protocols on physical performance related to falls in the oldest old: A randomized controlled trial. Geriatr Gerontol Int. 16(4): 492–9. 2016. PMID: 25868484. 10.1111/ggi.12497 KQ1E3a; KQ2E3a25868484
13 Apostolo, J, Dixe, MDA, . Effectiveness of a Combined Intervention on Psychological and Physical Capacities of Frail Older Adults: A Cluster Randomized Controlled Trial. International Journal of Environmental Research & Public Health [Electronic Resource]. 16(17): 28. 2019. PMID: 31466229. 10.3390/ijerph16173125 KQ1E5; KQ2E531466229
14 Aranda-Reneo, I, Albornos-Munoz, L, . Cost-Effectiveness of an Exercise Programme That Provided Group or Individual Training to Reduce the Fall Risk in Healthy Community-Dwelling People Aged 65-80: A Secondary Data Analysis. Healthcare. 9(6): 10. 2021. PMID: 34200873. 10.3390/healthcare9060714 KQ1E6b; KQ2E6b34200873
15 Areeudomwong, P, Saysalum, S, . Balance and functional fitness benefits of a Thai boxing dance program among community-dwelling older adults at risk of falling: A randomized controlled study. Arch Gerontol Geriatr. 83(): 231–238. 2019. PMID: 31102925. 10.1016/j.archger.2019.04.010 KQ1E5; KQ2E531102925
16 Arena, SK, Wilson, CM, . Impact of the HOP-UP-PT program on older adults at risk to fall: a randomized controlled trial. BMC Geriatr. 21(1): 520. 2021. PMID: 34598692. 10.1186/s12877-021-02450-0 KQ1E10; KQ2E534598692
17 Arghavani, H, Zolaktaf, V, . Comparing the effects of anticipatory postural adjustments focused training and balance training on postural preparation, balance confidence and quality of life in elderly with history of a fall. Aging-Clinical & Experimental Research. 32(9): 1757–1765. 2020. PMID: 31608424. 10.1007/s40520-019-01358-5 KQ1E5; KQ2E531608424
18 Arkkukangas, M, Stromqvist Baathe, K, . High Challenge Exercise and Learning Safe Landing Strategies among Community-Dwelling Older Adults: A Randomized Controlled Trial. International Journal of Environmental Research & Public Health [Electronic Resource]. 19(12): 16. 2022. PMID: 35742618. 10.3390/ijerph19127370 KQ1E5b; KQ2E5b35742618
19 Arnold, CM, Faulkner, RA. The effect of aquatic exercise and education on lowering fall risk in older adults with hip osteoarthritis [corrected] [published erratum appears in J AGING PHYS ACTIVITY 2010 Oct;18(4):477-479]. J Aging Phys Act. 18(3): 245–260. 2010. PMID: NONE. KQ1E5; KQ2E520651413
20 Barker, A, Cameron, P, . Evaluation of RESPOND, a patient-centred program to prevent falls in older people presenting to the emergency department with a fall: A randomised controlled trial. PLoS Medicine / Public Library of Science. 16(5): e1002807. 2019. PMID: 31125354. 10.1371/journal.pmed.1002807 KQ1E6d; KQ2E6d31125354
21 Barker, AL, Cameron, PA, . RESPOND--A patient-centred programme to prevent secondary falls in older people presenting to the emergency department with a fall: protocol for a multicentre randomised controlled trial. Inj Prev. 21(1): e1. 2015. PMID: 24958769. 10.1136/injuryprev-2014-041271 KQ1E9; KQ2E924958769
22 Barker, AL, Talevski, J, . Feasibility of Pilates exercise to decrease falls risk: a pilot randomized controlled trial in community-dwelling older people. Clin Rehabil. 30(10): 984–996. 2016. PMID: 26385357. KQ1E6d; KQ2E6d26385357
23 Bayliss, EA, Shetterly, SM, . The OPTIMIZE patient- and family-centered, primary care-based deprescribing intervention for older adults with dementia or mild cognitive impairment and multiple chronic conditions: study protocol for a pragmatic cluster randomized controlled trial. Trials [Electronic Resource]. 21(1): 542. 2020. PMID: 32552857. 10.1186/s13063-020-04482-0 KQ1E5; KQ2E532552857
24 Belleville, S, Cuesta, M, . Rationale and protocol of the StayFitLonger study: a multicentre trial to measure efficacy and adherence of a home-based computerised multidomain intervention in healthy older adults. BMC Geriatr. 20(1): 315. 2020. PMID: 32859156. 10.1186/s12877-020-01709-2 KQ1E5; KQ2E532859156
25 Bellumori, Maria, Uygur, Mehmet, . High-Speed Cycling Intervention Improves Rate-Dependent Mobility in Older Adults. Med Sci Sports Exerc. 49(1): 106–114. 2017. PMID: NONE. 10.1249/MSS.0000000000001069 KQ1E5b; KQ2E5b27501360
26 Benavent-Caballer, V, Rosado-Calatayud, P, . The effectiveness of a video-supported group-based Otago exercise programme on physical performance in community-dwelling older adults: a preliminary study. Physiotherapy. 102(3): 280–6. 2016. PMID: 26395209. 10.1016/j.physio.2015.08.002 KQ1E5; KQ2E526395209
27 Bernabei, R, Landi, F, . Multicomponent intervention to prevent mobility disability in frail older adults: randomised controlled trial (SPRINTT project). BMJ. 377(): e068788. 2022. PMID: 35545258. 10.1136/bmj-2021-068788 KQ1E6c; KQ2E6c35545258
28 Bernardelli, G, Roncaglione, C, . Adapted physical activity to promote active and healthy ageing: the PoliFIT pilot randomized waiting list-controlled trial. Aging-Clinical & Experimental Research. 31(4): 511–518. 2019. PMID: 30019265. 10.1007/s40520-018-1002-1 KQ1E6a; KQ2E6a30019265
29 Birimoglu, Okuyan C, Bilgili, N. Effect of tai chi chuan on fear of falling, balance and physical self-perception in elderly: a randomised controlled trial. Turk geriatri dergisi. 20(3): 232–241. 2017. PMID: NONE. KQ1E4b; KQ2E4b
30 Bischoff-Ferrari, HA, de Godoi Rezende Costa Molino, C, . DO-HEALTH: Vitamin D3 - Omega-3 - Home exercise - Healthy aging and longevity trial - Design of a multinational clinical trial on healthy aging among European seniors. Contemp Clin Trials. 100(): 106124. 2021. PMID: 32858228. 10.1016/j.cct.2020.106124 KQ1E9; KQ2E932858228
31 Bischoff-Ferrari, HA, Freystatter, G, . Effects of vitamin D, omega-3 fatty acids and a simple home strength exercise program on fall prevention: the DO-HEALTH randomized clinical trial. Am J Clin Nutr. 07(): 07. 2022. PMID: 35136915. 10.1093/ajcn/nqac022 KQ1E6d; KQ2E6d35136915
32 Bischoff-Ferrari, HA, Orav, EJ, . Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Arch Intern Med. 166(4): 424–430. 2006. PMID: 16505262. 10.1001/archinte.166.4.424 KQ1E6c; KQ2E6c16505262
33 Bjerk, M, Brovold, T, . A falls prevention programme to improve quality of life, physical function and falls efficacy in older people receiving home help services: study protocol for a randomised controlled trial. BMC Health Serv Res. 17(1): 559. 2017. PMID: 28806904. 10.1186/s12913-017-2516-5 KQ1E6a; KQ2E528806904
34 Bjerk, M, Brovold, T, . Effects of a falls prevention exercise programme on health-related quality of life in older home care recipients: a randomised controlled trial. Age Ageing. 48(2): 213–219. 2019. PMID: 30615055. 10.1093/ageing/afy192 KQ1E6a; KQ2E6a30615055
35 Bjerk, M, Brovold, T, . Effects of a falls prevention programme on health-related quality of life in older home care recipients: a randomised controlled trial. Eur Geriatr Med. 9(): S169-. 2018. PMID: NONE. 10.1007/s41999-018-0097-4 KQ1E7a; KQ2E7a
36 Bjerk, M, Brovold, T, . Evaluating a falls prevention intervention in older home care recipients: a comparison of SF-6D and EQ-5D. Qual Life Res. 28(12): 3187–3195. 2019. PMID: 31364036. 10.1007/s11136-019-02258-x KQ1E2; KQ2E231364036
37 Bjerk, M, Brovold, T, . Health-related quality of life in home care recipients after a falls prevention intervention: a 6-month follow-up. Eur J Public Health. 30(1): 64–69. 2020. PMID: 31169888. 10.1093/eurpub/ckz106 KQ1E6a; KQ2E531169888
38 Blancafort Alias, S, Cuevas-Lara, C, . A Multi-Domain Group-Based Intervention to Promote Physical Activity, Healthy Nutrition, and Psychological Wellbeing in Older People with Losses in Intrinsic Capacity: AMICOPE Development Study. International Journal of Environmental Research & Public Health [Electronic Resource]. 18(11): 02. 2021. PMID: 34199566. 10.3390/ijerph18115979 KQ1E5; KQ2E534199566
39 Blalock, SJ, Ferreri, SP, . Impact of STEADI-Rx: A Community Pharmacy-Based Fall Prevention Intervention. J Am Geriatr Soc. 68(8): 1778–1786. 2020. PMID: 32315461. 10.1111/jgs.16459 KQ1E10; KQ2E532315461
40 Bohm, S, Mandla-Liebsch, M, . Exercise of Dynamic Stability in the Presence of Perturbations Elicit Fast Improvements of Simulated Fall Recovery and Strength in Older Adults: A Randomized Controlled Trial. Frontiers in Sports & Active Living. 2(): 52. 2020. PMID: 33345043. 10.3389/fspor.2020.00052 KQ1E5; KQ2E533345043
41 Bolton, KL, Egerton, T, . Effects of exercise on bone density and falls risk factors in post-menopausal women with osteopenia: a randomised controlled trial. Journal of Science & Medicine in Sport. 15(2): 102–9. 2012. PMID: NONE. 10.1016/j.jsams.2011.08.007 KQ1E4a; KQ2E4a21996058
42 Boongird, C, Keesukphan, P, . Effects of a simple home-based exercise program on fall prevention in older adults: A 12-month primary care setting, randomized controlled trial. Geriatr Gerontol Int. 17(11): 2157–2163. 2017. PMID: 28436154. 10.1111/ggi.13052 KQ1E3a; KQ2E3a28436154
43 Bouzid, W, Tavassoli, N, . Impact of a personalised care plan for the elderly calling emergency medical services after a fall at home: The RISING-DOM multi-centre randomised controlled trial protocol. BMC Geriatr. 22(1): 182. 2022. PMID: 35246053. 10.1186/s12877-022-02850-w KQ1E6a; KQ2E6a35246053
44 Braghin, RMB, Libardi, EC, . Exercise on balance and function for knee osteoarthritis: A randomized controlled trial. J Bodyw Mov Ther. 22(1): 76–82. 2018. PMID: 29332761. 10.1016/j.jbmt.2017.04.006 KQ1E3a; KQ2E3a29332761
45 Breysse, Jill, Dixon, Sherry, . Aging Gracefully in Place: An Evaluation of the Capability of the CAPABLE © Approach. J Appl Gerontol. 41(3): 718–728. 2022. PMID: None. 10.1177/07334648211042606 KQ1E10; KQ2E534474609
46 Brown, JD, Smith, SM, . Comparative Effects of Angiotensin-Converting Enzyme Inhibitors and Angiotensin Receptor Blockers on Response to a Physical Activity Intervention in Older Adults: Results From the Lifestyle Interventions and Independence for Elders Study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 75(5): 1010–1016. 2020. PMID: 31070702. 10.1093/gerona/glz120 KQ1E4b; KQ2E4b31070702
47 Burke, Thomaz Nogueira, França, Fábio Jorge Renovato, . Postural control in elderly women with osteoporosis: comparison of balance, strengthening and stretching exercises. A randomized controlled trial. Clin Rehabil. 26(11): 1021–1031. 2012. PMID: None. 10.1177/0269215512442204 KQ1E3a; KQ2E3a22498664
48 Burton, E, Hill, K, . Balance on the Brain: a randomised controlled trial evaluating the effect of a multimodal exercise programme on physical performance, falls, quality of life and cognition for people with mild cognitive impairment-study protocol. BMJ Open. 12(4): e054725. 2022. PMID: 35437246. 10.1136/bmjopen-2021-054725 KQ1E5; KQ2E535437246
49 Bustamante-Troncoso, C, Herrera-López, Lm, . Effect of a multidimensional intervention for prevention of falls in the eldery. Aten Primaria. 52(10): 722–730. 2020. PMID: None. 10.1016/j.aprim.2019.07.018 KQ1E7b; KQ2E7b31740074
50 Carta, MG, Cossu, G, . Active elderly and health-can moderate exercise improve health and wellbeing in older adults? Protocol for a randomized controlled trial. Trials [Electronic Resource]. 22(1): 331. 2021. PMID: 33962664. 10.1186/s13063-021-05278-6 KQ1E5; KQ2E533962664
51 Casas-Herrero, A, Anton-Rodrigo, I, . Effect of a multicomponent exercise programme (VIVIFRAIL) on functional capacity in frail community elders with cognitive decline: study protocol for a randomized multicentre control trial. Trials [Electronic Resource]. 20(1): 362. 2019. PMID: 31208471. 10.1186/s13063-019-3426-0 KQ1E9; KQ2E931208471
52 Casas-Herrero, A, Saez de Asteasu, ML, . Effects of Vivifrail multicomponent intervention on functional capacity: a multicentre, randomized controlled trial. J Cachexia Sarcopenia Muscle. 13(2): 884–893. 2022. PMID: 35150086. 10.1002/jcsm.12925 KQ1E6a; KQ2E6a35150086
53 Cezar, NOC, Ansai, JH, . Feasibility of improving strength and functioning and decreasing the risk of falls in older adults with Alzheimer’s dementia: a randomized controlled home-based exercise trial. Arch Gerontol Geriatr. 96(): 104476. 2021. PMID: 34260986. 10.1016/j.archger.2021.104476 KQ1E3a; KQ2E3a34260986
54 Chittrakul, J, Siviroj, P, . Multi-System Physical Exercise Intervention for Fall Prevention and Quality of Life in Pre-Frail Older Adults: A Randomized Controlled Trial. Int J Environ Res Public Health. 17(9): . 2020. PMID: 32365613. 10.3390/ijerph17093102 KQ1E3a; KQ2E3a32365613
55 Clemson, L, Mackenzie, L, . Integrated solutions for sustainable fall prevention in primary care, the iSOLVE project: a type 2 hybrid effectiveness-implementation design. Implementation Science. 12(1): 12. 2017. PMID: 28173827. 10.1186/s13012-016-0529-9 KQ1E5; KQ2E528173827
56 Conneely, M, Leahy, A, . A physiotherapy-led transition to home intervention for older adults following emergency department discharge: protocol for a pilot feasibility randomised controlled trial. Pilot & Feasibility Studies. 8(1): 3. 2022. PMID: 34980285. 10.1186/s40814-021-00954-5 KQ1E6a; KQ2E6a34980285
57 Conradsson, D, Halvarsson, A. The effects of dual-task balance training on gait in older women with osteoporosis: A randomized controlled trial. Gait Posture. 68(): 562–568. 2019. PMID: 30640156. 10.1016/j.gaitpost.2019.01.005 KQ1E5b; KQ2E5b30640156
58 Costa, JNA, Ribeiro, ALA, . Balance Exercise Circuit for fall prevention in older adults: a randomized controlled crossover trial. Journal of Frailty Sarcopenia & Falls. 7(2): 60–71. 2022. PMID: 35775091. 10.22540/JFSF-07-060 KQ1E3a; KQ2E3a35775091
59 Davis, JC, Hsu, CL, . Baseline health-related quality of life predicts falls: a secondary analysis of a randomized controlled trial. Qual Life Res. 31(11): 3211–3220. 2022. PMID: 35798988. 10.1007/s11136-022-03175-2 KQ1E9; KQ2E935798988
60 Davis, JC, Hsu, CL, . Comparing the cost-effectiveness of the Otago Exercise Programme among older women and men: A secondary analysis of a randomized controlled trial. PLoS ONE [Electronic Resource]. 17(4): e0267247. 2022. PMID: 35442974. 10.1371/journal.pone.0267247 KQ1E9; KQ2E935442974
61 Davis, JC, Khan, KM, . Action Seniors! Cost-Effectiveness Analysis of a Secondary Falls Prevention Strategy Among Community-Dwelling Older Fallers. J Am Geriatr Soc. 68(9): 1988–1997. 2020. PMID: 32472567. 10.1111/jgs.16476 KQ1E9; KQ2E932472567
62 Dawson-Hughes, B, Harris, SS, . Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. 337(10): 670–676. 1997. PMID: 9278463. 10.1056/NEJM199709043371003 KQ1E6c; KQ2E6c9278463
63 Dedeyne, L, Dupont, J, . The exercise and nutrition for healthy ageing (ENHANCE) project: protocol of a triple blinded, randomized controlled trial. Osteoporos Int. 30(Suppl 2): S538-. 2019. PMID: NONE. 10.1007/s00198-019-04993-w KQ1E9; KQ2E9
64 Deepeshwar, S, Tanwar, M, . Effect of Yoga Based Lifestyle Intervention on Patients With Knee Osteoarthritis: A Randomized Controlled Trial. Frontiers in psychiatry Frontiers Research Foundation. 9(): 180. 2018. PMID: 29867604. 10.3389/fpsyt.2018.00180 KQ1E4a; KQ2E4a29867604
65 Desborough, JA, Clark, A, . Clinical and cost effectiveness of a multi-professional medication reviews in care homes (CAREMED). International Journal of Pharmacy Practice. 28(6): 626–634. 2020. PMID: 32666576. 10.1111/ijpp.12656 KQ1E4b; KQ2E532666576
66 DeWalt, NC, Stahorsky, KA, . Simulation Versus Written Fall Prevention Education in Older Hospitalized Adults: A Randomized Controlled Study. Clin Nurs Res. (): 10547738221082192. 2022. PMID: 35291853. 10.1177/10547738221082192 KQ1E3; KQ2E335291853
67 Dispennette, AK, Schafer, MA, . Effects of a Game-Centered Health Promotion Program on Fall Risk, Health Knowledge, and Quality of Life in Community-Dwelling Older Adults. Int J Exerc Sci. 12(4): 1149–1160. 2019. PMID: 31839849. KQ1E5b; KQ2E5b31839849
68 Dizdar, M, Irdesel, JF, . Effects of Balance-Coordination, Strengthening, and Aerobic Exercises to Prevent Falls in Postmenopausal Patients With Osteoporosis: A 6-Month Randomized Parallel Prospective Study. J Aging Phys Act. 26(1): 41–51. 2018. PMID: 28422544. 10.1123/japa.2016-0284 KQ1E6b; KQ2E6b28422544
69 Dohrn, IM, Hagstromer, M, . Short- and Long-Term Effects of Balance Training on Physical Activity in Older Adults With Osteoporosis: A Randomized Controlled Trial. Journal of Geriatric Physical Therapy. 40(2): 102–111. 2017. PMID: 26859463. 10.1519/JPT.0000000000000077 KQ1E5b; KQ2E5b26859463
70 Donatoni, da Silva L, Shiel, A, . Effects of Pilates on the risk of falls, gait, balance and functional mobility in healthy older adults: a randomised controlled trial. J Bodyw Mov Ther. 30(): 30–41. 2022. PMID: NONE. 10.1016/j.jbmt.2022.02.020 KQ1E5b; KQ2E5b35500977
71 Duckham, RL, Masud, T, . Randomised controlled trial of the effectiveness of community group and home-based falls prevention exercise programmes on bone health in older people: the ProAct≥65 bone study. Age Ageing. 44(4): 573–9. 2015. PMID: 25906791. 10.1093/ageing/afv055 KQ1E5; KQ2E525906791
72 Dukas, L, Bischoff, HA, . Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. J Am Geriatr Soc. 52(2): 230–236. 2004. PMID: 14728632. KQ1E6c; KQ2E6c14728632
73 Evers, Smaa, Dorresteijn, TAC, . Economic evaluation of a home-based programme to reduce concerns about falls in frail, independently-living older people. Expert Rev Pharmacoecon Outcomes Res. 20(6): 641–651. 2020. PMID: 31502897. 10.1080/14737167.2019.1666714 KQ1E5a; KQ2E5a31502897
74 Fahlstrom, G, Kamwendo, K, . Fall prevention by nursing assistants among community-living elderly people. A randomised controlled trial. Scand J Caring Sci. 32(2): 575–585. 2018. PMID: 28851132. 10.1111/scs.12481 KQ1E10; KQ2E528851132
75 Ferreira, A, Chaves, P, . The effect of a fall prevention exercise programme on fear of falling in the elderly. Eur Geriatr Med. 7(): S189-. 2016. PMID: NONE. KQ1E7a; KQ2E7a
76 Fielding, RA, Rejeski, WJ, . The Lifestyle Interventions and Independence for Elders Study: design and methods. J Gerontol A Biol Sci Med Sci. 66(11): 1226–37. 2011. PMID: 21825283. 10.1093/gerona/glr123 KQ1E9; KQ2E921825283
77 Finnegan, S, Bruce, J, . Life after falls prevention exercise - experiences of older people taking part in a clinical trial: a phenomenological study. BMC Geriatr. 21(1): 91. 2021. PMID: 33517904. 10.1186/s12877-021-02037-9 KQ1E2; KQ2E233517904
78 Fischbacher, M, Chocano-Bedoya, PO, . Safety and feasibility of a Dalcroze eurhythmics and a simple home exercise program among older adults with mild cognitive impairment (MCI) or mild dementia: the MOVE for your MIND pilot trial. Pilot & Feasibility Studies. 6(): 101. 2020. PMID: 32695433. 10.1186/s40814-020-00645-7 KQ1E10; KQ1E1032695433
79 Franco-Garcia, JM, Carlos-Vivas, J, . Effects of 6-Month Square Stepping Exercise Intervention on Physical and Cognitive Competence, Regucalcin, and Body Composition in Older People: Study Protocol for a Randomised Control Trial. International Journal of Environmental Research & Public Health [Electronic Resource]. 19(5): 06. 2022. PMID: 35270778. 10.3390/ijerph19053086 KQ1E6a; KQ2E6a35270778
80 Freiberger, E, Haberle, L, . Long-term effects of three multicomponent exercise interventions on physical performance and fall-related psychological outcomes in community-dwelling older adults: a randomized controlled trial. J Am Geriatr Soc. 60(3): 437–46. 2012. PMID: 22324753. 10.1111/j.1532-5415.2011.03859.x KQ1E2; KQ2E522324753
81 Fujita, K, Umegaki, H, . Short- and long-term effects of different exercise programs on the gait performance of older adults with subjective cognitive decline: A randomized controlled trial. Exp Gerontol. 156(): 111590. 2021. PMID: 34648847. 10.1016/j.exger.2021.111590 KQ1E5; KQ2E534648847
82 Gallagher, JC, Fowler, SE, . Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 86(8): 3618–3628. 2001. PMID: 11502787. 10.1210/jcem.86.8.7703 KQ1E6c; KQ2E6c11502787
83 Gallagher, JC, Rapuri, PB, . An age-related decrease in creatinine clearance is associated with an increase in number of falls in untreated women but not in women receiving calcitriol treatment. J Clin Endocrinol Metab. 92(1): 51–8. 2007. PMID: 17032712. 10.1210/jc.2006-1153 KQ1E6c; KQ2E6c17032712
84 Gawler, S, Skelton, DA, . Reducing falls among older people in general practice: The ProAct≥65 exercise intervention trial. Arch Gerontol Geriatr. 67(): 46–54. 2016. PMID: 27420150. 10.1016/j.archger.2016.06.019 KQ1E10; KQ2E527420150
85 Gill, TM, McGloin, JM, . Optimizing Retention in a Pragmatic Trial of Community-Living Older Persons: The STRIDE Study. J Am Geriatr Soc. 68(6): 1242–1249. 2020. PMID: 32212395. 10.1111/jgs.16356 KQ1E5; KQ2E532212395
86 Gill, TM, Pahor, M, . Effect of structured physical activity on prevention of serious fall injuries in adults aged 70-89: randomized clinical trial (LIFE Study). BMJ. 352(): i245. 2016. PMID: 26842425. 10.1136/bmj.i245 KQ1E6d; KQ2E6d26842425
87 Glendenning, P, Zhu, K, . Effects of three-monthly oral 150,000 IU cholecalciferol supplementation on falls, mobility, and muscle strength in older postmenopausal women: a randomized controlled trial. J Bone Miner Res. 27(1): 170–6. 2012. PMID: 21956713. 10.1002/jbmr.524 KQ1E6c; KQ2E6c21956713
88 Glickman-Simon, R. Home-based Tai Chi Chuan May Reduce Fall Rate Compared to Lower Extremity Exercise Training in Older Adults with History of Falls. Explore: the journal of science and healing. 13(1): 79–80. 2017. PMID: NONE. 10.1016/j.explore.2016.10.015 KQ1E7a; KQ2E7a27988242
89 Goldberg, Em, Marks, Sj, . 4EMF A Pilot Randomized Controlled Trial of GAPcare: the Geriatric Acute and Postacute Fall Prevention Intervention: feasibility and Acceptability. Ann Emerg Med. 74(4): S152-. 2019. PMID: NONE. 10.1016/j.annemergmed.2019.08.350 KQ1E7a; KQ2E7a
90 Goldberg, EM, Marks, SJ, . GAPcare: The Geriatric Acute and Post-Acute Fall Prevention Intervention in the Emergency Department: Preliminary Data. J Am Geriatr Soc. 68(1): 198–206. 2020. PMID: 31621901. 10.1111/jgs.16210 KQ1E3; KQ2E331621901
91 Goldberg, Em, Resnik, L, . Feasibility and initial efficacy of gapcare: the geriatric acute and post-acute care coordination fall prevention program. Acad Emerg Med. 26(): S125-. 2019. PMID: NONE. 10.1111/acem.13756 KQ1E7a; KQ2E7a
92 Goldberg, EM, Resnik, L, . GAPcare: the Geriatric Acute and Post-acute Fall Prevention Intervention-a pilot investigation of an emergency department-based fall prevention program for community-dwelling older adults. Pilot & Feasibility Studies. 5(): 106. 2019. PMID: 31463079. 10.1186/s40814-019-0491-9 KQ1E9; KQ2E931463079
93 Gomes, GCV, Simoes, MDS, . Feasibility, safety, acceptability, and functional outcomes of playing Nintendo Wii Fit PlusTM for frail older adults: A randomized feasibility clinical trial. Maturitas. 118(): 20–28. 2018. PMID: 30415751. 10.1016/j.maturitas.2018.10.002 KQ1E3a; KQ2E3a30415751
94 Gouveia, BR, Goncalves Jardim, H, . An evaluation of a nurse-led rehabilitation programme (the ProBalance Programme) to improve balance and reduce fall risk of community-dwelling older people: A randomised controlled trial. Int J Nurs Stud. 56(): 1–8. 2016. PMID: 26742607. 10.1016/j.ijnurstu.2015.12.004 KQ1E5b; KQ2E5b26742607
95 Granacher, U, Muehlbauer, T, . The performance of balance exercises during daily tooth brushing is not sufficient to improve balance and muscle strength in healthy older adults. BMC Geriatr. 21(1): 257. 2021. PMID: 33865308. 10.1186/s12877-021-02206-w KQ1E5; KQ2E533865308
96 Granbom, M, Clemson, L, . Preventing falls among older fallers: study protocol for a two-phase pilot study of the multicomponent LIVE LiFE program. Trials [Electronic Resource]. 20(1): 2. 2019. PMID: 30606239. 10.1186/s13063-018-3114-5 KQ1E9; KQ2E930606239
97 Greenberg, MR, Goodheart, V, . Emergency Department Stopping Elderly Accidents, Deaths and Injuries (ED STEADI) Program. J Emerg Med. 59(1): 1–11. 2020. PMID: 32389434. 10.1016/j.jemermed.2020.04.019 KQ1E3; KQ2E332389434
98 Griffin, J, Withers, Ej, . Comparison and impact of prospective and retrospective falls data completion methods in the prefit trial: results of a randomised methodology study within a trial (SWAT). Trials. 18(): . 2017. PMID: NONE. 10.1186/s13063-017-1902-y KQ1E7a; KQ2E7a
99 Gustafson, DH, Sr, Kornfield, . Effect of an eHealth intervention on older adults’ quality of life and health-related outcomes: a randomized clinical trial. J Gen Intern Med. 37(3): 521–530. 2022. PMID: 34100234. 10.1007/s11606-021-06888-1 KQ1E5; KQ2E534100234
100 Haas, M. Economic analysis of tai chi AS a means of preventing falls and related injuries among older adults. CHERE working paper 2006/4. Centre for Health Economics Research and Evaluation. Faculty of Business, University of Technology, Sydney. https://www.uts.edu.au/sites/default/files/wp2006_3.pdf. (): . 2019. PMID: NONE. KQ1E6a; KQ2E6a
101 Hagovska, M, Olekszyova, Z. Impact of the combination of cognitive and balance training on gait, fear and risk of falling and quality of life in seniors with mild cognitive impairment. Geriatr Gerontol Int. 16(9): 1043–50. 2016. PMID: 26338465. 10.1111/ggi.12593 KQ1E6c; KQ2E6c26338465
102 Halvarsson, A, Oddsson, L, . Long-term effects of a progressive and specific balance-training programme with multi-task exercises for older adults with osteoporosis: a randomized controlled study. Clin Rehabil. 30(11): 1049–1059. 2016. PMID: 26396164. 10.1177/0269215515605553 KQ1E10; KQ2E526396164
103 Hamrick, I, Mross, P, . Yoga’s effect on falls in rural, older adults. Complement Ther Med. 35(): 57–63. 2017. PMID: 29154068. 10.1016/j.ctim.2017.09.007 KQ1E6d; KQ2E6d29154068
104 Harper, KJ, Barton, AD, . Controlled clinical trial exploring the impact of a brief intervention for prevention of falls in an emergency department. Emergency Medicine Australasia. 29(5): 524–530. 2017. PMID: 28544279. 10.1111/1742-6723.12804 KQ1E3; KQ2E328544279
105 Harper, Kristie J, Barton, Annette D, . Risk assessment and the impact of point of contact intervention following emergency department presentation with a fall. Phys Occup Ther Geriatr. 35(3–4): 182–194. 2017. PMID: None. 10.1080/02703181.2017.1300620 KQ1E6a; KQ2E5
106 Harris, T, Limb, ES, . Effect of pedometer-based walking interventions on long-term health outcomes: Prospective 4-year follow-up of two randomised controlled trials using routine primary care data. PLoS Medicine / Public Library of Science. 16(6): e1002836. 2019. PMID: 31237875. 10.1371/journal.pmed.1002836 KQ1E1a; KQ2E1a31237875
107 Hawley-Hague, H, Tacconi, C, . Using smartphone TechnolOGy to support an EffecTive Home ExeRcise intervention to prevent falls amongst community dwelling older adults The TOGETHER feasibility RCT. Gerontology. 05(): 05. 2022. PMID: 36470216. 10.1159/000528471 KQ1E6d; KQ2E6d36470216
108 Haynes, A, Naylor, LH, . Land-walking vs. water-walking interventions in older adults: Effects on aerobic fitness. Journal of Sport & Health Science. 9(3): 274–282. 2020. PMID: 32444152. 10.1016/j.jshs.2019.11.005 KQ1E4a; KQ2E4a32444152
109 Hill, K, Barker, A, . Responding to the first fall to prevent the second: successful RCT in reducing falls using a person centred approach for older fallers presenting to emergency departments. Age Ageing. 48(2): iv18-. 2019. PMID: NONE. 10.1093/ageing/afz164.106 KQ1E7a; KQ2E7a
110 Hinrichs, T, Bucker, B, . Home-Based Exercise Supported by General Practitioner Practices: Ineffective in a Sample of Chronically Ill, Mobility-Limited Older Adults (the HOMEfit Randomized Controlled Trial). J Am Geriatr Soc. 64(11): 2270–2279. 2016. PMID: 27676362. 10.1111/jgs.14392 KQ1E5; KQ2E527676362
111 Hofgaard, J, Ermidis, G, . Effects of a 6-Week Faroese Chain Dance Programme on Postural Balance, Physical Function, and Health Profile in Elderly Subjects: A Pilot Study. Biomed Res Int. 2019(): 5392970. 2019. PMID: 31392213. 10.1155/2019/5392970 KQ1E5; KQ2E531392213
112 Hong, J, Kong, HJ, . Web-Based Telepresence Exercise Program for Community-Dwelling Elderly Women With a High Risk of Falling: Randomized Controlled Trial. JMIR MHealth and UHealth. 6(5): e132. 2018. PMID: 29807877. 10.2196/mhealth.9563 KQ1E5b; KQ2E5b29807877
113 Hosseini, L, Kargozar, E, . Tai Chi Chuan can improve balance and reduce fear of falling in community dwelling older adults: a randomized control trial. Journal of Exercise Rehabilitation. 14(6): 1024–1031. 2018. PMID: 30656165. 10.12965/jer.1836488.244 KQ1E3a; KQ2E3a30656165
114 Huang, N, Li, W, . Effects of a Modified Tai Chi Program on Older People with Mild Dementia: A Randomized Controlled Trial. J Alzheimers Dis. 72(3): 947–956. 2019. PMID: 31743998. 10.3233/JAD-190487 KQ1E3a; KQ2E3a31743998
115 Hung, WilliamW. Fall Injury Among Community-Dwelling Older Adults: Effect of a Multifactorial Intervention and a Home Hazard Removal Program. Journal of Clinical Outcomes Management. 29(3): 102–105. 2022. PMID: . 10.12788/jcom.0096 KQ1E2; KQ2E2
116 Iliffe, S, Kendrick, D, . Multicentre cluster randomised trial comparing a community group exercise programme and home-based exercise with usual care for people aged 65 years and over in primary care. Health Technol Assess. 18(49): vii–xxvii, 1–105. 2014. PMID: 25098959. 10.3310/hta18490 KQ1E9a; KQ2E9a25098959
117 Iliffe, S, Kendrick, D, . Multi-centre cluster randomised trial comparing a community group exercise programme with home based exercise with usual care for people aged 65 and over in primary care: protocol of the ProAct ≥65 trial. Trials. 11(): 6. 2010. PMID: 20082696. 10.1186/1745-6215-11-6 KQ1E9a; KQ2E9a20082696
118 Jagdhane, S, Kanekar, N, . The Effect of a Four-Week Balance Training Program on Anticipatory Postural Adjustments in Older Adults: A Pilot Feasibility Study. Curr Aging Sci. 9(4): 295–300. 2016. PMID: 27071477. KQ1E7b; KQ2E7b27071477
119 Jansen, CP, Nerz, C, . Lifestyle-integrated functional exercise to prevent falls and promote physical activity: Results from the LiFE-is-LiFE randomized non-inferiority trial. International Journal of Behavioral Nutrition & Physical Activity. 18(1): 115. 2021. PMID: 34479573. 10.1186/s12966-021-01190-z KQ1E6b; KQ2E6b34479573
120 Johansson, Erika, Jonsson, Hans, . The efficacy of a multifactorial falls-prevention programme, implemented in primary health care. British journal of occupational therapy. 81(8): 474–481. 2018. PMID: None. 10.1177/0308022618756303 KQ1E10; KQ2E5
121 Johnson, Shanthi, McLeod, Bill, . Impact of a home-based nutrition and exercise intervention in improving functional capacity associated with falls among rural seniors in Canada. Quality in Ageing & Older Adults. 19(4): 261–272. 2018. PMID: NONE. 10.1108/QAOA-11-2017-0044 KQ1E5b; KQ2E5b
122 Jun, Dai, Saleheen, Sibgat, . Video-based fall prevention education for cognitively impaired inpatients: a pilot study. Asian Journal of Gerontology & Geriatrics. 17(1): 11–16. 2022. 10.12809/ajgg-2021-490-oa KQ1E4b; KQ2E4b
123 Kamide, N, Shiba, Y, . Effects on balance, falls, and bone mineral density of a home-based exercise program without home visits in community-dwelling elderly women: a randomized controlled trial. J Physiol Anthropol. 28(3): 115–22. 2009. PMID: 19483372. KQ1E2; KQ2E519483372
124 Karinkanta, S, Heinonen, A, . Maintenance of exercise-induced benefits in physical functioning and bone among elderly women. Osteoporos Int. 20(4): 665–74. 2009. PMID: 18696173. 10.1007/s00198-008-0703-2 KQ1E5a; KQ2E5a18696173
125 Kazar-Toth, K, Karoczi, Ck, . HPR efficacy of different types of exercise programs in osteoporosis with high risk of falls. Ann Rheum Dis. 76(): 1482-. 2017. PMID: NONE. 10.1136/annrheumdis-2017-eular.3783 KQ1E7a; KQ2E7a
126 Keall, MD, Pierse, N, . Cost-benefit analysis of fall injuries prevented by a programme of home modifications: a cluster randomised controlled trial. Injury Prevention. 23(1): 22–26. 2017. PMID: 27312961. 10.1136/injuryprev-2015-041947 KQ1E5; KQ2E527312961
127 Keall, MD, Pierse, N, . Home modifications to reduce injuries from falls in the home injury prevention intervention (HIPI) study: a cluster-randomised controlled trial. Lancet. 385(9964): 231–8. 2015. PMID: 25255696. 10.1016/S0140-6736(14)61006-0 KQ1E4a; KQ2E525255696
128 Keall, MD, Tupara, H, . Home modifications to prevent home fall injuries in houses with Maori occupants (MHIPI): a randomised controlled trial. The lancet. Public Health. 6(9): e631–e640. 2021. PMID: 34371005. 10.1016/S2468-2667(21)00135-3 KQ1E4a; KQ2E534371005
129 Kemmler, W, Stengel S V, Mayer, . [Effect of whole body vibration on the neuromuscular performance of females 65 years and older. One-year results of the controlled randomized ELVIS study]. Z Gerontol Geriatr. 43(2): 125–32. 2010. PMID: NONE. 10.1007/s00391-009-0074-0 KQ1E7b; KQ2E7b19789832
130 Kienle, GS, Werthmann, PG, . A multi-centre, parallel-group, randomised controlled trial to assess the efficacy and safety of eurythmy therapy and tai chi in comparison with standard care in chronically ill elderly patients with increased risk of falling (ENTAiER): a trial protocol. BMC Geriatr. 20(1): 108. 2020. PMID: 32183768. 10.1186/s12877-020-1503-6 KQ1E6a; KQ2E6a32183768
131 Konnopka, C, Buchele, G, . Health-Economic Evaluation of the German Osteoporotic Fracture Prevention Program in Rural Areas (OFRA): Mobility and Falls Prevention Classes, Examination of Bone Health, and Consultation on Safety in the Living Environment. J Gen Intern Med. 38(3): 641–647. 2023. PMID: 35879537. 10.1007/s11606-022-07691-2 KQ1E6c; KQ2E6c35879537
132 Kornholt, J, Feizi, ST, . Effects of a comprehensive medication review intervention on health-related quality of life and other clinical outcomes in geriatric outpatients with polypharmacy: A pragmatic randomized clinical trial. Br J Clin Pharmacol. 20(): 20. 2022. PMID: 35184324. 10.1111/bcp.15287 KQ1E10; KQ2E535184324
133 Korpelainen, R, Keinanen-Kiukaanniemi, S, . Effect of exercise on extraskeletal risk factors for hip fractures in elderly women with low BMD: a population-based randomized controlled trial. J Bone Miner Res. 21(5): 772–9. 2006. PMID: 16734393. 10.1359/jbmr.060116 KQ1E5a; KQ2E5a16734393
134 Kulkarni, S, Nagarkar, A. Effect of a video-assisted fall prevention program on fall incidence in community-dwelling older adults during COVID. Geriatr Nurs (Minneap). 50(): 31–37. 2023. PMID: 36640516. 10.1016/j.gerinurse.2022.12.022 KQ1E3a; KQ2E3a36640516
135 Kumar, R. Pedal exerciser for Improving muscle strength in the elderly- a randomised cluster controlled feasibility study. Physiotherapy (united kingdom). 107(): e123-. 2020. PMID: NONE. 10.1016/j.physio.2020.03.177 KQ1E7a; KQ2E7a
136 Landi, F, Cesari, M, . The “Sarcopenia and Physical fRailty IN older people: multi-componenT Treatment strategies” (SPRINTT) randomized controlled trial: design and methods. Aging-Clinical & Experimental Research. 29(1): 89–100. 2017. PMID: 28144914. 10.1007/s40520-016-0715-2 KQ1E9; KQ2E928144914
137 Lauzé, M, Martel, Dd, . Feasibility, Acceptability and Effects of a Home-Based Exercise Program Using a Gerontechnology on Physical Capacities After a Minor Injury in Community-Living Older Adults: a Pilot Study. Journal of nutrition, health & aging. 22(1): 16–25. 2018. PMID: NONE. 10.1007/s12603-017-0938-8 KQ1E5b; KQ2E5b
138 Law, H, Bte, Ismail N, . Targeting falls through frailty intervention by a combined nutritional intervention and physical exercise programme in community-dwelling older fallers: a pilot randomized clinical trial. J Am Geriatr Soc. 66(): S128-. 2018. PMID: NONE. 10.1111/jgs.15376 KQ1E7a; KQ2E7a
139 Levinger, P, Dunn, J, . High-speed resistance training and balance training for people with knee osteoarthritis to reduce falls risk: study protocol for a pilot randomized controlled trial. Trials [Electronic Resource]. 18(1): 384. 2017. PMID: 28821271. 10.1186/s13063-017-2129-7 KQ1E5; KQ2E528821271
140 Li, Chi Yu. Efficacy of Low-Magnitude High-Frequency Vibration on Preventing Fall and Muscle Loss in Community Elderly. . Ph.D.(): 200 p. 2014. PMID: None. KQ1E7a; KQ2E7a
141 Li, CY, Leung, KS, . Low-magnitude, high-frequency vibration treatment reduced fall incidences and fracture risks in community elderly: A prospective cluster- randomized controlled trial and 1 year follow-up. Osteoporos Int. 24(): S529. 2013. PMID: None. 10.1007/s00198-013-2538-8 KQ1E7a; KQ2E7a
142 Li, F, Harmer, P, . Cost-Effectiveness of a Therapeutic Tai Ji Quan Fall Prevention Intervention for Older Adults at High Risk of Falling. Journals of gerontology. Series A, Biological sciences and medical sciences. 74(9): 1504–1510. 2019. PMID: NONE. 10.1093/gerona/glz008 KQ1E6d; KQ2E6d30629121
143 Li, F, Harmer, P, . Dual-Task Walking Capacity Mediates Tai Ji Quan Impact on Physical and Cognitive Function. Med Sci Sports Exerc. 51(11): 2318–2324. 2019. PMID: 31169795. 10.1249/MSS.0000000000002051 KQ1E6d; KQ2E6d31169795
144 Li, F, Harmer, P, . Effectiveness of Tai Ji Quan vs Multimodal and Stretching Exercise Interventions for Reducing Injurious Falls in Older Adults at High Risk of Falling: Follow-up Analysis of a Randomized Clinical Trial. JAMA Network Open. 2(2): e188280. 2019. PMID: 30768195. 10.1001/jamanetworkopen.2018.8280 KQ1E6d; KQ2E6d30768195
145 Li, F, Harmer, P, . Implementing an Online Virtual Falls Prevention Intervention During a Public Health Pandemic for Older Adults with Mild Cognitive Impairment: A Feasibility Trial. Clin Interv Aging. 16(): 973–983. 2021. PMID: 34079243. 10.2147/CIA.S306431 KQ1E6b; KQ2E6b34079243
146 Liew, LK, Tan, MP, . The Modified Otago Exercises Prevent Grip Strength Deterioration Among Older Fallers in the Malaysian Falls Assessment and Intervention Trial (MyFAIT). Journal of Geriatric Physical Therapy. 42(3): 123–129. 2019. PMID: 29381526. 10.1519/JPT.0000000000000155 KQ1E5; KQ2E529381526
147 Lindgren, Charlotte, Ståhle, Agneta, . Long-term effects of self-reported physical function and disability after participation in an individually adjusted and specific progressive balance training programme for older adults with fear of falling and tendency to fall. European Journal of Physiotherapy. 20(3): 152–158. 2018. PMID: NONE. 10.1080/21679169.2018.1429491 KQ1E5b; KQ2E5b
148 Liu, M, Xue, QL, . Disability Prevention Program Improves Life-Space and Falls Efficacy: A Randomized Controlled Trial. J Am Geriatr Soc. 69(1): 85–90. 2021. PMID: 32951215. 10.1111/jgs.16808 KQ1E5; KQ2E532951215
149 Liu-Ambrose, T, Davis, J, . Action seniors! Promoting executive functions with exercise to prevent falls in at-risk older adults. Alzheimer’s & dementia. 14(7): P989-. 2018. PMID: NONE. 10.1016/j.jalz.2018.06.1339 KQ1E7a; KQ2E7a
150 Liu-Ambrose, T, Davis, JC, . Effect of a Home-Based Exercise Program on Subsequent Falls Among Community-Dwelling High-Risk Older Adults After a Fall: A Randomized Clinical Trial. JAMA. 321(21): 2092–2100. 2019. PMID: 31162569. 10.1001/jama.2019.5795 KQ1E6d; KQ2E6d31162569
151 Liu-Ambrose, T, Davis, JC, . Exercise, Processing Speed, and Subsequent Falls: A Secondary Analysis of a 12-Month Randomized Controlled Trial. J Gerontol A Biol Sci Med Sci. 76(4): 675–682. 2021. PMID: 33225343. 10.1093/gerona/glaa239 KQ1E6d; KQ2E6d33225343
152 Lo, B. A multidisciplinary ED-based fall prevention intervention reduced subsequent ED visits in older adults. Ann Intern Med. 174(2): JC19. 2021. PMID: 33524284. 10.7326/ACPJ202102160-019 KQ1E7a; KQ2E7a33524284
153 Lytras, D, Sykaras, E, . Effects of a modified Otago exercise program delivered through outpatient physical therapy to community-dwelling older adult fallers in Greece during the COVID-19 pandemic: a controlled, randomized, multicenter trial. Eur Geriatr Med. 13(4): 893–906. 2022. PMID: 35606677. 10.1007/s41999-022-00656-y KQ1E6d; KQ2E6d35606677
154 Lyu, J, Li, W, . Efficacy of practising Tai Chi for older people with mild dementia: protocol for a randomised controlled study. BMJ Open. 8(5): e019940. 2018. PMID: 29764877. 10.1136/bmjopen-2017-019940 KQ1E3a; KQ2E3a29764877
155 Madureira, MM, Bonfa, E, . A 12-month randomized controlled trial of balance training in elderly women with osteoporosis: improvement of quality of life. Maturitas. 66(2): 206–11. 2010. PMID: NONE. 10.1016/j.maturitas.2010.03.009 KQ1E3a; KQ2E3a20395080
156 Madureira, MM. Efetividade de um programa de treino de equilíbrio no estado funcional e na freqüência de quedas em mulheres idosas com osteoporose: estudo randomizado e controlado/ Effectiveness of a balance training program on functional status and falling frequency in elderly women with osteoporosis: a randomized controlled study. . (): . 2010. PMID: NONE. KQ1E3a; KQ2E3a
157 Mahlknecht, A, Wiedermann, CJ, . Expert-based medication reviews to reduce polypharmacy in older patients in primary care: a northern-Italian cluster-randomised controlled trial. BMC Geriatr. 21(1): 659. 2021. PMID: 34814835. 10.1186/s12877-021-02612-0 KQ1E10; KQ2E534814835
158 Mangin, D, Lamarche, L, . Team approach to polypharmacy evaluation and reduction: study protocol for a randomized controlled trial. Trials [Electronic Resource]. 22(1): 746. 2021. PMID: 34702336. 10.1186/s13063-021-05685-9 KQ1E5; KQ2E534702336
159 Mat, S, Ng, CT, . Effect of Modified Otago Exercises on Postural Balance, Fear of Falling, and Fall Risk in Older Fallers With Knee Osteoarthritis and Impaired Gait and Balance: A Secondary Analysis. Pm & R. 10(3): 254–262. 2018. PMID: 28827207. 10.1016/j.pmrj.2017.08.405 KQ1E9; KQ2E928827207
160 Mat, S, Ng, Ct, . Effect of the Otago exercises on postural balance and fear of falling among older fallers with knee osteoarthritis. Osteoarthritis and cartilage. 24(): S66-. 2016. PMID: NONE. KQ1E7a; KQ2E7a
161 Matchar, DB, Eom, K, . A Cost-Effectiveness Analysis of a Randomized Control Trial of a Tailored, Multifactorial Program to Prevent Falls Among the Community-Dwelling Elderly. Arch Phys Med Rehabil. 100(1): 1–8. 2019. PMID: 30165053. 10.1016/j.apmr.2018.07.434 KQ1E5a; KQ2E5a30165053
162 McGinnis, Gj, Yu, B, . E4 cancer survivors show better fall and functional status outcomes after receiving exercise interventions than non-E4 cancer survivors. International journal of radiation oncology biology physics. 99(2): E541-. 2017. PMID: NONE. 10.1016/j.ijrobp.2017.06.1900 KQ1E7a; KQ2E7a
163 McMahon, SK, Wyman, JF, . Combining Motivational and Physical Intervention Components to Promote Fall-Reducing Physical Activity Among Community-Dwelling Older Adults: A Feasibility Study. American Journal of Health Promotion. 30(8): 638–644. 2016. PMID: 26389979. KQ1E5; KQ2E526389979
164 Merchant, RA, Chan, YH, . Possible Sarcopenia and Impact of Dual-Task Exercise on Gait Speed, Handgrip Strength, Falls, and Perceived Health. Frontiers in Medicine. 8(): 660463. 2021. PMID: 33937294. 10.3389/fmed.2021.660463 KQ1E5; KQ2E533937294
165 Meziere, A, Oubaya, N, . Exercise Interventions With Trained Home Helpers for Preventing Loss of Autonomy and Falls in Community-Dwelling Older Adults Receiving Home Heath Physical Therapy T4H: A Randomized Controlled Pilot Study. Journal of Geriatric Physical Therapy. 44(3): E138–E149. 2021. PMID: 33534333. 10.1519/JPT.0000000000000287 KQ1E6a; KQ2E6a33534333
166 Mikolaizak, AS, Lord, SR, . A multidisciplinary intervention to prevent subsequent falls and health service use following fall-related paramedic care: a randomised controlled trial. Age Ageing. 46(2): 200–207. 2017. PMID: 28399219. 10.1093/ageing/afw190 KQ1E6d; KQ2E6d28399219
167 Mikolaizak, AS, Lord, SR, . Adherence to a multifactorial fall prevention program following paramedic care: Predictors and impact on falls and health service use. Results from an RCT a priori subgroup analysis. Australas J Ageing. 37(1): 54–61. 2018. PMID: 29139599. 10.1111/ajag.12465 KQ1E9; KQ2E929139599
168 Mikolaizak, AS, Simpson, PM, . Intervention to prevent further falls in older people who call an ambulance as a result of a fall: a protocol for the iPREFER randomised controlled trial. BMC Health Serv Res. 13(): 360. 2013. PMID: 24070456. 10.1186/1472-6963-13-360 KQ1E9; KQ2E924070456
169 Montero-Alia, P, Miralles-Basseda, R, . Controlled trial of balance training using a video game console in community-dwelling older adults. Age Ageing. 48(4): 506–512. 2019. PMID: 31081504. 10.1093/ageing/afz047 KQ1E10; KQ1E1031081504
170 Montero-Alia, P, Munoz-Ortiz, L, . Study protocol of a randomized clinical trial evaluating the effectiveness of a primary care intervention using the Nintendo TM Wii console to improve balance and decrease falls in the elderly. BMC Geriatr. 16(): 8. 2016. PMID: 26796956. 10.1186/s12877-015-0178-x KQ1E9a; KQ2E9a26796956
171 Mortsiefer, A, Wilm, S, . Family conferences and shared prioritisation to improve patient safety in the frail elderly (COFRAIL): study protocol of a cluster randomised intervention trial in primary care. Trials [Electronic Resource]. 21(1): 285. 2020. PMID: 32197631. 10.1186/s13063-020-4182-x KQ1E6a; KQ2E6a32197631
172 Muller, C, Lautenschlager, S, . A feasibility study of a home-based lifestyle-integrated physical exercise training and home modification for community-living older people (Part 2): the FIT-at-Home fall prevention program. Disabil Rehabil. 43(10): 1380–1390. 2021. PMID: 31868030. 10.1080/09638288.2019.1700564 KQ1E2; KQ2E231868030
173 Muller, C, Lautenschlager, S, . Development of a lifestyle-integrated physical exercise training and home modification intervention for older people living in a community with a risk of falling (Part 1): the FIT-at-Home fall prevention program. Disabil Rehabil. 43(10): 1367–1379. 2021. PMID: 31760814. 10.1080/09638288.2019.1661530 KQ1E9; KQ2E931760814
174 Narita, M, Islam, Mm, . Effects of Customized Balance Exercises on Older Women Whose Balance Ability Has Deteriorated With Age. J Women Aging. 27(3): 237–250. 2015. PMID: . 10.1080/08952841.2014.933633 KQ1E6a; KQ2E525607815
175 Naseri, C, McPhail, Sm, . Evaluation of Tailored Falls Education on Older Adults’ Behavior Following Hospitalization. J Am Geriatr Soc. 67(11): 2274–2281. 2019. PMID: NONE. 10.1111/jgs.16053 KQ1E4b; KQ2E4b31265139
176 Newbury, JW, Marley, JE, . A randomised controlled trial of the outcome of health assessment of people aged 75 years and over. Med J Aust. 175(2): 104–107. 2001. PMID: 11556409. KQ1E10; KQ2E511556409
177 Niznik, J, Ferreri, SP, . A deprescribing medication program to evaluate falls in older adults: methods for a randomized pragmatic clinical trial. Trials [Electronic Resource]. 23(1): 256. 2022. PMID: 35379307. 10.1186/s13063-022-06164-5 KQ1E5; KQ2E535379307
178 Noopud, P, Suputtitada, A, . Effects of Thai traditional dance on balance performance in daily life among older women. Aging-Clinical & Experimental Research. 31(7): 961–967. 2019. PMID: 30298380. 10.1007/s40520-018-1040-8 KQ1E5; KQ2E530298380
179 Nyman, SR, Hayward, C, . A randomised controlled trial comparing the effectiveness of tai chi alongside usual care with usual care alone on the postural balance of community-dwelling people with dementia: protocol for the TACIT trial (TAi ChI for people with demenTia). BMC Geriatr. 18(1): 263. 2018. PMID: 30390620. 10.1186/s12877-018-0935-8 KQ1E9; KQ2E930390620
180 Nyman, SR, Ingram, W, . Randomised Controlled Trial Of The Effect Of Tai Chi On Postural Balance Of People With Dementia. Clin Interv Aging. 14(): 2017–2029. 2019. PMID: 31819385. 10.2147/CIA.S228931 KQ1E4b; KQ2E4b31819385
181 Oliveira, JS, Sherrington, C, . Statistical analysis plan for the coaching for healthy AGEing trial - a cluster-randomised controlled trial to enhance physical activity and prevent falls in community-dwelling older people. Braz J Phys Ther. 25(6): 908–914. 2021. PMID: 34802917. 10.1016/j.bjpt.2021.10.003 KQ1E5; KQ2E534802917
182 Olsen, CF, Bergland, A. The effect of exercise and education on fear of falling in elderly women with osteoporosis and a history of vertebral fracture: results of a randomized controlled trial. Osteoporos Int. 25(8): 2017–25. 2014. PMID: . 10.1007/s00198-014-2724-3 KQ1E10; KQ1E1024807628
183 Pahor, M, Guralnik, JM, . Impact and Lessons From the Lifestyle Interventions and Independence for Elders (LIFE) Clinical Trials of Physical Activity to Prevent Mobility Disability. J Am Geriatr Soc. 68(4): 872–881. 2020. PMID: 32105353. 10.1111/jgs.16365 KQ1E5; KQ2E532105353
184 Parry, SW, Bamford, C, . Cognitive-behavioural therapy-based intervention to reduce fear of falling in older people: therapy development and randomised controlled trial - the Strategies for Increasing Independence, Confidence and Energy (STRIDE) study. Health Technol Assess. 20(56): 1–206. 2016. PMID: 27480813. 10.3310/hta20560 KQ1E6d; KQ2E6d27480813
185 Patil, R, Kolu, P, . Cost-effectiveness of vitamin D supplementation and exercise in preventing injurious falls among older home-dwelling women: findings from an RCT. Osteoporos Int. 27(1): 193–201. 2015. PMID: 26205890. 10.1007/s00198-015-3240-9 KQ1E5a; KQ2E5a26205890
186 Patru, S, Marcu, Ir, . Effects of tai chi exercise on muscle strength and balance in postmenopau-salwomen with osteopaenia. Osteoporos Int. 28(): S301-. 2017. PMID: NONE. 10.1007/s00198-017-3950-2 KQ1E7a; KQ2E7a
187 Pazit, L, Jeremy, D, . Safety and feasibility of high speed resistance training with and without balance exercises for knee osteoarthritis: A pilot randomised controlled trial. Physical Therapy in Sport. 34(): 154–163. 2018. PMID: 30317013. 10.1016/j.ptsp.2018.10.001 KQ1E5; KQ2E530317013
188 Pekkarinen, T, Loyttyniemi, E, . Hip fracture prevention with a multifactorial educational program in elderly community-dwelling Finnish women. Osteoporos Int. 24(12): 2983–92. 2013. PMID: 23652464. 10.1007/s00198-013-2381-y KQ1E3; KQ2E323652464
189 Perttila, NM, Ohman, H, . Effect of Exercise on Drug-Related Falls Among Persons with Alzheimer’s Disease: A Secondary Analysis of the FINALEX Study. Drugs Aging. 35(11): 1017–1023. 2018. PMID: 30315403. 10.1007/s40266-018-0594-7 KQ1E4b; KQ2E4b30315403
190 Pettersson, B, Lundin-Olsson, L, . Effectiveness of a self-managed digital exercise programme to prevent falls in older community-dwelling adults: study protocol for the Safe Step randomised controlled trial. BMJ Open. 10(5): e036194. 2020. PMID: 32423936. 10.1136/bmjopen-2019-036194 KQ1E6a; KQ2E6a32423936
191 Phirom, K, Kamnardsiri, T, . Beneficial Effects of Interactive Physical-Cognitive Game-Based Training on Fall Risk and Cognitive Performance of Older Adults. International Journal of Environmental Research & Public Health [Electronic Resource]. 17(17): 21. 2020. PMID: 32825555. 10.3390/ijerph17176079 KQ1E5; KQ2E532825555
192 Porthouse, J, Cockayne, S, . Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 330(7498): 1003. 2005. PMID: 15860827. 10.1136/bmj.330.7498.1003 KQ1E6c; KQ2E6c15860827
193 Posch, M, Schranz, A, . Effectiveness of a Mini-Trampoline Training Program on Balance and Functional Mobility, Gait Performance, Strength, Fear of Falling and Bone Mineral Density in Older Women with Osteopenia. Clin Interv Aging. 14(): 2281–2293. 2019. PMID: 31908438. 10.2147/CIA.S230008 KQ1E5; KQ2E531908438
194 Purkart, B, Bertoncelj, B, . Improving Postural Stability in Active Older Adults: Argentine Tango Dance as an Alternative Fall-prevention Strategy. Altern Ther Health Med. 24(): 24. 2022. PMID: 35325871. KQ1E6a; KQ2E6a35325871
195 Quintela Cardoso do Carmo, Paulo Jorge, Carvalho, Joana, . IMBALANCE AND FALL-RISK IMPROVEMENTS IN THE ELDERLY: EFFECTS OF COMBINED STRENGTH AND AEROBIC TRAINING. Journal of Hearing Science. 10(): 41–47. 2020. PMID: NONE. 10.17430/JHS.2020.10.1.5 KQ1E5; KQ2E5
196 Raichlen, DA, Bharadwaj, PK, . Effects of simultaneous cognitive and aerobic exercise training on dual-task walking performance in healthy older adults: results from a pilot randomized controlled trial. BMC Geriatr. 20(1): 83. 2020. PMID: 32122325. 10.1186/s12877-020-1484-5 KQ1E5; KQ2E532122325
197 Ramon-Espinoza, F, Anton-Rodrigo, I, . Effect of a multicomponent exercise programme (VIVIFRAIL) on cognitive function in Frail Community Elders with Cognitive Decline: study Protocol for a Randomized Multicentre Control Trial. Eur Geriatr Med. 11(Suppl 1): S116-. 2020. PMID: NONE. 10.1007/s41999-020-00428-6 KQ1E7a; KQ2E7a
198 Rapp, K, Kampe, K, . The osteoporotic fracture prevention program in rural areas (OFRA): a protocol for a cluster-randomized health care fund driven intervention in a routine health care setting. BMC Musculoskelet Disord. 17(1): 458. 2016. PMID: 27821102. KQ1E6c; KQ2E6c27821102
199 Rapp, K, Lamb, SE, . Effect of an osteoporotic fracture prevention program on fracture incidence in routine care: a cluster-randomized trial. BMC Med. 20(1): 49. 2022. PMID: 35114993. 10.1186/s12916-021-02226-8 KQ1E6c; KQ2E6c35114993
200 Renehan, E, Meyer, C, . Posthospital Falls Prevention Intervention: A Mixed-Methods Study. J Aging Phys Act. 27(2): 155–165. 2019. PMID: 29989468. 10.1123/japa.2017-0406 KQ1E10; KQ2E529989468
201 Rodrigues, Elisângela Valevein, Gallo, Luiza Herminia, . Effects of Dance Exergaming on Depressive Symptoms, Fear of Falling, and Musculoskeletal Function in Fallers and Nonfallers Community-Dwelling Older Women. Rejuvenation Res. 21(6): 518–526. 2018. PMID: NONE. 10.1089/rej.2017.2041 KQ1E3a; KQ2E3a29669458
202 Rodrigues, IB, Wang, E, . The MoveStrong program for promoting balance and functional strength training and adequate protein intake in pre-frail older adults: A pilot randomized controlled trial. PLoS ONE [Electronic Resource]. 16(9): e0257742. 2021. PMID: 34559837. 10.1371/journal.pone.0257742 KQ1E5; KQ2E534559837
203 Rogers, MW, Creath, RA, . Comparison of Lateral Perturbation-Induced Step Training and Hip Muscle Strengthening Exercise on Balance and Falls in Community-Dwelling Older Adults: A Blinded Randomized Controlled Trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 76(9): e194–e202. 2021. PMID: 33491052. 10.1093/gerona/glab017 KQ1E10; KQ1E1033491052
204 Roller, M, Kachingwe, A, . Pilates Reformer exercises for fall risk reduction in older adults: A randomized controlled trial. J Bodyw Mov Ther. 22(4): 983–998. 2018. PMID: 30368346. 10.1016/j.jbmt.2017.09.004 KQ1E5; KQ2E530368346
205 Rooijackers, TH, Kempen, Gijm, . Effectiveness of a reablement training program for homecare staff on older adults’ sedentary behavior: A cluster randomized controlled trial. J Am Geriatr Soc. 69(9): 2566–2578. 2021. PMID: 34097301. 10.1111/jgs.17286 KQ1E6; KQ2E634097301
206 Rossi-Izquierdo, M, Gayoso-Diz, P, . Vestibular rehabilitation in elderly patients with postural instability: reducing the number of falls-a randomized clinical trial. Aging Clin Exp Res. 30(11): 1353–1361. 2018. PMID: 30008159. 10.1007/s40520-018-1003-0 KQ1E10; KQ2E530008159
207 Saez, De Asteasu Ml, Rodrigo, Ia, . Gait kinematic parameters analysis using an inertial sensor unit after 1 month of multicomponent exercise training (vivifrail) in frail/prefrail older adults with cognitive impairment: preliminary results of a randomized controlled trial. Eur Geriatr Med. 9(): S108–s109. 2018. PMID: NONE. 10.1007/s41999-018-0097-4 KQ1E7a; KQ2E7a
208 Sanders, KM, Stuart, AL, . Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. JAMA. 303(18): 1815–22. 2010. PMID: 20460620. 10.1001/jama.2010.594 KQ1E6c; KQ2E6c20460620
209 Santin-Medeiros, F, Santos-Lozano, A, . Effect of 8 months of whole-body vibration training on quality of life in elderly women. Research in Sports Medicine. 25(1): 101–107. 2017. PMID: 27885859. 10.1080/15438627.2016.1258638 KQ1E5b; KQ2E5b27885859
210 Sciamanna, CN, Ballentine, NH, . Working to Increase Stability through Exercise (WISE): screening, recruitment, and baseline characteristics. Trials [Electronic Resource]. 22(1): 809. 2021. PMID: 34781994. 10.1186/s13063-021-05761-0 KQ1E6a; KQ2E6a34781994
211 Sedaghati, P, Goudarzian, M, . The impact of a multicomponent-functional training with postural correction on functional balance in the elderly with a history of falling. Journal of Experimental Orthopaedics. 9(1): 23. 2022. PMID: 35233709. 10.1186/s40634-022-00459-x KQ1E3a; KQ2E3a35233709
212 Sen, EI, Esmaeilzadeh, S, . Effects of whole-body vibration and high impact exercise on bone metabolism and fall risk in postmenopausal women, Postmenopozal Kadinlarda Tum Vucut Titresim Egzersizleri ve Vucut Atirliti ile Yapilan Yuksek Guclu Egzersizlerin Kemik Metabolizmasi ve Dusme Riski Uzerindeki Etkileri. [Turkish, English]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 59(): 247. 2013. PMID: NONE. 10.4274/tftr.24.59.1 KQ1E7a; KQ2E7a
213 Serra-Prat, M, Sist, X, . Effectiveness of an intervention to prevent frailty in pre-frail community-dwelling older people consulting in primary care: a randomised controlled trial. Age Ageing. 46(3): 401–407. 2017. PMID: 28064172. 10.1093/ageing/afw242 KQ1E6c; KQ2E6c28064172
214 Smulders, Ellen, van Lankveld, Wim, . Can improved obstacle avoidance performance explain the effectiveness of a multimodal falls prevention program for persons with osteoporosis? [corrected] [published erratum appears in J AM GERIATR SOC 2011 May;59(5):959]. J Am Geriatr Soc. 59(2): 368–369. 2011. PMID: NONE. 10.1111/j.1532-5415.2011.03254.x KQ1E7a; KQ2E7a21314656
215 Song, R, Roberts, BL, . A randomized study of the effects of t’ai chi on muscle strength, bone mineral density, and fear of falling in women with osteoarthritis. Journal of Alternative & Complementary Medicine. 16(3): 227–33. 2010. PMID: NONE. 10.1089/acm.2009.0165 KQ1E4a; KQ2E4a20192907
216 Sousa, N, Mendes, R, . Combined exercise is more effective than aerobic exercise in the improvement of fall risk factors: a randomized controlled trial in community-dwelling older men. Clin Rehabil. 31(4): 478–486. 2017. PMID: 27353246. 10.1177/0269215516655857 KQ1E5b; KQ2E5b27353246
217 Souto Braz, RR, Campos, SL, . Effectiveness of Whole-Body Vibration Combined with Multicomponent Training on the Risk of Falls and Quality of Life in Elderly Women with Osteoporosis: Study Protocol for a Randomized Controlled Clinical Trial. Biology (Basel). 11(2): 08. 2022. PMID: 35205132. 10.3390/biology11020266 KQ1E6a; KQ2E6a35205132
218 Sprague, BN, Ross, LA, . Does Cognitive Training Reduce Falls across Ten Years?: Data from the ACTIVE Trial. International Journal of Environmental Research & Public Health [Electronic Resource]. 20(6): 11. 2023. PMID: 36981850. 10.3390/ijerph20064941 KQ1E6c; KQ2E6c36981850
219 Squires, P, Pahor, M, . Impact of Anticholinergic Medication Burden on Mobility and Falls in the Lifestyle Interventions for Elders (LIFE) Study. J Clin Med. 9(9): 16. 2020. PMID: 32947839. 10.3390/jcm9092989 KQ1E2; KQ2E232947839
220 Stanghelle, B, Bentzen, H, . Physical fitness in older women with osteoporosis and vertebral fracture after a resistance and balance exercise programme: 3-month post-intervention follow-up of a randomised controlled trial. BMC Musculoskelet Disord. 21(1): 471. 2020. PMID: 32682416. 10.1186/s12891-020-03495-9 KQ1E5; KQ2E532682416
221 Stanmore, EK, Mavroeidi, A, . The effectiveness and cost-effectiveness of strength and balance Exergames to reduce falls risk for people aged 55 years and older in UK assisted living facilities: a multi-centre, cluster randomised controlled trial. BMC Med. 17(1): 49. 2019. PMID: 30813926. 10.1186/s12916-019-1278-9 KQ1E6a; KQ2E6a30813926
222 Stark, Susan, Keglovits, Marian, . A Randomized Controlled Feasibility Trial of Tailored Home Modifications To Improve Activities of Daily Living. Am J Occup Ther. 70(): 1–1. 2016. PMID: NONE. 10.5014/ajot.2016.70S1-RP103E KQ1E5b; KQ2E5b
223 Stasi, S, Tsekoura, M, . Motor Control and Ergonomic Intervention Home-Based Program: A Pilot Trial Performed in the Framework of the Motor Control Home Ergonomics Elderlies’ Prevention of Falls (McHeELP) Project. Cureus. 13(4): e14336. 2021. PMID: 33968539. 10.7759/cureus.14336 KQ1E5; KQ2E533968539
224 Stevens, Z, Carpenter, H, . Lessons learnt during a complex, multicentre cluster randomised controlled trial: the ProAct≥65 trial. Trials. 14(): 192. 2013. PMID: 23815878. 10.1186/1745-6215-14-192 KQ1E5a; KQ2E5a23815878
225 Szanton, SL, Clemson, L, . Pilot Outcomes of a Multicomponent Fall Risk Program Integrated Into Daily Lives of Community-Dwelling Older Adults. J Appl Gerontol. 40(3): 320–327. 2021. PMID: 32193981. 10.1177/0733464820912664 KQ1E6a; KQ2E6a32193981
226 Takatori, K, Matsumoto, D, . Benefits of a novel concept of home-based exercise with the aim of preventing aspiration pneumonia and falls in frail older women: a pragmatic controlled trial. BMJ Open Sport & Exercise Medicine. 2(1): e000127. 2016. PMID: 27900185. KQ1E2; KQ2E227900185
227 Tan, ACW, Clemson, L, . Strategies for recruitment in general practice settings: the iSOLVE fall prevention pragmatic cluster randomised controlled trial. BMC Med Res Methodol. 19(1): 236. 2019. PMID: 31829133. 10.1186/s12874-019-0869-7 KQ1E5; KQ2E531829133
228 Tan, PJ, Khoo, EM, . An individually-tailored multifactorial intervention program for older fallers in a middle-income developing country: Malaysian Falls Assessment and Intervention Trial (MyFAIT). BMC Geriatr. 14(): 78. 2014. PMID: 24951180. 10.1186/1471-2318-14-78 KQ1E9; KQ2E924951180
229 Tan, PJ, Khoo, EM, . Individually-tailored multifactorial intervention to reduce falls in the Malaysian Falls Assessment and Intervention Trial (MyFAIT): A randomized controlled trial. PLoS ONE [Electronic Resource]. 13(8): e0199219. 2018. PMID: 30074996. 10.1371/journal.pone.0199219 KQ1E6d; KQ2E6d30074996
230 Tan, Pj, Khoo, Em, . The effects of a tailored multifactorial intervention on rate of fall and time-to-first fall in Malaysia. Age Ageing. 46(): . 2017. PMID: NONE. 10.1093/ageing/afx120.44 KQ1E7a; KQ2E7a
231 Tan, Pj, Tan, Mp. Characteristics of fall recurrence: results of the malaysian falls assessment and intervention trial (MyFAIT). Age Ageing. 46(): i32-. 2017. PMID: NONE. 10.1093/ageing/afx072.119 KQ1E7a; KQ2E7a
232 Taylor, ME, Close, JCT, . Pilot feasibility study of a home-based fall prevention exercise program (StandingTall) delivered through a tablet computer (iPad) in older people with dementia. Australas J Ageing. 39(3): e278–e287. 2020. PMID: 31538401. 10.1111/ajag.12717 KQ1E6a; KQ2E6a31538401
233 Taylor, ME, Wesson, J, . Erratum to: Tailored Exercise and Home Hazard Reduction Program for Fall Prevention in Older People With Cognitive Impairment: The i-FOCIS Randomized Controlled Trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 77(2): e108. 2022. PMID: 35134864. 10.1093/gerona/glab316 KQ1E7a; KQ2E7a35134864
234 Tew, GA, Ward, L, . Does yoga reduce the risk of falls in older people?. BMJ. 370(): m3246. 2020. PMID: 32883704. 10.1136/bmj.m3246 KQ1E7a; KQ2E7a32883704
235 Thaiyanto, J, Sittichoke, C, . Effects of Multicomponent Exercise on Cognitive Performance and Fall Risk in Older Women with Mild Cognitive Impairment. Journal of Nutrition, Health & Aging. 25(2): 160–164. 2021. PMID: NONE. 10.1007/s12603-020-1458-5 KQ1E5b; KQ2E5b
236 Thiamwong, Ladda, Huang, HelenJ, . Shifting Maladaptive Fall Risk Appraisal in Older Adults through an in-Home Physio-fEedback and Exercise pRogram (PEER): A Pilot Study. Clin Gerontol. 43(4): 378–390. 2020. PMID: NONE. 10.1080/07317115.2019.1692120 KQ1E5b; KQ2E5b31713464
237 Thomsen, MJ, Liston, M, . Dancing Against falls iN Community-dwElling older adults (DANCE): a study protocol of a stratified, block-randomised trial. Injury Prevention. 28(1): 93–101. 2022. PMID: 34544808. 10.1136/injuryprev-2021-044224 KQ1E6a; KQ2E6a34544808
238 Tiedemann, A, Rissel, C, . Health coaching and pedometers to enhance physical activity and prevent falls in community-dwelling people aged 60 years and over: study protocol for the Coaching for Healthy AGEing (CHAnGE) cluster randomised controlled trial. BMJ Open. 6(5): e012277. 2016. PMID: 27165652. 10.1136/bmjopen-2016-012277 KQ1E5; KQ2E527165652
239 Trautwein, S, Barisch-Fritz, B, . Effects of a 16-week multimodal exercise program on gait performance in individuals with dementia: a multicenter randomized controlled trial. BMC Geriatr. 20(1): 245. 2020. PMID: 32677897. 10.1186/s12877-020-01635-3 KQ1E4b; KQ2E4b32677897
240 Tsang, WW, Fu, AS. Virtual reality exercise to improve balance control in older adults at risk of falling. Hong Kong Medical Journal. 22 Suppl 2(): S19–22. 2016. PMID: 26908338. KQ1E3; KQ2E326908338
241 Tsekoura, M, Stasi, S, . Methodology of a home-based motor control exercise and ergonomic intervention programme for community-dwelling older people: The McHeELP study. Journal of Frailty Sarcopenia & Falls. 6(3): 153–162. 2021. PMID: 34557615. 10.22540/JFSF-06-153 KQ1E9; KQ2E934557615
242 Vale, Fernando Alves, Voos, Mariana Callil, . Balance as an Additional Effect of Strength and Flexibility Aquatic Training in Sedentary Lifestyle Elderly Women. Current Gerontology & Geratrics Research. (): 1–6. 2020. PMID: NONE. 10.1155/2020/1895473 KQ1E3a; KQ2E3a
243 Vaziri, DD, Aal, K, . Exploring user experience and technology acceptance for a fall prevention system: results from a randomized clinical trial and a living lab. European Reviews of Aging & Physical Activity. 13(): 6. 2016. PMID: 27293489. 10.1186/s11556-016-0165-z KQ1E5b; KQ2E5b27293489
244 Vogel, O, Niederer, D, . Multimodal Exercise Effects in Older Adults Depend on Sleep, Movement Biography, and Habitual Physical Activity: A Randomized Controlled Trial. Front Aging Neurosci. 13(): 722799. 2021. PMID: 34744686. 10.3389/fnagi.2021.722799 KQ1E5b; KQ2E5b34744686
245 von Stengel, S, Kemmler, W, . Effects of whole body vibration on bone mineral density and falls: results of the randomized controlled ELVIS study with postmenopausal women. Osteoporos Int. 22(1): 317–25. 2011. PMID: 20306017. 10.1007/s00198-010-1215-4 KQ1E6d; KQ2E6d20306017
246 Wayne, PM, Kiel, DP, . Impact of Tai Chi exercise on multiple fracture-related risk factors in post-menopausal osteopenic women: a pilot pragmatic, randomized trial. BMC Complement Altern Med. 12(): 7. 2012. PMID: 22289280. 10.1186/1472-6882-12-7 KQ1E4a; KQ2E4a22289280
247 Werner, C, Wolf-Belala, N, . A multifactorial interdisciplinary intervention to prevent functional and mobility decline for more participation in (pre-)frail community-dwelling older adults (PromeTheus): study protocol for a multicenter randomized controlled trial. BMC Geriatr. 22(1): 124. 2022. PMID: 35164686. 10.1186/s12877-022-02783-4 KQ1E6a; KQ2E6a35164686
248 Wetherell, JL, Bower, ES, . Integrated Exposure Therapy and Exercise Reduces Fear of Falling and Avoidance in Older Adults: A Randomized Pilot Study. American Journal of Geriatric Psychiatry. 26(8): 849–859. 2018. PMID: 29754811. 10.1016/j.jagp.2018.04.001 KQ1E6d; KQ2E6d29754811
249 Williams, Jonathan, Nyman, Samuel. A secondary analysis of a randomised controlled trial to investigate the effect of Tai Chi on the instrumented timed up and go test in people with mild to moderate dementia. Aging Clin Exp Res. 33(8): 2175–2181. 2021. PMID: NONE. 10.1007/s40520-020-01741-7 KQ1E9; KQ2E933141417
250 Williams, SB, Brand, CA, . Feasibility and outcomes of a home-based exercise program on improving balance and gait stability in women with lower-limb osteoarthritis or rheumatoid arthritis: a pilot study. Arch Phys Med Rehabil. 91(1): 106–14. 2010. PMID: NONE. 10.1016/j.apmr.2009.08.150 KQ1E5; KQ2E520103404
251 Wijlhuizen, Gj, Du, Bois P, . Effect evaluation of a multifactor community intervention to reduce falls among older persons. International journal of injury control and safey promotion. 14(1): 25–33. 2007. KQ1E2; KQ2E2
252 Winters-Stone, Km, Li, F, . The GET FIT trial (NCT01635413): a randomized controlled trial of strength training versus Tai Ji Quan for fall prevention among female cancer survivors. J Clin Oncol. 39(15 suppl): . 2021. PMID: NONE. 10.1200/JCO.2021.39.15_suppl.12059 KQ1E7a; KQ2E7a
253 Witte, K, Emmermacher, P, . Improvement of Balance and General Physical Fitness in Older Adults by Karate: a Randomized Controlled Trial. Complementary medicine research. 24(6): 390–393. 2017. PMID: NONE. 10.1159/000479151 KQ1E7b; KQ2E7b29020668
254 Yang, F, Su, X, . Vibration training reducing falls in community-living older adults: a pilot randomized controlled trial. Aging-Clinical & Experimental Research. 35(4): 803–814. 2023. PMID: 36781617. 10.1007/s40520-023-02362-6 KQ1E6; KQ2E636781617
255 Yingyongyudha, A, Ramrong, T, . Effect of dual task training regarding to postural stability in the healthy elderly. Age Ageing. 48(2): iv9-. 2019. PMID: NONE. 10.1093/ageing/afz164.32 KQ1E7a; KQ2E7a
256 Zhao, Y, Chung, PK, . Effectiveness of a balance-focused exercise program for enhancing functional fitness of older adults at risk of falling: A randomised controlled trial. Geriatr Nurs (Minneap). 38(6): 491–497. 2017. PMID: 28359614. 10.1016/j.gerinurse.2017.02.011 KQ1E5; KQ2E528359614
257 Zhao, Y, Chung, PK, . Effectiveness of a Community-Based Exercise Program on Balance Performance and Fear of Falling in Older Nonfallers at Risk for Falling: A Randomized, Controlled Study. J Aging Phys Act. 24(4): 516–524. 2016. PMID: 26796916. KQ1E6d; KQ2E6d26796916
258 Zieschang, T, Schwenk, M, . Falls and Physical Activity in Persons With Mild to Moderate Dementia Participating in an Intensive Motor Training: Randomized Controlled Trial. Alzheimer Dis Assoc Disord. 31(4): 307–314. 2017. PMID: 28628488. 10.1097/WAD.0000000000000201 KQ1E6d; KQ2E6d28628488