# Appendix C Included Studies

Included studies List, by Key Question (KQ) and Intervention Type

Ancillary publication(s) indented under primary article

## KEY QUESTION 1

### Multifactorial

1. Bhasin S, Gill TM, Reuben DB, . A Randomized Trial of a Multifactorial Strategy to Prevent Serious Fall Injuries. N Engl J Med. 2020;383(2):129–40. PMID: 32640131. 10.1056/NEJMoa2002183 32640131
  a. Bhasin S, Gill TM, Reuben DB, . Strategies to Reduce Injuries and Develop Confidence in Elders (STRIDE): A Cluster-Randomized Pragmatic Trial of a Multifactorial Fall Injury Prevention Strategy: Design and Methods. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2018;73(8):1053–61. PMID: 29045582. 10.1093/gerona/glx190 29045582
  b. Ganz DA, Siu AL, Magaziner J, . Protocol for serious fall injury adjudication in the Strategies to Reduce Injuries and Develop Confidence in Elders (STRIDE) study. Injury Epidemiology. 2019;6:14. PMID: 31245263. 10.1186/s40621-019-0190-2 31245263
  c. Ganz DA, Yuan AH, Greene EJ, . Effect of the STRIDE fall injury prevention intervention on falls, fall injuries, and health-related quality of life. Journal of the American Geriatrics Society. 2022;70(11):3221–9. PMID: 35932279. 10.1111/jgs.17964 35932279
  d. Gill TM, Bhasin S, Reuben DB, . Effect of a Multifactorial Fall Injury Prevention Intervention on Patient Well-Being: The STRIDE Study. Journal of the American Geriatrics Society. 2021;69(1):173–9. PMID: 33037632. 10.1111/jgs.16854 33037632
  e. Gill TM, McGloin JM, Latham NK, . Screening, Recruitment, and Baseline Characteristics for the Strategies to Reduce Injuries and Develop Confidence in Elders (STRIDE) Study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2018;73(11):1495–501. PMID: 30020415. 10.1093/gerona/gly076 30020415
  f. McMahon S, Greene E, Latham N, . Engagement of older adults in STRIDE’s multifactorial fall injury prevention intervention. Journal of the American Geriatrics Society. 2022;70(11):3116–26. PMID: 35924574. 10.1111/jgs.17983 35924574
  g. Reuben DB, Gazarian P, Alexander N, . The Strategies to Reduce Injuries and Develop Confidence in Elders Intervention: Falls Risk Factor Assessment and Management, Patient Engagement, and Nurse Co-management. Journal of the American Geriatrics Society. 2017;65(12):2733–9. PMID: 29044479. 10.1111/jgs.15121 29044479
2. Bruce J, Hossain A, Lall R, . Fall prevention interventions in primary care to reduce fractures and falls in people aged 70 years and over: the PreFIT three-arm cluster RCT. Health Technol Assess. 2021;25(34):1–114. PMID: 34075875. 10.3310/hta25340 34075875
  a. Bruce J, Lall R, Withers EJ, . A cluster randomised controlled trial of advice, exercise or multifactorial assessment to prevent falls and fractures in community-dwelling older adults: protocol for the prevention of falls injury trial (PreFIT). BMJ Open. 2016;6(1):e009362. PMID: 26781504. 10.1136/bmjopen-2015-009362 26781504
  b. Bruce J, Ralhan S, Sheridan R, . The design and development of a complex multifactorial falls assessment intervention for falls prevention: The Prevention of Falls Injury Trial (PreFIT). BMC Geriatrics. 2017;17(1):116. PMID: 28571563. 10.1186/s12877-017-0492-6 28571563
  c. Finnegan S, Bruce J, Skelton DA, . Development and delivery of an exercise programme for falls prevention: the Prevention of Falls Injury Trial (PreFIT). Physiotherapy. 2018;104(1):72–9. PMID: 28801033. 10.1016/j.physio.2017.06.004 28801033
  d. Lamb SE, Bruce J, Hossain A, . Screening and Intervention to Prevent Falls and Fractures in Older People. New England Journal of Medicine. 2020;383(19):1848–59. PMID: 33211928. 10.1056/NEJMoa2001500 33211928
3. Cameron ID, Fairhall N, Langron C, . A multifactorial interdisciplinary intervention reduces frailty in older people: randomized trial. BMC medicine. 2013;11:65. PMID: 23497404. 10.1186/1741-7015-11-65 23497404
4. Ciaschini PM, Straus SE, Dolovich LR, . Community-based intervention to optimise falls risk management: a randomised controlled trial. Age Ageing. 2009;38(6):724–30. PMID: 19767629. 10.1093/ageing/afp176 19767629
5. Close J, Ellis M, Hooper R, . Prevention of falls in the elderly trial (PROFET): a randomised controlled trial. Lancet. 1999;353(9147):93–7. PMID: 10023893. 10.1016/S0140-6736(98)06119-4 10023893
6. Cohen MA, Miller J, Xiaomei S, . Prevention Program Lowered The Risk Of Falls And Decreased Claims For Long-Term Services Among Elder Participants. Health Affairs. 2015;34(6):971–7. PMID: 26056202. 10.1377/hlthaff.2014.1172 26056202
7. Conroy S, Kendrick D, Harwood R, . A multicentre randomised controlled trial of day hospital-based falls prevention programme for a screened population of community-dwelling older people at high risk of falls. Age Ageing. 2010;39(6):704–10. PMID: 20823124. 10.1093/ageing/afq096 20823124
8. Davison J, Bond J, Dawson P, . Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention--a randomised controlled trial. Age Ageing. 2005;34(2):162–8. PMID: 15716246. 10.1093/ageing/afi053 15716246
9. de Vries OJ, Peeters GM, Elders PJ, . Multifactorial intervention to reduce falls in older people at high risk of recurrent falls: a randomized controlled trial. Arch Intern Med. 2010;170(13):1110–7. PMID: 20625015. 10.1001/archinternmed.2010.169 20625015
  a. Peeters GM, de Vries OJ, Elders PJ, . Prevention of fall incidents in patients with a high risk of falling: design of a randomised controlled trial with an economic evaluation of the effect of multidisciplinary transmural care. BMC Geriatr. 2007;7:15. PMID: 17605771. 10.1186/1471-2318-7-15 17605771
10. Elley CR, Robertson MC, Garrett S, . Effectiveness of a falls-and-fracture nurse coordinator to reduce falls: a randomized, controlled trial of at-risk older adults. J Am Geriatr Soc. 2008;56(8):1383–9. PMID: 18808597. 10.1111/j.1532-5415.2008.01802.x 18808597
11. Fairhall N, Sherrington C, Lord SR, . Effect of a multifactorial, interdisciplinary intervention on risk factors for falls and fall rate in frail older people: a randomised controlled trial. Age Ageing. 2014;43(5):616–22. PMID: 24381025. 10.1093/ageing/aft204 24381025
  a. Fairhall N, Aggar C, Kurrle SE, . Frailty Intervention Trial (FIT). BMC Geriatr. 2008;8:27. PMID: 18851754. 10.1186/1471-2318-8-27 18851754
  b. Fairhall N, Sherrington C, Cameron ID, . A multifactorial intervention for frail older people is more than twice as effective among those who are compliant: complier average causal effect analysis of a randomised trial. J Physiother. 2017;63(1):40–4. PMID: 27993489. 10.1016/j.jphys.2016.11.007 27993489
  c. Ferrer A, Formiga F, Sanz H, . Multifactorial assessment and targeted intervention to reduce falls among the oldest-old: a randomized controlled trial. Clin Interv Aging. 2014;9:383–93. PMID: 24596458. 10.2147/CIA.S57580 24596458
12. Hendriks MR, Bleijlevens MH, van Haastregt JC, . Lack of effectiveness of a multidisciplinary fall-prevention program in elderly people at risk: a randomized, controlled trial. J Am Geriatr Soc. 2008;56(8):1390–7. PMID: 18662214. 10.1111/j.1532-5415.2008.01803.x 18662214
13. Hogan DB, MacDonald FA, Betts J, . A randomized controlled trial of a community-based consultation service to prevent falls. CMAJ. 2001;165(5):537–43. PMID: 11563205.11563205
14. Imhof L, Naef R, Wallhagen MI, . Effects of an advanced practice nurse in-home health consultation program for community-dwelling persons aged 80 and older. J Am Geriatr Soc. 2012;60(12):2223–31. PMID: 23194103. 10.1111/jgs.12026 23194103
15. La Porta F, Lullini G, Caselli S, . Efficacy of a multiple-component and multifactorial personalized fall prevention program in a mixed population of community-dwelling older adults with stroke, Parkinson’s Disease, or frailty compared to usual care: The PRE.C.I.S.A. randomized controlled trial. Front Neurol. 2022;13:943918. PMID: 36119666. 10.3389/fneur.2022.943918 36119666
16. Lightbody E, Watkins C, Leathley M, . Evaluation of a nurse-led falls prevention programme versus usual care: a randomized controlled trial. Age Ageing. 2002;31(3):203–10. PMID: 12006310.12006310
17. Logan PA, Coupland CA, Gladman JR, . Community falls prevention for people who call an emergency ambulance after a fall: randomised controlled trial. BMJ. 2010;340:c2102. PMID: 20460331. 10.1136/bmj.c2102 20460331
18. Lord SR, Tiedemann A, Chapman K, . The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(8):1296–304. PMID: 16078954. 10.1111/j.1532-5415.2005.53425.x 16078954
19. Moller UO, Kristensson J, Midlov P, . Effects of a one-year home-based case management intervention on falls in older people: a randomized controlled trial. J Aging Phys Act. 2014;22(4):457–64. PMID: 24152667. 10.1123/japa.2013-0101 24152667
20. Palvanen M, Kannus P, Piirtola M, . Effectiveness of the Chaos Falls Clinic in preventing falls and injuries of home-dwelling older adults: a randomised controlled trial. Injury. 2014;45(1):265–71. PMID: 23579066. 10.1016/j.injury.2013.03.010 23579066
21. Perula LA, Varas-Fabra F, Rodriguez V, . Effectiveness of a multifactorial intervention program to reduce falls incidence among community-living older adults: a randomized controlled trial. Arch Phys Med Rehabil. 2012;93(10):1677–84. PMID: 22609117. 10.1016/j.apmr.2012.03.035 22609117
22. Russell MA, Hill KD, Day LM, . A randomized controlled trial of a multifactorial falls prevention intervention for older fallers presenting to emergency departments. J Am Geriatr Soc. 2010;58(12):2265–74. PMID: 21143436. 10.1111/j.1532-5415.2010.03191.x 21143436
23. Salminen MJ, Vahlberg TJ, Salonoja MT, . Effect of a risk-based multifactorial fall prevention program on the incidence of falls. J Am Geriatr Soc. 2009;57(4):612–9. PMID: 19392952. 10.1111/j.1532-5415.2009.02176.x 19392952
  a. Salminen M, Vahlberg T, Kivela SL. The long-term effect of a multifactorial fall prevention programme on the incidence of falls requiring medical treatment. Public Health. 2009;123(12):809–13. PMID: 19958918. 10.1016/j.puhe.2009.10.018 19958918
24. Spice CL, Morotti W, George S, . The Winchester falls project: a randomised controlled trial of secondary prevention of falls in older people. Age Ageing. 2009;38(1):33–40. PMID: 18829689. 10.1093/ageing/afn192 18829689
25. Tinetti ME, Baker DI, McAvay G, . A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331(13):821–7. PMID: 8078528. 10.1056/NEJM199409293311301 8078528
26. van Haastregt JC, Diederiks JP, van Rossum E, . Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321(7267):994–8. PMID: 11039967.11039967
27. Vind AB, Andersen HE, Pedersen KD, . An outpatient multifactorial falls prevention intervention does not reduce falls in high-risk elderly Danes. J Am Geriatr Soc. 2009;57(6):971–7. PMID: 19507291.19507291
  a. Vind AB, Andersen HE, Pedersen KD, . The Effect of a program of Multifactorial Fall Prevention on Health Related Quality of Life, Functional Ability, Fear of Falling and Psychological Well-being. A Randomized Controlled Trial. Aging Clin Exp Res. 2010;22(3):249–54. PMID: 19934621. 10.3275/6628 19934621
28. Wagner EH, LaCroix AZ, Grothaus L, . Preventing disability and falls in older adults: a population-based randomized trial. Am J Public Health. 1994;84(11):1800–6. PMID: 7977921.7977921

### Exercise

1. Barnett A, Smith B, Lord SR, . Community-based group exercise improves balance and reduces falls in at-risk older people: a randomised controlled trial. Age Ageing. 2003;32(4):407–14. PMID: 12851185.12851185
2. Bruce J, Hossain A, Lall R, . Fall prevention interventions in primary care to reduce fractures and falls in people aged 70 years and over: the PreFIT three-arm cluster RCT. Health Technol Assess. 2021;25(34):1–114. PMID: 34075875. 10.3310/hta25340 34075875
  a. Bruce J, Lall R, Withers EJ, . A cluster randomised controlled trial of advice, exercise or multifactorial assessment to prevent falls and fractures in community-dwelling older adults: protocol for the prevention of falls injury trial (PreFIT). BMJ Open. 2016;6(1):e009362. PMID: 26781504. 10.1136/bmjopen-2015-009362 26781504
  b. Bruce J, Ralhan S, Sheridan R, . The design and development of a complex multifactorial falls assessment intervention for falls prevention: The Prevention of Falls Injury Trial (PreFIT). BMC Geriatrics. 2017;17(1):116. PMID: 28571563. 10.1186/s12877-017-0492-6 28571563
  c. Finnegan S, Bruce J, Skelton DA, . Development and delivery of an exercise programme for falls prevention: the Prevention of Falls Injury Trial (PreFIT). Physiotherapy. 2018;104(1):72–9. PMID: 28801033. 10.1016/j.physio.2017.06.004 28801033
  d. Lamb SE, Bruce J, Hossain A, . Screening and Intervention to Prevent Falls and Fractures in Older People. New England Journal of Medicine. 2020;383(19):1848–59. PMID: 33211928. 10.1056/NEJMoa2001500 33211928
3. Buchner DM, Cress ME, de Lateur BJ, . The effect of strength and endurance training on gait, balance, fall risk, and health services use in community-living older adults. J Gerontol A Biol Sci Med Sci. 1997;52(4):M218–M24. PMID: 9224433.9224433
  a. Buchner DM, Cress ME, Wagner EH, . The Seattle FICSIT/MoveIt study: the effect of exercise on gait and balance in older adults. J Am Geriatr Soc. 1993;41(3):321–5. PMID: 8440857.8440857
  b. Buchner DM, Hornbrook MC, Kutner NG, . Development of the common data base for the FICSIT trials. J Am Geriatr Soc. 1993;41(3):297–308. PMID: 8440854.8440854
  c. Tinetti ME, Baker DI, Garrett PA, . Yale FICSIT: risk factor abatement strategy for fall prevention. J Am Geriatr Soc. 1993;41(3):315–20. PMID: 8440856.8440856
4. Callisaya ML, Jayakody O, Vaidya A, . A novel cognitive-motor exercise program delivered via a tablet to improve mobility in older people with cognitive impairment - StandingTall Cognition and Mobility. Exp Gerontol. 2021;152:111434. PMID: 34098009. 10.1016/j.exger.2021.111434 34098009
5. Campbell AJ, Robertson MC, Gardner MM, . Randomised controlled trial of a general practice programme of home based exercise to prevent falls in elderly women. BMJ. 1997;315(7115):1065–9. PMID: 9366737.9366737
6. Chyu MC, James CR, Sawyer SF, . Effects of tai chi exercise on posturography, gait, physical function and quality of life in postmenopausal women with osteopaenia: a randomized clinical study. Clinical Rehabilitation. 2010;24(12):1080–90. PMID: 20702512. 10.1177/0269215510375902 20702512
7. Delbaere K, Valenzuela T, Lord SR, . E-health StandingTall balance exercise for fall prevention in older people: results of a two year randomised controlled trial. BMJ. 2021;373:n740. PMID: 33824131. 10.1136/bmj.n740 33824131
  a. Ambrens M, van Schooten KS, Lung T, . Economic evaluation of the e-Health StandingTall balance exercise programme for fall prevention in people aged 70 years and over. Age & Ageing. 2022;51(6):01. PMID: 35679193. 10.1093/ageing/afac130 35679193
8. El-Khoury F, Cassou B, Latouche A, . Effectiveness of two year balance training programme on prevention of fall induced injuries in at risk women aged 75-85 living in community: Ossebo randomised controlled trial. BMJ. 2015;351:h3830. PMID: 26201510. 10.1136/bmj.h3830 26201510
  a. Dargent-Molina P, El Khoury F, Cassou B. The ‘Ossebo’ intervention for the prevention of injurious falls in elderly women: background and design. Glob Health Promot. 2013;20(2 Suppl):88–93. PMID: 23678502. 10.1177/1757975913483341 23678502
9. Fitzharris MP, Day L, Lord SR, . The Whitehorse NoFalls trial: effects on fall rates and injurious fall rates. Age Ageing. 2010;39(6):728–33. PMID: 20817936. 10.1093/ageing/afq109 20817936
  a. Day L, Fildes B, Gordon I, . Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. PMID: 12130606.12130606
10. Goldberg SE, van der Wardt V, Brand A, . Promoting activity, Independence and stability in early dementia (PrAISED): a, multisite, randomised controlled, feasibility trial. BMC Geriatrics. 2019;19(1):353. PMID: 31842828. 10.1186/s12877-019-1379-5 31842828
  a. Harwood RH, van der Wardt V, Goldberg SE, . A development study and randomised feasibility trial of a tailored intervention to improve activity and reduce falls in older adults with mild cognitive impairment and mild dementia. Pilot feasibility stud. 2018;4:49. PMID: 29468084. 10.1186/s40814-018-0239-y 29468084
11. Karinkanta S, Kannus P, Uusi-Rasi K, . Combined resistance and balance-jumping exercise reduces older women’s injurious falls and fractures: 5-year follow-up study. Age Ageing. 2015;44(5):784–9. PMID: 25990940. 10.1093/ageing/afv064 25990940
  a. Karinkanta S, Heinonen A, Sievanen H, . A multi-component exercise regimen to prevent functional decline and bone fragility in home-dwelling elderly women: randomized, controlled trial. Osteoporos Int. 2007;18(4):453–62. PMID: 17103296. 10.1007/s00198-006-0256-1 17103296
  b. Karinkanta S, Nupponen R, Heinonen A, . Effects of exercise on health-related quality of life and fear of falling in home-dwelling older women. J Aging Phys Act. 2012;20(2):198–214. PMID: 22472580.22472580
12. Korpelainen R, Keinanen-Kiukaanniemi S, Heikkinen J, . Effect of impact exercise on bone mineral density in elderly women with low BMD: a population-based randomized controlled 30-month intervention. Osteoporos Int. 2006;17(1):109–18. PMID: 15889312. 10.1007/s00198-005-1924-2 15889312
  a. Korpelainen R, Keinanen-Kiukaanniemi S, Nieminen P, . Long-term outcomes of exercise: follow-up of a randomized trial in older women with osteopenia. Arch Intern Med. 2010;170(17):1548–56. PMID: 20876406. 10.1001/archinternmed.2010.311 20876406
13. Kovacs E, Prokai L, Meszaros L, . Adapted physical activity is beneficial on balance, functional mobility, quality of life and fall risk in community-dwelling older women: a randomized single-blinded controlled trial. Eur J Phys Rehabil Med. 2013;49(3):301–10. PMID: 23486300.23486300
14. Kronhed AG, Hallberg I, –dkvist L, . Effect of training on health-related quality of life, pain and falls in osteoporotic women. Adv Physiother. 2009;11(3):154–65. PMID: None.
15. Lamb SE, Mistry D, Alleyne S, . Aerobic and strength training exercise programme for cognitive impairment in people with mild to moderate dementia: the DAPA RCT. Health Technology Assessment (Winchester, England). 2018;22(28):1–202. PMID: 29848412. 10.3310/hta22280 29848412
16. Lipsitz LA, Macklin EA, Travison TG, . A Cluster Randomized Trial of Tai Chi vs Health Education in Subsidized Housing: The MI-WiSH Study. Journal of the American Geriatrics Society. 2019;67(9):1812–9. PMID: 31116883. 10.1111/jgs.15986 31116883
  a. Wayne PM, Gagnon MM, Macklin EA, . The Mind Body-Wellness in Supportive Housing (Mi-WiSH) study: Design and rationale of a cluster randomized controlled trial of Tai Chi in senior housing. Contemporary Clinical Trials. 2017;60:96–104. PMID: 28694204. 10.1016/j.cct.2017.07.005 28694204
17. Logghe IH, Zeeuwe PE, Verhagen AP, . Lack of effect of Tai Chi Chuan in preventing falls in elderly people living at home: a randomized clinical trial. J Am Geriatr Soc. 2009;57(1):70–5. PMID: 19054193. 10.1111/j.1532-5415.2008.02064.x 19054193
  a. Logghe IH, Verhagen AP, Rademaker AC, . Explaining the ineffectiveness of a Tai Chi fall prevention training for community-living older people: a process evaluation alongside a randomized clinical trial (RCT). Arch Gerontol Geriatr. 2011;52(3):357–62. PMID: 20965096. 10.1016/j.archger.2010.05.013 20965096
18. Luukinen H, Lehtola S, Jokelainen J, . Pragmatic exercise-oriented prevention of falls among the elderly: a population-based, randomized, controlled trial. Prev Med. 2007;44(3):265–71. PMID: 17174387. 10.1016/j.ypmed.2006.09.011 17174387
19. Merom D, Mathieu E, Cerin E, . Social Dancing and Incidence of Falls in Older Adults: A Cluster Randomised Controlled Trial. PLoS Medicine / Public Library of Science. 2016;13(8):e1002112. PMID: 27575534. 10.1371/journal.pmed.1002112 27575534
20. Miko I, Szerb I, Szerb A, . Effect of a balance-training programme on postural balance, aerobic capacity and frequency of falls in women with osteoporosis: A randomized controlled trial. J Rehabil Med. 2018;50(6):542–7. PMID: 29767227. 10.2340/16501977-2349 29767227
21. Morgan RO, Virnig BA, Duque M, . Low-intensity exercise and reduction of the risk for falls among at-risk elders. J Gerontol A Biol Sci Med Sci. 2004;59(10):1062–7. PMID: 15528779.15528779
22. Ng TP, Feng L, Nyunt MS, . Nutritional, Physical, Cognitive, and Combination Interventions and Frailty Reversal Among Older Adults: A Randomized Controlled Trial. Am J Med. 2015. PMID: 26159634. 10.1016/j.amjmed.2015.06.017 26159634
23. Ohman H, Savikko N, Strandberg T, . Effects of Exercise on Functional Performance and Fall Rate in Subjects with Mild or Advanced Alzheimer’s Disease: Secondary Analyses of a Randomized Controlled Study. Dement Geriatr Cogn Disord. 2016;41(3–4):233–41. PMID: 27160164. 10.1159/000445712 27160164
  a. Pitkala KH, Poysti MM, Laakkonen ML, . Effects of the Finnish Alzheimer disease exercise trial (FINALEX): a randomized controlled trial. JAMA Intern Med. 2013;173(10):894–901. PMID: 23589097. 10.1001/jamainternmed.2013.359 23589097
  b. Pitkala KH, Raivio MM, Laakkonen ML, . Exercise rehabilitation on home-dwelling patients with Alzheimer’s disease--a randomized, controlled trial. Study protocol. Trials. 2010;11:92. PMID: 20925948. 10.1186/1745-6215-11-92 20925948
24. Oliveira JS, Sherrington C, Paul SS, . A combined physical activity and fall prevention intervention improved mobility-related goal attainment but not physical activity in older adults: a randomised trial. J Physiother. 2019;65(1):16–22. PMID: 30581138. 10.1016/j.jphys.2018.11.005 30581138
  a. Tiedemann A, Paul S, Ramsay E, . What is the effect of a combined physical activity and fall prevention intervention enhanced with health coaching and pedometers on older adults’ physical activity levels and mobility-related goals? Study protocol for a randomised controlled trial. BMC Public Health. 2015;15:477. PMID: 25956926. 10.1186/s12889-015-1380-7 25956926
25. Rikkonen T, Sund R, Koivumaa-Honkanen H, . Effectiveness of exercise on fall prevention in community-dwelling older adults: a 2-year randomized controlled study of 914 women. Age & Ageing. 2023;52(4):01. PMID: 37097767. 10.1093/ageing/afad059 37097767
26. Robertson MC, Devlin N, Gardner MM, . Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls. 1: Randomised controlled trial. BMJ. 2001;322(7288):697–701. PMID: 11264206.11264206
27. Rosado H, Bravo J, Raimundo A, . Effects of two 24-week multimodal exercise programs on reaction time, mobility, and dual-task performance in community-dwelling older adults at risk of falling: a randomized controlled trial. BMC Public Health. 2021;21(Suppl 2):408. PMID: 34758759. 10.1186/s12889-021-10448-x 34758759
  a. Rosado H, Bravo J, Raimundo A, . Can two multimodal psychomotor exercise programs improve attention, affordance perception, and balance in community dwellings at risk of falling? A randomized controlled trial. BMC Public Health. 2022;21(Suppl 2):2336. PMID: 35818044. 10.1186/s12889-022-13725-5 35818044
28. Sherrington C, Lord SR, Vogler CM, . A post-hospital home exercise program improved mobility but increased falls in older people: a randomised controlled trial. PLoS ONE. 2014;9(9):e104412. PMID: 25180702. 10.1371/journal.pone.0104412 25180702
29. Siegrist M, Freiberger E, Geilhof B, . Fall Prevention in a Primary Care Setting. Dtsch. 2016;113(21):365–72. PMID: 27504699. 10.3238/arztebl.2016.0365 27504699
  a. Blank WA, Freiberger E, Siegrist M, . An interdisciplinary intervention to prevent falls in community-dwelling elderly persons: protocol of a cluster-randomized trial [PreFalls]. BMC Geriatr. 2011;11:7. PMID: 21329525. 10.1186/1471-2318-11-7 21329525
  b. Hentschke C, Halle M, Geilhof B, . 24-Months Cluster-Randomized Intervention Trial of a Targeted Fall Prevention Program in a Primary Care Setting. Journal of General Internal Medicine. 2021;08:08. PMID: 34240282. 10.1007/s11606-021-06944-w 34240282
30. Stathi A, Greaves CJ, Thompson JL, . Effect of a physical activity and behaviour maintenance programme on functional mobility decline in older adults: the REACT (Retirement in Action) randomised controlled trial. Lancet Public Health. 2022;7(4):e316–e26. PMID: 35325627. 10.1016/S2468-2667(22)00004-4 35325627
  a. Stathi A, Withall J, Greaves CJ, . A community-based physical activity intervention to prevent mobility-related disability for retired older people (REtirement in ACTion (REACT)): study protocol for a randomised controlled trial. Trials. 2018;19(1):228. PMID: 29665854. 10.1186/s13063-018-2603-x 29665854
31. Suikkanen S, Soukkio P, Aartolahti E, . Effect of 12-Month Supervised, Home-Based Physical Exercise on Functioning Among Persons With Signs of Frailty: A Randomized Controlled Trial. Archives of Physical Medicine & Rehabilitation. 2021;102(12):2283–90. PMID: 34283997. 10.1016/j.apmr.2021.06.017 34283997
  a. Soukkio P, Suikkanen S, Kaaria S, . Effects of 12-month home-based physiotherapy on duration of living at home and functional capacity among older persons with signs of frailty or with a recent hip fracture - protocol of a randomized controlled trial (HIPFRA study). BMC Geriatrics. 2018;18(1):232. PMID: 30285645. 10.1186/s12877-018-0916-y 30285645
  b. Suikkanen SA, Soukkio PK, Aartolahti EM, . Effects of Home-Based Physical Exercise on Days at Home and Cost-Effectiveness in Pre-Frail and Frail Persons: Randomized Controlled Trial. J Am Med Dir Assoc. 2021;22(4):773–9. PMID: 32694001. 10.1016/j.jamda.2020.06.005 32694001
32. Tomita M, Fisher N, Ramsey D, . Effects of Virtual-Group Exercise at Home (V-GEAH) on Adherence and Fall Risks in Older Adults with a History of Falling. Gerontology Geriatr Res. 2016;2(3):1018.
  a. Tomita MR, Fisher NM, Ramsey D, . Follow-Up of a Virtual-Group-Exercise at Home Program to Reduce Fall Risks. Journal of the American Geriatrics Society. 2019;67(9):1981–3. PMID: 31206588. 10.1111/jgs.15992 31206588
33. Trombetti A, Hars M, Herrmann FR, . Effect of music-based multitask training on gait, balance, and fall risk in elderly people: a randomized controlled trial. Arch Intern Med. 2011;171(6):525–33. PMID: 21098340. 10.1001/archinternmed.2010.446 21098340
34. Tuvemo Johnson S, Anens E, Johansson AC, . The Otago Exercise Program With or Without Motivational Interviewing for Community-Dwelling Older Adults: A 12-Month Follow-Up of a Randomized, Controlled Trial. J Appl Gerontol. 2021;40(3):289–99. PMID: 32114877. 10.1177/0733464820902652 32114877
  a. Arkkukangas M, Johnson ST, Hellstrom K, . Fall Prevention Exercises With or Without Behavior Change Support for Community-Dwelling Older Adults: A Two-Year Follow-Up of a Randomized Controlled Trial. J Aging Phys Act. 2019/06/13 ed2019. p. 34–41. PMID: 31188707. 10.1123/japa.2019-0116 31188707
  b. Arkkukangas M, Soderlund A, Eriksson S, . One-Year Adherence to the Otago Exercise Program With or Without Motivational Interviewing in Community-Dwelling Older Adults. J Aging Phys Activity. 2018;26(3):390–5. PMID: 28952864. 10.1123/japa.2017-0009 28952864
  c. Arkkukangas M, Soderlund A, Eriksson S, . Fall Preventive Exercise With or Without Behavior Change Support for Community-Dwelling Older Adults: A Randomized Controlled Trial With Short-Term Follow-up. Journal of Geriatric Physical Therapy. 2019;42(1):9–17. PMID: 28244890. 10.1519/JPT.0000000000000129 28244890
35. Uusi-Rasi K, Patil R, Karinkanta S, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 2015;175(5):703–11. PMID: 25799402. 10.1001/jamainternmed.2015.0225 25799402
  a. Uusi-Rasi K, Kannus P, Karinkanta S, . Study protocol for prevention of falls: a randomized controlled trial of effects of vitamin D and exercise on falls prevention. BMC Geriatr. 2012;12:12. PMID: 22448872. 10.1186/1471-2318-12-12 22448872
  b. Uusi-Rasi K, Patil R, Karinkanta S, . A 2-Year Follow-Up After a 2-Year RCT with Vitamin D and Exercise: Effects on Falls, Injurious Falls and Physical Functioning Among Older Women. J Gerontol A Biol Sci Med Sci. 2017;72(9):1239–45. PMID: 28369286. 10.1093/gerona/glx044 28369286
  c. Patil R, Karinkanta S, Tokola K, . Effects of Vitamin D and Exercise on the Wellbeing of Older Community-Dwelling Women: A Randomized Controlled Trial. Gerontology. 2016;62(4):401–8. PMID: 26682749. 10.1159/000442441 26682749
36. Voukelatos A, Cumming RG, Lord SR, . A randomized, controlled trial of tai chi for the prevention of falls: the Central Sydney tai chi trial. J Am Geriatr Soc. 2007;55(8):1185–91. PMID: 17661956. 10.1111/j.1532-5415.2007.01244.x 17661956
37. Voukelatos A, Merom D, Sherrington C, . The impact of a home-based walking programme on falls in older people: the Easy Steps randomised controlled trial. Age Ageing. 2015;44(3):377–83. PMID: 25572426. 10.1093/ageing/afu186 25572426
  a. Voukelatos A, Merom D, Rissel C, . The effect of walking on falls in older people: the ‘Easy Steps to Health’ randomized controlled trial study protocol. BMC Public Health. 2011;11:888. PMID: 22115340. 10.1186/1471-2458-11-888 22115340

### Exercise + Education +

1. Daly RM, Gianoudis J, Kersh ME, . Effects of a 12-Month Supervised, Community-Based, Multimodal Exercise Program Followed by a 6-Month Research-to-Practice Transition on Bone Mineral Density, Trabecular Microarchitecture, and Physical Function in Older Adults: A Randomized Controlled Trial. Journal of Bone & Mineral Research. 2020;35(3):419–29. PMID: 31498937. 10.1002/jbmr.3865 31498937
  a. Gianoudis J, Bailey CA, Ebeling PR, . Effects of a targeted multimodal exercise program incorporating high-speed power training on falls and fracture risk factors in older adults: a community-based randomized controlled trial. J Bone Miner Res. 2014;29(1):182–91. PMID: 23775701. 10.1002/jbmr.2014 23775701
  b. Gianoudis J, Bailey CA, Sanders KM, . Osteo-cise: strong bones for life: protocol for a community-based randomised controlled trial of a multi-modal exercise and osteoporosis education program for older adults at risk of falls and fractures. BMC Musculoskelet Disord. 2012;13:78. PMID: 22640372. 10.1186/1471-2474-13-78 22640372
  c. Talevski J, Gianoudis J, Bailey CA, . Effects of an 18-month community-based, multifaceted, exercise program on patient-reported outcomes in older adults at risk of fracture: secondary analysis of a randomised controlled trial. Osteoporosis International. 2023;34(5):891–900. PMID: 36862193. 10.1007/s00198-023-06693-y 36862193
2. Sherrington C, Fairhall N, Kirkham C, . Exercise to Reduce Mobility Disability and Prevent Falls After Fall-Related Leg or Pelvic Fracture: RESTORE Randomized Controlled Trial. Journal of General Internal Medicine. 2020;35(10):2907–16. PMID: 32016702. 10.1007/s11606-020-05666-9 32016702
  a. Sherrington C, Fairhall N, Kirkham C, . Exercise and fall prevention self-management to reduce mobility-related disability and falls after fall-related lower limb fracture in older people: protocol for the RESTORE (Recovery Exercises and STepping On afteR fracturE) randomised controlled trial. BMC Geriatrics. 2016;16:34. PMID: 26838998. 10.1186/s12877-016-0206-5 26838998
3. Shumway-Cook A, Silver I, Mary L, . Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. J Gerontol A Biol Sci Med Sci. 2007;62(12):1420–7. PMID: 18166695.18166695
4. Smulders E, Weerdesteyn V, Groen BE, . Efficacy of a short multidisciplinary falls prevention program for elderly persons with osteoporosis and a fall history: a randomized controlled trial. Arch Phys Med Rehabil. 2010;91(11):1705–11. PMID: 21044715. 10.1016/j.apmr.2010.08.004 21044715

### Exercise + Environment

1. Fitzharris MP, Day L, Lord SR, . The Whitehorse NoFalls trial: effects on fall rates and injurious fall rates. Age Ageing. 2010;39(6):728–33. PMID: 20817936. 10.1093/ageing/afq109 20817936
  a. Day L, Fildes B, Gordon I, . Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. PMID: 12130606.12130606
2. Matchar DB, Duncan PW, Lien CT, . Randomized Controlled Trial of Screening, Risk Modification, and Physical Therapy to Prevent Falls Among the Elderly Recently Discharged From the Emergency Department to the Community: The Steps to Avoid Falls in the Elderly Study. Archives of Physical Medicine & Rehabilitation. 2017;98(6):1086–96. PMID: 28202383. 10.1016/j.apmr.2017.01.014 28202383
3. Taylor ME, Wesson J, Sherrington C, . Tailored Exercise and Home Hazard Reduction Program for Fall Prevention in Older People With Cognitive Impairment: The i-FOCIS Randomized Controlled Trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2021;76(4):655–65. PMID: 32949456. 10.1093/gerona/glaa241 32949456

### Environment

1. Chu MM, Fong KN, Lit AC, . An Occupational Therapy Fall Reduction Home Visit Program for Community-Dwelling Older Adults in Hong Kong After an Emergency Department Visit for a Fall. Journal of the American Geriatrics Society. 2017;65(2):364–72. PMID: 27858951. 10.1111/jgs.14527 27858951
2. Cockayne S, Pighills A, Adamson J, . Home environmental assessments and modification delivered by occupational therapists to reduce falls in people aged 65 years and over: the OTIS RCT. Health Technol Assess. 2021;25(46):1–118. PMID: 34254934. 10.3310/hta25460 34254934
  a. Cockayne S, Pighills A, Adamson J, . Can occupational therapist-led home environmental assessment prevent falls in older people? A modified cohort randomised controlled trial protocol. BMJ Open. 2018;8(9):e022488. PMID: 30206086. 10.1136/bmjopen-2018-022488 30206086
  b. Cockayne S, Pighills A, Fairhurst C, . Home hazard assessment and environmental modification to prevent falls in older people: the OTIS trial. F1000Res. 2021;25 June 2021:1–18. 10.12688/f1000research.52313.1 34316353
3. Fitzharris MP, Day L, Lord SR, . The Whitehorse NoFalls trial: effects on fall rates and injurious fall rates. Age Ageing. 2010;39(6):728–33. PMID: 20817936. 10.1093/ageing/afq109 20817936
  a. Day L, Fildes B, Gordon I, . Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. PMID: 12130606.12130606
4. Pighills AC, Torgerson DJ, Sheldon TA, . Environmental assessment and modification to prevent falls in older people.[Erratum appears in J Am Geriatr Soc. 2011 Apr;59(4):776]. J Am Geriatr Soc. 2011;59(1):26–33. PMID: 21226674. 10.1111/j.1532-5415.2010.03221.x 21226674
5. Stark S, Keglovits M, Somerville E, . Home Hazard Removal to Reduce Falls Among Community-Dwelling Older Adults: A Randomized Clinical Trial. JAMA netw. 2021;4(8):e2122044. PMID: 34463746. 10.1001/jamanetworkopen.2021.22044 34463746
  a. Stark S, Somerville E, Keglovits M, . Protocol for the home hazards removal program (HARP) study: a pragmatic, randomized clinical trial and implementation study. BMC Geriatrics. 2017;17(1):90. PMID: 28427336. 10.1186/s12877-017-0478-4 28427336
6. Stevens M, Holman CD, Bennett N, . Preventing falls in older people: outcome evaluation of a randomized controlled trial. J Am Geriatr Soc. 2001;49(11):1448–55. PMID: 11890582.11890582

### Medication Review/Modification

1. Blalock SJ, Casteel C, Roth MT, . Impact of enhanced pharmacologic care on the prevention of falls: a randomized controlled trial. Am J Geriatr Pharmacother. 2010;8(5):428–40. PMID: 21335296. 10.1016/j.amjopharm.2010.09.002 21335296
2. Boye ND, van der Velde N, de Vries OJ, . Effectiveness of medication withdrawal in older fallers: results from the Improving Medication Prescribing to reduce Risk Of FALLs (IMPROveFALL) trial. Age & Ageing. 2017;46(1):142–6. PMID: 28181639. 10.1093/ageing/afw161 28181639
  a. Hartholt KA, Boye ND, Van der Velde N, . [Cost] effectiveness of withdrawal of fall-risk increasing drugs versus conservative treatment in older fallers: design of a multicenter randomized controlled trial (IMPROveFALL-study). BMC Geriatr. 2011;11:48. PMID: 21854643. 10.1186/1471-2318-11-48 21854643
  b. Polinder S, Boye ND, Mattace-Raso FU, . Cost-utility of medication withdrawal in older fallers: results from the improving medication prescribing to reduce risk of FALLs (IMPROveFALL) trial. BMC Geriatrics. 2016;16(1):179. PMID: 27809792.27809792
3. Mott DA, Martin B, Breslow R, . Impact of a medication therapy management intervention targeting medications associated with falling: Results of a pilot study. J Am Pharm Assoc (2003). 2016;56(1):22–8. PMID: 26802916. 10.1016/j.japh.2015.11.001 26802916
  a. Mott D, Martin B, Breslow R, . The development of a community-based, pharmacistprovided falls prevention MTM intervention for older adults: Relationship building, methods, and rationale. Inov Pharm. 2014;5(1):140. PMID: 25309809.25309809
4. Romskaug R, Skovlund E, Straand J, . Effect of Clinical Geriatric Assessments and Collaborative Medication Reviews by Geriatrician and Family Physician for Improving Health-Related Quality of Life in Home-Dwelling Older Patients Receiving Polypharmacy: A Cluster Randomized Clinical Trial. JAMA Intern Med. 2020;180(2):181–9. PMID: 31617562. 10.1001/jamainternmed.2019.5096 31617562
  a. Romskaug R, Molden E, Straand J, . Cooperation between geriatricians and general practitioners for improved pharmacotherapy in home-dwelling elderly people receiving polypharmacy - the COOP Study: study protocol for a cluster randomised controlled trial. Trials [Electronic Resource]. 2017;18(1):158. PMID: 28372591. 10.1186/s13063-017-1900-0 28372591

### Psychological

1. Dorresteijn TA, Zijlstra GA, Ambergen AW, . Effectiveness of a home-based cognitive behavioral program to manage concerns about falls in community-dwelling, frail older people: results of a randomized controlled trial.[Erratum appears in BMC Geriatr. 2016;16:108; PMID: 27220990]. BMC Geriatr. 2016;16:2. PMID: 26739339. 10.1186/s12877-015-0177-y 26739339
  a. Dorresteijn TA, Rixt Zijlstra GA, Van Haastregt JC, . Feasibility of a nurse-led in-home cognitive behavioral program to manage concerns about falls in frail older people: a process evaluation. Res Nurs Health. 2013;36(3):257–70. PMID: 23533013. 10.1002/nur.21534 23533013
  b. Dorresteijn TA, Zijlstra GA, Delbaere K, . Evaluating an in-home multicomponent cognitive behavioural programme to manage concerns about falls and associated activity avoidance in frail community-dwelling older people: Design of a randomised control trial [NCT01358032]. BMC Health Serv Res. 2011;11:228. PMID: 21933436. 10.1186/1472-6963-11-228 21933436
2. Lim ML, Tran M, van Schooten KS, . A Self-Guided Online Cognitive Behavioural Therapy to Reduce Fear of Falling in Older People: a Randomised Controlled Trial. Int J Behav Med. 2022;02:02. PMID: 35655058. 10.1007/s12529-022-10105-6 35655058
3. Zijlstra GA, van Haastregt JC, Ambergen T, . Effects of a multicomponent cognitive behavioral group intervention on fear of falling and activity avoidance in community-dwelling older adults: results of a randomized controlled trial. J Am Geriatr Soc. 2009;57(11):2020–8. PMID: 19793161. 10.1111/j.1532-5415.2009.02489.x 19793161
  a. Kempen GI, Oude Wesselink SF, van Haastregt JC, . Long-term effect on mortality of a multicomponent cognitive behavioural group intervention to reduce fear of falling in older adults: a randomised controlled trial. Age Ageing. 2011;40(4):519–23. PMID: 21551460. 10.1093/ageing/afr041 21551460

### Education

1. Clemson L, Cumming RG, Kendig H, . The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J Am Geriatr Soc. 2004;52(9):1487–94. PMID: 15341550. 10.1111/j.1532-5415.2004.52411.x 15341550

## KEY QUESTION 2

### Multifactorial

1. Bruce J, Hossain A, Lall R, . Fall prevention interventions in primary care to reduce fractures and falls in people aged 70 years and over: the PreFIT three-arm cluster RCT. Health Technol Assess. 2021;25(34):1–114. PMID: 34075875. 10.3310/hta25340 34075875
  a. Bruce J, Lall R, Withers EJ, . A cluster randomised controlled trial of advice, exercise or multifactorial assessment to prevent falls and fractures in community-dwelling older adults: protocol for the prevention of falls injury trial (PreFIT). BMJ Open. 2016;6(1):e009362. PMID: 26781504. 10.1136/bmjopen-2015-009362 26781504
  b. Bruce J, Ralhan S, Sheridan R, . The design and development of a complex multifactorial falls assessment intervention for falls prevention: The Prevention of Falls Injury Trial (PreFIT). BMC Geriatrics. 2017;17(1):116. PMID: 28571563. 10.1186/s12877-017-0492-6 28571563
  c. Finnegan S, Bruce J, Skelton DA, . Development and delivery of an exercise programme for falls prevention: the Prevention of Falls Injury Trial (PreFIT). Physiotherapy. 2018;104(1):72–9. PMID: 28801033. 10.1016/j.physio.2017.06.004 28801033
  d. Lamb SE, Bruce J, Hossain A, . Screening and Intervention to Prevent Falls and Fractures in Older People. New England Journal of Medicine. 2020;383(19):1848–59. PMID: 33211928. 10.1056/NEJMoa2001500 33211928
2. Fairhall N, Sherrington C, Lord SR, . Effect of a multifactorial, interdisciplinary intervention on risk factors for falls and fall rate in frail older people: a randomised controlled trial. Age Ageing. 2014;43(5):616–22. PMID: 24381025. 10.1093/ageing/aft204 24381025
  a. Fairhall N, Aggar C, Kurrle SE, . Frailty Intervention Trial (FIT). BMC Geriatr. 2008;8:27. PMID: 18851754. 10.1186/1471-2318-8-27 18851754
  b. Fairhall N, Sherrington C, Cameron ID, . A multifactorial intervention for frail older people is more than twice as effective among those who are compliant: complier average causal effect analysis of a randomised trial. J Physiother. 2017;63(1):40–4. PMID: 27993489. 10.1016/j.jphys.2016.11.007 27993489
  c. Ferrer A, Formiga F, Sanz H, . Multifactorial assessment and targeted intervention to reduce falls among the oldest-old: a randomized controlled trial. Clin Interv Aging. 2014;9:383–93. PMID: 24596458. 10.2147/CIA.S57580 24596458
3. Hendriks MR, Bleijlevens MH, van Haastregt JC, . Lack of effectiveness of a multidisciplinary fall-prevention program in elderly people at risk: a randomized, controlled trial. J Am Geriatr Soc. 2008;56(8):1390–7. PMID: 18662214. 10.1111/j.1532-5415.2008.01803.x 18662214
4. Salminen MJ, Vahlberg TJ, Salonoja MT, . Effect of a risk-based multifactorial fall prevention program on the incidence of falls. J Am Geriatr Soc. 2009;57(4):612–9. PMID: 19392952. 10.1111/j.1532-5415.2009.02176.x 19392952
  a. Salminen M, Vahlberg T, Kivela SL. The long-term effect of a multifactorial fall prevention programme on the incidence of falls requiring medical treatment. Public Health. 2009;123(12):809–13. PMID: 19958918. 10.1016/j.puhe.2009.10.018 19958918
5. Tinetti ME, Baker DI, McAvay G, . A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331(13):821–7. PMID: 8078528. 10.1056/NEJM199409293311301 8078528

### Exercise

1. Bruce J, Hossain A, Lall R, . Fall prevention interventions in primary care to reduce fractures and falls in people aged 70 years and over: the PreFIT three-arm cluster RCT. Health Technol Assess. 2021;25(34):1–114. PMID: 34075875. 10.3310/hta25340 34075875
  a. Bruce J, Lall R, Withers EJ, . A cluster randomised controlled trial of advice, exercise or multifactorial assessment to prevent falls and fractures in community-dwelling older adults: protocol for the prevention of falls injury trial (PreFIT). BMJ Open. 2016;6(1):e009362. PMID: 26781504. 10.1136/bmjopen-2015-009362 26781504
  b. Bruce J, Ralhan S, Sheridan R, . The design and development of a complex multifactorial falls assessment intervention for falls prevention: The Prevention of Falls Injury Trial (PreFIT). BMC Geriatrics. 2017;17(1):116. PMID: 28571563. 10.1186/s12877-017-0492-6 28571563
  c. Finnegan S, Bruce J, Skelton DA, . Development and delivery of an exercise programme for falls prevention: the Prevention of Falls Injury Trial (PreFIT). Physiotherapy. 2018;104(1):72–9. PMID: 28801033. 10.1016/j.physio.2017.06.004 28801033
  d. Lamb SE, Bruce J, Hossain A, . Screening and Intervention to Prevent Falls and Fractures in Older People. New England Journal of Medicine. 2020;383(19):1848–59. PMID: 33211928. 10.1056/NEJMoa2001500 33211928
2. Callisaya ML, Jayakody O, Vaidya A, . A novel cognitive-motor exercise program delivered via a tablet to improve mobility in older people with cognitive impairment - StandingTall Cognition and Mobility. Exp Gerontol. 2021;152:111434. PMID: 34098009. 10.1016/j.exger.2021.111434 34098009
3. Delbaere K, Valenzuela T, Lord SR, . E-health StandingTall balance exercise for fall prevention in older people: results of a two year randomised controlled trial. BMJ. 2021;373:n740. PMID: 33824131. 10.1136/bmj.n740 33824131
4. El-Khoury F, Cassou B, Latouche A, . Effectiveness of two year balance training programme on prevention of fall induced injuries in at risk women aged 75-85 living in community: Ossebo randomised controlled trial. BMJ. 2015;351:h3830. PMID: 26201510. 10.1136/bmj.h3830 26201510
  a. Dargent-Molina P, El Khoury F, Cassou B. The ‘Ossebo’ intervention for the prevention of injurious falls in elderly women: background and design. Glob Health Promot. 2013;20(2 Suppl):88–93. PMID: 23678502. 10.1177/1757975913483341 23678502
5. Karinkanta S, Kannus P, Uusi-Rasi K, . Combined resistance and balance-jumping exercise reduces older women’s injurious falls and fractures: 5-year follow-up study. Age Ageing. 2015;44(5):784–9. PMID: 25990940. 10.1093/ageing/afv064 25990940
  a. Karinkanta S, Heinonen A, Sievanen H, . A multi-component exercise regimen to prevent functional decline and bone fragility in home-dwelling elderly women: randomized, controlled trial. Osteoporos Int. 2007;18(4):453–62. PMID: 17103296. 10.1007/s00198-006-0256-1 17103296
  b. Karinkanta S, Nupponen R, Heinonen A, . Effects of exercise on health-related quality of life and fear of falling in home-dwelling older women. J Aging Phys Act. 2012;20(2):198–214. PMID: 22472580.22472580
6. Lamb SE, Mistry D, Alleyne S, . Aerobic and strength training exercise programme for cognitive impairment in people with mild to moderate dementia: the DAPA RCT. Health Technology Assessment (Winchester, England). 2018;22(28):1–202. PMID: 29848412. 10.3310/hta22280 29848412
7. Lipsitz LA, Macklin EA, Travison TG, . A Cluster Randomized Trial of Tai Chi vs Health Education in Subsidized Housing: The MI-WiSH Study. Journal of the American Geriatrics Society. 2019;67(9):1812–9. PMID: 31116883. 10.1111/jgs.15986 31116883
  a. Wayne PM, Gagnon MM, Macklin EA, . The Mind Body-Wellness in Supportive Housing (Mi-WiSH) study: Design and rationale of a cluster randomized controlled trial of Tai Chi in senior housing. Contemporary Clinical Trials. 2017;60:96–104. PMID: 28694204. 10.1016/j.cct.2017.07.005 28694204
8. Merom D, Mathieu E, Cerin E, . Social Dancing and Incidence of Falls in Older Adults: A Cluster Randomised Controlled Trial. PLoS Medicine / Public Library of Science. 2016;13(8):e1002112. PMID: 27575534. 10.1371/journal.pmed.1002112 27575534
9. Miko I, Szerb I, Szerb A, . Effect of a balance-training programme on postural balance, aerobic capacity and frequency of falls in women with osteoporosis: A randomized controlled trial. J Rehabil Med. 2018;50(6):542–7. PMID: 29767227. 10.2340/16501977-2349 29767227
10. Ng TP, Feng L, Nyunt MS, . Nutritional, Physical, Cognitive, and Combination Interventions and Frailty Reversal Among Older Adults: A Randomized Controlled Trial. Am J Med. 2015. PMID: 26159634. 10.1016/j.amjmed.2015.06.017 26159634
11. Oliveira JS, Sherrington C, Paul SS, . A combined physical activity and fall prevention intervention improved mobility-related goal attainment but not physical activity in older adults: a randomised trial. J Physiother. 2019;65(1):16–22. PMID: 30581138. 10.1016/j.jphys.2018.11.005 30581138
  a. Tiedemann A, Paul S, Ramsay E, . What is the effect of a combined physical activity and fall prevention intervention enhanced with health coaching and pedometers on older adults’ physical activity levels and mobility-related goals? Study protocol for a randomised controlled trial. BMC Public Health. 2015;15:477. PMID: 25956926. 10.1186/s12889-015-1380-7 25956926
12. Rikkonen T, Sund R, Koivumaa-Honkanen H, . Effectiveness of exercise on fall prevention in community-dwelling older adults: a 2-year randomized controlled study of 914 women. Age & Ageing. 2023;52(4):01. PMID: 37097767. 10.1093/ageing/afad059 37097767
13. Sherrington C, Lord SR, Vogler CM, . A post-hospital home exercise program improved mobility but increased falls in older people: a randomised controlled trial. PLoS ONE. 2014;9(9):e104412. PMID: 25180702. 10.1371/journal.pone.0104412 25180702
14. Siegrist M, Freiberger E, Geilhof B, . Fall Prevention in a Primary Care Setting. Dtsch. 2016;113(21):365–72. PMID: 27504699. 10.3238/arztebl.2016.0365 27504699
  a. Blank WA, Freiberger E, Siegrist M, . An interdisciplinary intervention to prevent falls in community-dwelling elderly persons: protocol of a cluster-randomized trial [PreFalls]. BMC Geriatr. 2011;11:7. PMID: 21329525. 10.1186/1471-2318-11-7 21329525
  b. Hentschke C, Halle M, Geilhof B, . 24-Months Cluster-Randomized Intervention Trial of a Targeted Fall Prevention Program in a Primary Care Setting. Journal of General Internal Medicine. 2021;08:08. PMID: 34240282. 10.1007/s11606-021-06944-w 34240282
15. Stathi A, Greaves CJ, Thompson JL, . Effect of a physical activity and behaviour maintenance programme on functional mobility decline in older adults: the REACT (Retirement in Action) randomised controlled trial. Lancet Public Health. 2022;7(4):e316–e26. PMID: 35325627. 10.1016/S2468-2667(22)00004-4 35325627
  a. Stathi A, Withall J, Greaves CJ, . A community-based physical activity intervention to prevent mobility-related disability for retired older people (REtirement in ACTion (REACT)): study protocol for a randomised controlled trial. Trials. 2018;19(1):228. PMID: 29665854. 10.1186/s13063-018-2603-x 29665854
16. Suikkanen S, Soukkio P, Aartolahti E, . Effect of 12-Month Supervised, Home-Based Physical Exercise on Functioning Among Persons With Signs of Frailty: A Randomized Controlled Trial. Archives of Physical Medicine & Rehabilitation. 2021;102(12):2283–90. PMID: 34283997. 10.1016/j.apmr.2021.06.017 34283997
  a. Soukkio P, Suikkanen S, Kaaria S, . Effects of 12-month home-based physiotherapy on duration of living at home and functional capacity among older persons with signs of frailty or with a recent hip fracture - protocol of a randomized controlled trial (HIPFRA study). BMC Geriatrics. 2018;18(1):232. PMID: 30285645. 10.1186/s12877-018-0916-y 30285645
  b. Suikkanen SA, Soukkio PK, Aartolahti EM, . Effects of Home-Based Physical Exercise on Days at Home and Cost-Effectiveness in Pre-Frail and Frail Persons: Randomized Controlled Trial. J Am Med Dir Assoc. 2021;22(4):773–9. PMID: 32694001. 10.1016/j.jamda.2020.06.005 32694001
17. Trombetti A, Hars M, Herrmann FR, . Effect of music-based multitask training on gait, balance, and fall risk in elderly people: a randomized controlled trial. Arch Intern Med. 2011;171(6):525–33. PMID: 21098340. 10.1001/archinternmed.2010.446 21098340
18. Tuvemo Johnson S, Anens E, Johansson AC, . The Otago Exercise Program With or Without Motivational Interviewing for Community-Dwelling Older Adults: A 12-Month Follow-Up of a Randomized, Controlled Trial. J Appl Gerontol. 2021;40(3):289–99. PMID: 32114877. 10.1177/0733464820902652 32114877
  a. Arkkukangas M, Johnson ST, Hellstrom K, . Fall Prevention Exercises With or Without Behavior Change Support for Community-Dwelling Older Adults: A Two-Year Follow-Up of a Randomized Controlled Trial. J Aging Phys Act. 2019/06/13 ed2019. p. 34–41. PMID: 31188707. 10.1123/japa.2019-0116 31188707
  b. Arkkukangas M, Soderlund A, Eriksson S, . One-Year Adherence to the Otago Exercise Program With or Without Motivational Interviewing in Community-Dwelling Older Adults. J Aging Phys Activity. 2018;26(3):390–5. PMID: 28952864. 10.1123/japa.2017-0009 28952864
  c. Arkkukangas M, Soderlund A, Eriksson S, . Fall Preventive Exercise With or Without Behavior Change Support for Community-Dwelling Older Adults: A Randomized Controlled Trial With Short-Term Follow-up. Journal of Geriatric Physical Therapy. 2019;42(1):9–17. PMID: 28244890. 10.1519/JPT.0000000000000129 28244890
19. Uusi-Rasi K, Patil R, Karinkanta S, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 2015;175(5):703–11. PMID: 25799402. 10.1001/jamainternmed.2015.0225 25799402
  a. Uusi-Rasi K, Kannus P, Karinkanta S, . Study protocol for prevention of falls: a randomized controlled trial of effects of vitamin D and exercise on falls prevention. BMC Geriatr. 2012;12:12. PMID: 22448872. 10.1186/1471-2318-12-12 22448872
  b. Uusi-Rasi K, Patil R, Karinkanta S, . A 2-Year Follow-Up After a 2-Year RCT with Vitamin D and Exercise: Effects on Falls, Injurious Falls and Physical Functioning Among Older Women. J Gerontol A Biol Sci Med Sci. 2017;72(9):1239–45. PMID: 28369286. 10.1093/gerona/glx044 28369286
  c. Patil R, Karinkanta S, Tokola K, . Effects of Vitamin D and Exercise on the Wellbeing of Older Community-Dwelling Women: A Randomized Controlled Trial. Gerontology. 2016;62(4):401–8. PMID: 26682749. 10.1159/000442441 26682749

### Exercise + Education +

1. Daly RM, Gianoudis J, Kersh ME, . Effects of a 12-Month Supervised, Community-Based, Multimodal Exercise Program Followed by a 6-Month Research-to-Practice Transition on Bone Mineral Density, Trabecular Microarchitecture, and Physical Function in Older Adults: A Randomized Controlled Trial. Journal of Bone & Mineral Research. 2020;35(3):419–29. PMID: 31498937. 10.1002/jbmr.3865 31498937
  a. Gianoudis J, Bailey CA, Ebeling PR, . Effects of a targeted multimodal exercise program incorporating high-speed power training on falls and fracture risk factors in older adults: a community-based randomized controlled trial. J Bone Miner Res. 2014;29(1):182–91. PMID: 23775701. 10.1002/jbmr.2014 23775701
  b. Gianoudis J, Bailey CA, Sanders KM, . Osteo-cise: strong bones for life: protocol for a community-based randomised controlled trial of a multi-modal exercise and osteoporosis education program for older adults at risk of falls and fractures. BMC Musculoskelet Disord. 2012;13:78. PMID: 22640372. 10.1186/1471-2474-13-78 22640372
2. Sherrington C, Fairhall N, Kirkham C, . Exercise to Reduce Mobility Disability and Prevent Falls After Fall-Related Leg or Pelvic Fracture: RESTORE Randomized Controlled Trial. Journal of General Internal Medicine. 2020;35(10):2907–16. PMID: 32016702. 10.1007/s11606-020-05666-9 32016702
  a. Sherrington C, Fairhall N, Kirkham C, . Exercise and fall prevention self-management to reduce mobility-related disability and falls after fall-related lower limb fracture in older people: protocol for the RESTORE (Recovery Exercises and STepping On afteR fracturE) randomised controlled trial. BMC Geriatrics. 2016;16:34. PMID: 26838998. 10.1186/s12877-016-0206-5 26838998
3. Shumway-Cook A, Silver I, Mary L, . Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. J Gerontol A Biol Sci Med Sci. 2007;62(12):1420–7. PMID: 18166695.18166695
4. Smulders E, Weerdesteyn V, Groen BE, . Efficacy of a short multidisciplinary falls prevention program for elderly persons with osteoporosis and a fall history: a randomized controlled trial. Arch Phys Med Rehabil. 2010;91(11):1705–11. PMID: 21044715. 10.1016/j.apmr.2010.08.004 21044715

### Exercise + Environment

1. Taylor ME, Wesson J, Sherrington C, . Tailored Exercise and Home Hazard Reduction Program for Fall Prevention in Older People With Cognitive Impairment: The i-FOCIS Randomized Controlled Trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2021;76(4):655–65. PMID: 32949456. 10.1093/gerona/glaa241 32949456

### Environment

1. Cockayne S, Pighills A, Adamson J, . Home environmental assessments and modification delivered by occupational therapists to reduce falls in people aged 65 years and over: the OTIS RCT. Health Technol Assess. 2021;25(46):1–118. PMID: 34254934. 10.3310/hta25460 34254934
  a. Cockayne S, Pighills A, Adamson J, . Can occupational therapist-led home environmental assessment prevent falls in older people? A modified cohort randomised controlled trial protocol. BMJ Open. 2018;8(9):e022488. PMID: 30206086. 10.1136/bmjopen-2018-022488 30206086
  b. Cockayne S, Pighills A, Fairhurst C, . Home hazard assessment and environmental modification to prevent falls in older people: the OTIS trial. F1000Res. 2021;25 June 2021:1–18. 10.12688/f1000research.52313.1 34316353
2. Stark S, Keglovits M, Somerville E, . Home Hazard Removal to Reduce Falls Among Community-Dwelling Older Adults: A Randomized Clinical Trial. JAMA netw. 2021;4(8):e2122044. PMID: 34463746. 10.1001/jamanetworkopen.2021.22044 34463746
  a. Stark S, Somerville E, Keglovits M, . Protocol for the home hazards removal program (HARP) study: a pragmatic, randomized clinical trial and implementation study. BMC Geriatrics. 2017;17(1):90. PMID: 28427336. 10.1186/s12877-017-0478-4 28427336

### Psychological

1. Zijlstra GA, van Haastregt JC, Ambergen T, . Effects of a multicomponent cognitive behavioral group intervention on fear of falling and activity avoidance in community-dwelling older adults: results of a randomized controlled trial. J Am Geriatr Soc. 2009;57(11):2020–8. PMID: 19793161. 10.1111/j.1532-5415.2009.02489.x 19793161
  a. Kempen GI, Oude Wesselink SF, van Haastregt JC, . Long-term effect on mortality of a multicomponent cognitive behavioural group intervention to reduce fear of falling in older adults: a randomised controlled trial. Age Ageing. 2011;40(4):519–23. PMID: 21551460. 10.1093/ageing/afr041 21551460