# Appendix B Literature Flow

Appendix B Figure 1 Literature Flow Diagram

*Study may appear in more than one intervention category.

Appendix B Figure 1 shows the literature flow diagram. 5,142 citations were screened. 403 full text articles were assessed for eligibility. 83 trials in 145 publications were included for Key Question 1, and 30 trials studies in 65 publications were included for Key Question 2.