# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Bridge search – Date delivered 5/8/23

Original search – Date delivered 4/22/22

Sources Searched: database and platform 2016 to present
MEDLINE via Ovid
CINAHL via EBSCO
Cochrane Central Register of Controlled Clinical Trials via Wiley

Search filters used:

RCT filter:

- Chris Cooper, Jo Varley-Campbell and Patrice Carter, Established search filters may miss studies when identifying randomized controlled trials, Journal of Clinical Epidemiology, 2019-08-01, Volume 112, Pages 12–19 30986533
- Glanville JM, Lefebvre C, Miles JN, Camoso-Stefinovic J. How to identify randomized controlled trials in MEDLINE: ten years on. Journal of the Medical Library Association 2006; 94: 130–136. https://www.ncbi.nlm.nih.gov/pmc/articles/PMC1435857/ 16636704
- Box 3.d Cochrane Highly Sensitive Search Strategy for identifying randomized trials in MEDLINE: sensitivity- and precision-maximizing version (2008 revision); Ovid format from: Lefebvre C, Glanville J, Briscoe S, Littlewood A, Marshall C, Metzendorf M-I, Noel-Storr A, Rader T, Shokraneh F, Thomas J, Wieland LS. Chapter 4: Searching for and selecting studies. In: Higgins JPT, Thomas J, Chandler J, Cumpston M, Li T, Page MJ, Welch VA (editors). Cochrane Handbook for Systematic Reviews of Interventions version 6.2 (updated February 2021). Cochrane, 2021. Available from www.training.cochrane.org/handbook
- Glanville et al, 2019, Development of a Search Filter to Identify Reports of Controlled Clinical Trials Within CINAHL Plus

Justification for Limits (what studies/papers):

“This search strategy was adopted from/adapted from/.. the strategy used by SEARCH CREATOR/S (year). The following changes were made…”

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword
- kf = author attributed keyword
- st = subset

MEDLINE

Database: Ovid MEDLINE(R) ALL <1946 to April 21, 2022>

Search Strategy:

------------------------------------------------------------

1. Accidental Falls/ (27337)
2. (falls or faller or fallers or fall injur$).ti,ab,kf. (53652)
3. (fall or falling).ti. (14131)
4. 1 or 2 or 3 (72260)
5. aged/ or “aged, 80 and over”/ or frail elderly/ (3393862)
6. Geriatric Assessment/ (31036)
7. Geriatrics/ (31013)
8. Health Services for the Aged/ (18137)
9. geriatric$.ti,ab,kf. (72187)
10. older.ti,ab,kf. (503575)
11. senior$.ti,ab. (46894)
12. elder$.ti,ab,kf. (290222)
13. aged.ti,ab,kf. (663188)
14. 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (4137540)
15. 4 and 14 (32442)
16. limit 15 to (english language and yr="2016 -Current") (12111)
17. (randomized controlled trial or controlled clinical trial).pt. or clinical trials as topic.sh. or exp Randomized Controlled Trials as Topic/ or (randomized or randomised or placebo or randomly or phase iii or phase 3).ti,ab,kf. or trial.ti. (1570961)
18. (RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$).ti,ab,kf. not medline.st. (208715)
19. 17 or 18 (1648512)
20. 16 and 19 (1796)

CINAHL via EBSCO

- S10 S8 AND S9 Limiters - Published Date: 20160101-; English Language
  Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 2,723
- S9 (MH randomized controlled trials) or (MH double-blind studies) or (MH single-blind studies) or (MH random assignment) or (MH pretest-posttest design) or (MH cluster sample) or (TI (randomised OR randomized)) or (AB (random*)) or (TI (trial)) or (MH (sample size) AND AB (assigned OR allocated OR control)) or (MH (placebos)) or (PT (randomized controlled trial)) or (AB (control W5 group)) or (MH (crossover design) OR MH (comparative studies)) or (AB (cluster W3 RCT)) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 949,992
- S8 (S4 AND S7) Expanders - Also search within the full text of the articles; Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 25,638
- S7 S5 OR S6 Expanders - Also search within the full text of the articles; Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 1,173,921
- S6 TI ( geriatric* or older or senior* or elder* or aged ) OR AB ( geriatric* or older or senior* or elder* or aged ) Expanders - Also search within the full text of the articles; Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 503,910
- S5 (MH “Frail Elderly”) OR (MH “Aged”) OR (MH “Aged, 80 and Over”) Expanders - Also search within the full text of the articles; Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 911,333
- S4 S1 OR S2 OR S3 Expanders - Also search within the full text of the articles; Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 57,328
- S3 TI (fall or falling) Expanders - Also search within the full text of the articles; Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 19,265
- S2 TI ( (falls or faller or fallers or fall injur*) ) OR AB ( (falls or faller or fallers or fall injur*) ) Expanders - Also search within the full text of the articles; Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 47,802
- S1 mh “accidental falls” Expanders - Also search within the full text of the articles; Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 25,215

Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL) via Wiley

Date Run: 22/04/2022 13:28:50

- ID Search Hits
- #1 “accidental falls”:ti,ab,kw 1815
- #2 (falls or faller or fallers or “fall injur*”):ti,ab,kw 8316
- #3 (fall or falling):ti 1535
- #4 ^1-#3^ 8954
- #5 (geriatric* OR older OR senior* OR elder* OR aged):ti,ab,kw 594397
- #6 #4 and #5 with Publication Year from 2016 to present, in Trials 2786

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Included | Excluded
Aim | Trials with the primary or secondary aim of reducing falls or falls-related injuries | Comparative effectiveness trials of fall interventions
Population | Community-dwelling, ambulatory adults age ≥65 years at unselected or increased risk for falls | Trials conducted exclusively in populations living in settings outside of the community (e.g., hospitals, nursing or care homes, rehabilitation centers, or other long-term care facilities); Trials conducted exclusively in special populations (e.g., adults with neurocognitive disorders such as moderate to severe dementia or Parkinson’s disease) where interventions may be considered disease management; Trials conducted exclusively in a population with pre-existing social ties
Interventions | Interventions that are primary care feasible or referable; Categories of included interventions:; - Exercise (supervised or unsupervised, individual or group); - Multifactorial assessment and intervention; - Medication modification/review; - Psychological (individual or group); - Environmental assessment and modification; - Knowledge/Education; Interventions may be delivered alone or in combination | Categories of excluded interventions:; - Social marketing; - Policy; - Surgery; - Fluid or nutrition therapy; - Management of urinary incontinence; - Assistive technology; - Vitamin D, supplements
Comparators | Placebo, minimal control (i.e., provision of education via written materials, video, lecture), usual care | Active comparators
Outcomes | KQ 1:; - Falls; - Mortality (all-cause and falls-related); - Fall-related morbidity, defined as:; ○ Fall-related injuries and fractures; ○ Disability (as measured by instrumental activities of daily life instruments); ○ Quality of life (validated instruments); ○ Hospitalizations for fall-related injuries; ○ Emergency department visits for fall-related injuries; ○ Institutionalizations (e.g., transition from community dwelling to nursing or care homes, or other long-term care facilities); KQ 2: Harms outcomes as reported in studies | KQ 1:; - Basic activities of daily living; - Falls Efficacy Scale; - Function measures (e.g., Performance-Oriented Mobility Assessment, Timed Get Up & Go Test, 6-meter timed walk, Functional Reach Test, and Berg Balance Scale); KQ 2: Minor adverse events that are reported using nonvalidated, nongeneralizable measures
Followup | Minimum 6 months followup
Study Designs | Randomized, controlled trials | Editorials, letters, systematic and nonsystematic reviews, opinions, non-randomized studies of interventions, convenience surveys, qualitative studies
Setting | Interventions conducted in primary care, referable from primary care
Country | Countries categorized as “Very High” on the 2019 Human Development Index^*^ | Countries that are not categorized as “Very High”
Language | English only | Non-English language publications
Quality | Fair or good, according to design-specific criteria | Poor, according to design-specific criteria

* As defined by the United Nations Development Programme. Human Development Report 2020. http://hdr.undp.org/sites/default/files/hdr2020.pdf. Accessed 1/28/2022.

Abbreviation: KQ = key question.

Appendix A Table 2 Study-Design Quality Rating Criteria

Study Design | Adapted Quality Criteria
Randomized clinical trials^*^, adapted from U.S. Preventive Services Task Force Manual^2^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

Abbreviations: KQ = key question; U.S. = United States.

Appendix A Figure 1 Risk of Bias in Multifactorial Intervention Trials, by Domain

Appendix A Figure 1 depicts the risk of bias in the multifactorial intervention trials, by domain. The five domains are: randomization/confounding, intervention deviations, outcome measurement, missing data, and selective reporting. The trials are sorted vertically by quality rating, starting from good to fair. There are nine good quality studies and 19 fair quality studies. Good quality studies have low risk of bias for each domain, whereas fair quality studies have at least one domain with moderate risk of bias.

Appendix A Figure 2 Risk of Bias in Exercise Intervention Trials, by Domain

Appendix A Figure 2 depicts the risk of bias in the exercise intervention trials, by domain. The five domains are: randomization process/confounding, intervention deviations, outcome measurement, missing data, and selective reporting. The trials are sorted vertically by quality rating, starting from good to fair. There are five good quality studies and 32 fair quality studies. Good quality studies have low risk of bias for each domain, whereas fair quality studies have at least one domain with moderate risk of bias.

Appendix A Figure 3 Risk of Bias in Other Intervention Trials, by Domain

Appendix A Figure 3 depicts the risk of bias in the other intervention trials, by domain. The five domains are: randomization process/confounding, intervention deviations, outcome measurement, missing data, and selective reporting. The trials are sorted vertically by quality rating, starting from good to fair. There are nine good quality studies and 11 fair quality studies. Good quality studies have low risk of bias for each domain, whereas fair quality studies have at least one domain with moderate or high risk of bias.