# References

1 U.S. Preventive Services Task Force, Curry SJ, Krist AH, . Interventions to prevent child maltreatment: US Preventive Services Task Force recommendation statement. JAMA. 2018;320(20):2122–2128. doi:10.1001/jama.2018.17772 30480735
2 World Health Organization, International Society for Prevention of Child Abuse and Neglect. Child maltreatment. Published 2020. Accessed 9 November, 2021. https://www.who.int/news-room/fact-sheets/detail/child-maltreatment
3 Leeb RT, Paulozzi LJ, Melanson C, Simon TR, Arias I. Child maltreatment surveillance: uniform definitions for public health and recommended data elements. Published 2008. Accessed 10 November, 2021. https://www.cdc.gov/violenceprevention/pdf/cm_surveillance-a.pdf
4 National Child Abuse and Neglect Training and Publications Project. The child abuse prevention and treatment act: 40 years of safeguarding America’s children. U.S. Department of Health and Human Services, Children’s Bureau; 2014. https://www.acf.hhs.gov/sites/default/files/documents/cb/capta_40yrs.pdf
5 117th Congress. S. 1927: to amend the Child Abuse Prevention and Treatment Act. Government Printing Office (GPO); 2021. https://www.govinfo.gov/content/pkg/BILLS-117s1927is/pdf/BILLS-117s1927is.pdf
6 Children’s Bureau. What is child abuse and neglect? how does my state define child abuse and neglect? Published 2013. Accessed 9 November, 2021. https://www.acf.hhs.gov/cb/faq/can1
7 Child Welfare Information Gateway. Definitions of child abuse and neglect. Published 2019. https://www.childwelfare.gov/pubPDFs/define.pdf
8 Committee on Child Maltreatment Research, Policy, and Practice for the Next Decade: Phase II, Board on Children, Youth, and Families, Committee on Law and Justice, . New directions in child abuse and neglect research. National Academies Press; 2014.
9 Child Welfare Information Gateway. Acts of omission: an overview of child neglect. Published 2018. Accessed 11 November, 2021. https://www.childwelfare.gov/pubPDFs/acts.pdf
10 Child Welfare Information Gateway. Child abuse and neglect fatalities 2019: statistics and interventions. Published 2021. Accessed 11 November, 2021. www.childwelfare.gov/pubpdfs/fatality.pdf
11 Child Welfare Information Gateway. Long-term consequences of child abuse and neglect. Published 2013. Accessed 9 November, 2021. https://www.childwelfare.gov/pubPDFs/long_term_consequences.pdf
12 Danese A, Tan M. Childhood maltreatment and obesity: systematic review and meta-analysis. Mol Psychiatry. 2014;19(5):544–554. doi:10.1038/mp.2013.54 23689533
13 Rogers NT, Power C, Pinto Pereira SM. Child maltreatment, early life socioeconomic disadvantage and all-cause mortality in mid-adulthood: findings from a prospective British birth cohort. BMJ Open. 2021;11(9):e050914. doi:10.1136/bmjopen-2021-050914
14 Ramo-Fernandez L, Boeck C, Koenig AM, . The effects of childhood maltreatment on epigenetic regulation of stress-response associated genes: an intergenerational approach. Sci Rep. 2019;9(1):983. doi:10.1038/s41598-018-36689-2 31000782
15 Hillmann K, Neukel C, Hagemann D, Herpertz SC, Bertsch K. Resilience factors in women with severe early-life maltreatment. Psychopathology. 2016;49(4):261–268. doi:10.1159/000447457 27414657
16 Letkiewicz AM, Weldon AL, Tengshe C, Niznikiewicz MA, Heller W. Cumulative childhood maltreatment and executive functioning in adulthood. J Aggress Maltreat Trauma. 2020;30(4):547–563. doi:10.1080/10926771.2020.1832171
17 Nikulina V, Widom CS. Child maltreatment and executive functioning in middle adulthood: a prospective examination. Neuropsychology. 2013;27(4):417–427. doi:10.1037/a0032811 23876115
18 Slade EP, Wissow LS. The influence of childhood maltreatment on adolescents’ academic performance. Econ Educ Rev. 2007;26(5):604–614. doi:10.1016/j.econedurev.2006.10.003 18037979
19 Lippard ETC, Nemeroff CB. The devastating clinical consequences of child abuse and neglect: increased disease vulnerability and poor treatment response in mood disorders. Am J Psychiatry. 2020;177(1):20–36. doi:10.1176/appi.ajp.2019.19010020 31537091
20 Nelson J, Klumparendt A, Doebler P, Ehring T. Childhood maltreatment and characteristics of adult depression: meta-analysis. Br J Psychiatry. 2017;210(2):96–104. doi:10.1192/bjp.bp.115.180752 27908895
21 McRae EM, Stoppelbein L, O’Kelley SE, Fite PK, Smith SB. Pathways from child maltreatment to proactive and reactive aggression: the role of posttraumatic stress symptom clusters. Psychol Trauma. 2021. doi:10.1037/tra0001051
22 Li M, D’Arcy C, Meng X. Maltreatment in childhood substantially increases the risk of adult depression and anxiety in prospective cohort studies: systematic review, meta-analysis, and proportional attributable fractions. Psychol Med. 2016;46(4):717–730. doi:10.1017/S0033291715002743 26708271
23 Nemeroff CB, Heim CM, Thase ME, . Differential responses to psychotherapy versus pharmacotherapy in patients with chronic forms of major depression and childhood trauma. Proc Natl Acad Sci U S A. 2003;100(24):14293–14296. doi:10.1073/pnas.2336126100 14615578
24 Nanni V, Uher R, Danese A. Childhood maltreatment predicts unfavorable course of illness and treatment outcome in depression: a meta-analysis. Am J Psychiatry. 2012;169(2):141–151. doi:10.1176/appi.ajp.2011.11020335 22420036
25 Thompson R, Lewis T, Neilson EC, . Child maltreatment and risky sexual behavior. Child Maltreat. 2017;22(1):69–78. doi:10.1177/1077559516674595 27777330
26 Wang ZY, Hu M, Yu TL, Yang J. The relationship between childhood maltreatment and risky sexual behaviors: a meta-analysis. Int J Environ Res Public Health. 2019;16(19):3666. doi:10.3390/ijerph16193666 31569567
27 London S, Quinn K, Scheidell JD, Frueh BC, Khan MR. Adverse experiences in childhood and sexually transmitted infection risk from adolescence into adulthood. Sex Transm Dis. 2017;44(9):524–532. doi:10.1097/olq.0000000000000640 28809769
28 Hahm HC, Lee Y, Ozonoff A, Van Wert MJ. The impact of multiple types of child maltreatment on subsequent risk behaviors among women during the transition from adolescence to young adulthood. J Youth Adolesc. 2010;39(5):528–540. doi:10.1007/s10964-009-9490-0 20020190
29 Swedo EA, D’Angelo DV, Fasula AM, Clayton HB, Ports KA. Associations of adverse childhood experiences with pregnancy and infant health. Am J Prev Med. 2023;64(4):512–524. doi:10.1016/j.amepre.2022.10.017 36697281
30 Young-Wolff KC, Wei J, Varnado N, Rios N, Staunton M, Watson C. Adverse childhood experiences and pregnancy intentions among pregnant women seeking prenatal care. Womens Health Issues. 2021;31(2):100–106. doi:10.1016/j.whi.2020.08.012 33032888
31 Edalati H, Nicholls TL. Childhood maltreatment and the risk for criminal justice involvement and victimization among homeless individuals: a systematic review. Trauma Violence Abuse. 2019;20(3):315–330. doi:10.1177/1524838017708783 29333962
32 Ellis RA, Awada SR, Orcutt HK, Shelleby EC. Childhood maltreatment and risky substance use behaviors: the mediating roles of posttraumatic stress symptoms & callous unemotional traits. Subst Use Misuse. 2021;56(3):388–395. doi:10.1080/10826084.2020.1868519 33426983
33 Vanderminden J, Hamby S, David-Ferdon C, . Rates of neglect in a national sample: Child and family characteristics and psychological impact. Child Abuse Negl. 2019;88:256–265. doi:10.1016/j.chiabu.2018.11.014 30544033
34 Godbout N, Vaillancourt-Morel MP, Bigras N, . Intimate partner violence in male survivors of child maltreatment: a meta-analysis. Trauma Violence Abuse. 2019;20(1):99–113. doi:10.1177/1524838017692382 29333983
35 Ben-David V, Jonson-Reid M, Drake B, Kohl PL. The association between childhood maltreatment experiences and the onset of maltreatment perpetration in young adulthood controlling for proximal and distal risk factors. Child Abuse Negl. 2015;46:132–141. doi:10.1016/j.chiabu.2015.01.013 25682732
36 Cicchetti D, Toth SL. Child maltreatment. Annu Rev Clin Psychol. 2005;1(1):409–438. doi:10.1146/annurev.clinpsy.1.102803.144029 17716094
37 Wulczyn F. Epidemiological perspectives on maltreatment prevention. Future Child. 2009;19(2):39–66.19719022
38 Vial A, van der Put C, Stams G, Kossakowski J, Assink M. Exploring the interrelatedness of risk factors for child maltreatment: a network approach. Child Abuse Negl. 2020;107:104622. doi:10.1016/j.chiabu.2020.104622 32663718
39 van der Put CE, Assink M, Boekhout van Solinge NF. Predicting child maltreatment: a meta-analysis of the predictive validity of risk assessment instruments. Child Abuse Negl. 2017;73:71–88. doi:10.1016/j.chiabu.2017.09.016 28945998
40 Yang MY, Maguire-Jack K. Individual and cumulative risks for child abuse and neglect. Fam Relat. 2018;67(2):287–301. doi:10.1111/fare.12310
41 Lee JY, Yoon S, Park K, Radney A, Shipe SL, Pace GT. Father-mother co-involvement in child maltreatment: associations of prior perpetration, parental substance use, parental medical conditions, inadequate housing, and intimate partner violence with different maltreatment types. Children (Basel). 2023;10(4). doi:10.3390/children10040707
42 Kobulsky JM, Yoon SH, Wildfeuer R, Simonsson P, Shin SH. The effects of father-perpetration of maltreatment on adolescent health risk. J Interpers Violence. 2022;37(15–16):NP13092–NP13114. doi:10.1177/08862605211001484 33765850
43 Centers for Disease Control and Prevention. Child maltreatment prevention. Published 2015. Accessed 9 November 2021 http://www.cdc.gov/violenceprevention/childmaltreatment
44 Legano LA, Desch LW, Messner SA, . Maltreatment of children with disabilities. Pediatrics. 2021;147(5). doi:10.1542/peds.2021-050920
45 Black DA, Heyman RE, Smith Slep AM. Risk factors for child sexual abuse. Aggress Violent Behav. 2001;6(2–3):203–229. doi:10.1016/s1359-1789(00)00023-9
46 National Center for Injury Prevention and Control. Child abuse and neglect prevention. Published 2021. Accessed 9 November 2021 https://www.cdc.gov/violenceprevention/childabuseandneglect/index.html
47 Coulton CJ, Crampton DS, Irwin M, Spilsbury JC, Korbin JE. How neighborhoods influence child maltreatment: a review of the literature and alternative pathways. Child Abuse Negl. 2007;31(11–12):1117–1142. doi:10.1016/j.chiabu.2007.03.023 18023868
48 Wilkins N, Tsao B, Hertz M, Davis R, Klevens J, National Center for Injury Prevention and Control. Connecting the dots: an overview of the links among multiple forms of violence. 2014. https://www.cdc.gov/violenceprevention/pdf/connecting_the_dots-a.pdf
49 Austin AE, Lesak AM, Shanahan ME. Risk and protective factors for child maltreatment: a review. Curr Epidemiol Rep. 2020;7(4):334–342.34141519
50 Meng X, Fleury MJ, Xiang YT, Li M, D’Arcy C. Resilience and protective factors among people with a history of child maltreatment: a systematic review. Soc Psychiatry Psychiatr Epidemiol. 2018;53(5):453–475. doi:10.1007/s00127-018-1485-2 29349479
51 Centers for Disease Control and Prevention. Children benefit when parents have safe, stable, nurturing relationships. Centers for Disease Control and Prevention; n.d. http://www.cdc.gov/violenceprevention/pdf/ssnrs-for-parents.pdf
52 U.S. Department of Health and Human Services. Preventing child maltreatment and promoting well-being: a network for action 2013 resource guide. U.S. Department of Health and Human Service, Administration for Children and Families; n.d.
53 Schofield TJ, Lee RD, Merrick MT. Safe, stable, nurturing relationships as a moderator of intergenerational continuity of child maltreatment: a meta-analysis. J Adolesc Health. 2013;53(4 Suppl):S32–38. doi:10.1016/j.jadohealth.2013.05.004
54 Li F, Godinet MT, Arnsberger P. Protective factors among families with children at risk of maltreatment: follow up to early school years. Child Youth Serv Rev. 2011;33(1):139–148. doi:10.1016/j.childyouth.2010.08.026
55 Centers for Disease Control and Prevention. Child abuse and neglect prevention. Published 2015. Accessed 9 November 2021 http://www.cdc.gov/violenceprevention/childmaltreatment
56 Thornberry TP, Henry KL, Smith CA, Ireland TO, Greenman SJ, Lee RD. Breaking the cycle of maltreatment: the role of safe, stable, and nurturing relationships. J Adolesc Health. 2013;53(4 Suppl):S25–31. doi:10.1016/j.jadohealth.2013.04.019 24059936
57 Bethell CD, Carle A, Hudziak J, . Methods to assess adverse childhood experiences of children and families: toward approaches to promote child well-being in policy and practice. Acad Pediatr. 2017;17(7s):S51–s69. doi:10.1016/j.acap.2017.04.161 28865661
58 Maguire-Jack K, Showalter K. The protective effect of neighborhood social cohesion in child abuse and neglect. Child Abuse Negl. 2016;52:29–37. doi:10.1016/j.chiabu.2015.12.011 26774530
59 Freisthler B. Need for and access to supportive services in the child welfare system. GeoJournal. 2013;78(3):429–441. doi:10.1007/s10708-011-9426-6 23788827
60 Klevens J, Luo F, Xu L, Peterson C, Latzman NE. Paid family leave’s effect on hospital admissions for pediatric abusive head trauma. Inj Prev. 2016;22(6):442–445. doi:10.1136/injuryprev-2015-041702 26869666
61 Raissian KM, Bullinger LR. Money matters: does the minimum wage affect child maltreatment rates? Child Youth Serv Rev. 2017;72:60–70. doi:10.1016/j.childyouth.2016.09.033
62 U.S. Department of Health & Human Services, Administration for Children and Families, Children’s Bureau, Administration on Children, Youth and Families. Child maltreatment 2021. 2023. https://www.acf.hhs.gov/sites/default/files/documents/cb/cm2021.pdf
63 U.S. Department of Health and Human Services. Child maltreatment 2019. Published 2021.
64 UNICEF. A league table of child maltreatment deaths in rich nations. 2003. https://www.un-ilibrary.org/content/books/9789210601344/read
65 Pritchard C, Williams R, Rosenorn-Lanng E. Child abuse-related deaths, child mortality (0–4 years) and income inequality in the USA and other developed nations 1989–91 v 2013–15: speaking truth to power. Child Abuse Review. 2020;28(5):339–352. doi:10.1002/car.2599
66 Peterson C, Florence C, Klevens J. The economic burden of child maltreatment in the United States, 2015. Child Abuse Negl. 2018;86:178–183. doi:10.1016/j.chiabu.2018.09.018 30308348
67 Fang X, Brown DS, Florence CS, Mercy JA. The economic burden of child maltreatment in the United States and implications for prevention. Child Abuse Negl. 2012;36(2):156–165. doi:10.1016/j.chiabu.2011.10.006 22300910
68 Sedlak AJ, Mettenburg J, Basena M, . Fourth national incidence study of child abuse and neglect (NIS–4). Published 2010. Accessed 18 October 2021 https://www.acf.hhs.gov/sites/default/files/documents/opre/nis4_report_congress_full_pdf_jan2010.pdf
69 Hussey JM, Chang JJ, Kotch JB. Child maltreatment in the United States: prevalence, risk factors, and adolescent health consequences. Pediatrics. 2006;118(3):933–942. doi:10.1542/peds.2005-2452 16950983
70 Finkelhor D, Turner H, Ormrod R, Hamby SL. Violence, abuse, and crime exposure in a national sample of children and youth. Pediatrics. 2009;124(5):1411–1423. doi:10.1542/peds.2009-0467 19805459
71 Finkelhor D, Vanderminden J, Turner H, Hamby S, Shattuck A. Child maltreatment rates assessed in a national household survey of caregivers and youth. Child Abuse Negl. 2014;38(9):1421–1435. doi:10.1016/j.chiabu.2014.05.005 24953383
72 Viswanathan M, Fraser JG, Pan H, . Primary care interventions to prevent child maltreatment: updated evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2018;320(20):2129–2140. doi:10.1001/jama.2018.17647 30480734
73 Cénat JM, McIntee S-E, Mukunzi JN, Noorishad P-G. Overrepresentation of Black children in the child welfare system: a systematic review to understand and better act. Child Youth Serv Rev. 2021;120:105714. doi:10.1016/j.childyouth.2020.105714
74 Mumpower JL. Disproportionality at the “front end” of the child welfare services system: an analysis of rates of referrals, “hits”, “misses”, and “false alarms”. J Health Hum Serv Adm. 2010;33(3):364–405.21329193
75 Sedlak AJ, McPherson K, Das B. Fourth national incidence study of child abuse and neglect (NIS–4). Supplementary analyses of race differences in child maltreatment rates in the NIS–4. 2010. https://www.acf.hhs.gov/sites/default/files/documents/opre/nis4_supp_analysis_race_diff_mar2010.pdf
76 Hymel KP, Laskey AL, Crowell KR, . Racial and ethnic disparities and bias in the evaluation and reporting of abusive head trauma. J Pediatr. 2018;198:137–143.e131. doi:10.1016/j.jpeds.2018.01.048 29606408
77 Jenny C, Hymel KP, Ritzen A, Reinert SE, Hay TC. Analysis of missed cases of abusive head trauma. JAMA. 1999;281(7):621–626. doi:10.1001/jama.281.7.621 10029123
78 Lane WG, Rubin DM, Monteith R, Christian CW. Racial differences in the evaluation of pediatric fractures for physical abuse. JAMA. 2002;288(13):1603–1609. doi:10.1001/jama.288.13.1603 12350191
79 Berger LM, McDaniel M, Paxson C. Assessing parenting behaviors across racial groups: implications for the child welfare system. Soc Serv Rev. 2005;79(4):653–688. doi:10.1086/454389
80 Dettlaff AJ, Rycraft JR. Deconstructing disproportionality: views from multiple community stakeholders. Child Welfare. 2008;87(2):37–58.18972931
81 Cort NA, Cerulli C, He H. Investigating health disparities and disproportionality in child maltreatment reporting: 2002-2006. J Public Health Manag Pract. 2010;16(4):329–336. doi:10.1097/PHH.0b013e3181c4d933 20520372
82 Palusci VJ, Botash AS. Race and bias in child maltreatment diagnosis and reporting. Pediatrics. 2021;148(1):e2020049625. doi:10.1542/peds.2020-049625 34088760
83 Ards SD, Myers SL, Malkis A, Sugrue E, Zhou L. Racial disparity in reported and substantiated child abuse and neglect: an examination of systematic bias. Child Youth Serv Rev. 2003;25(5–6):375–392.
84 Maguire-Jack K, Lanier P, Johnson-Motoyama M, Welch H, Dineen M. Geographic variation in racial disparities in child maltreatment: the influence of county poverty and population density. Child Abuse Negl. 2015;47:1–13. doi:10.1016/j.chiabu.2015.05.020 26122647
85 Drake B, Jolley JM, Lanier P, Fluke J, Barth RP, Jonson-Reid M. Racial bias in child protection? a comparison of competing explanations using national data. Pediatrics. 2011;127(3):471–478. doi:10.1542/peds.2010-1710 21300678
86 Lanier P, Maguire-Jack K, Walsh T, Drake B, Hubel G. Race and ethnic differences in early childhood maltreatment in the United States. J Dev Behav Pediatr. 2014;35(7):419–426. doi:10.1097/DBP.0000000000000083 25180892
87 Acevedo-Garcia D, Osypuk TL, McArdle N, Williams DR. Toward a policy-relevant analysis of geographic and racial/ethnic disparities in child health. Health Aff (Millwood). 2008;27(2):321–333. doi:10.1377/hlthaff.27.2.321 18332486
88 Rebbe R, Sattler KM, Mienko JA. The association of race, ethnicity, and poverty with child maltreatment reporting. Pediatrics. 2022;150(2):e2021053346. doi:10.1542/peds.2021-053346 35843980
89 Cole AB, Armstrong CM, Giano ZD, Hubach RD. An update on ACEs domain frequencies across race/ethnicity and sex in a nationally representative sample. Child Abuse Negl. 2022;129:105686. doi:10.1016/j.chiabu.2022.105686 35662683
90 Richards TN, Schwartz JA, Wright E. Examining adverse childhood experiences among Native American persons in a nationally representative sample: differences among racial/ethnic groups and race/ethnicity-sex dyads. Child Abuse Negl. 2021;111:104812. doi:10.1016/j.chiabu.2020.104812 33220946
91 Heart MY, Chase J, Elkins J, Altschul DB. Historical trauma among Indigenous Peoples of the Americas: concepts, research, and clinical considerations. J Psychoactive Drugs. 2011;43(4):282–290. doi:10.1080/02791072.2011.628913 22400458
92 Warne D, Lajimodiere D. American Indian health disparities: psychosocial influences. Soc Personal Psychol Compass. 2015;9(10):567–579. doi:10.1111/spc3.12198
93 Luken A, Nair R, Fix RL. On racial disparities in child abuse reports: exploratory mapping the 2018 NCANDS. Child Maltreat. 2021;26(3):267–281. doi:10.1177/10775595211001926 33729016
94 Child Welfare Information Gateway. Framework for prevention of child maltreatment. Published n.d. Accessed 11 November 2021 https://www.childwelfare.gov/topics/preventing/overview/framework/
95 U.S. Preventive Services Task Force. Procedure manual. Published 2023. Accessed 10 January, 2024. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual
96 Hunter AA, Flores G. Social determinants of health and child maltreatment: a systematic review. Pediatr Res. 2021;89(2):269–274. doi:10.1038/s41390-020-01175-x 32977325
97 U.S. Department of Health and Human Services. 2021/2022 prevention resource guide. Published 2021. Accessed 10 November, 2021. https://www.childwelfare.gov/pubPDFs/guide_2021.pdf
98 Kodner C, Wetherton A. Diagnosis and management of physical abuse in children. Am Fam Physician. 2013;88(10):669–675.24364482
99 MacMillan HL, Canadian Task Force on Preventive Health Care. Preventive health care, 2000 update: prevention of child maltreatment. CMAJ. 2000;163(11):1451–1458.11192650
100 Centers for Disease Control and Prevention. Guide to community preventive services. violence prevention: early childhood home visitation. Centers for Disease Control and Prevention; 2010.
101 Flaherty EG, Stirling J, Jr., American Academy of Pediatrics, Committee on Child Abuse and Neglect. Clinical report-the pediatrician’s role in child maltreatment prevention. Pediatrics. 2010;126(4):833–841.20945525
102 American Academy of Pediatrics. Prevention of child abuse and neglect. Published 2021. Accessed 10 November, 2021. https://www.aap.org/en/patient-care/child-abuse-and-neglect/prevention-of-child-abuse-and-neglect/
103 United Nations Development Programme. Human development insights: access and explore human development data for 191 countries and territories worldwide. Published n.d. Accessed 7 December 2022. https://hdr.undp.org/data-center/country-insights#/ranks
104 Sterne JAC, Savović J, Page MJ, . RoB 2: a revised tool for assessing risk of bias in randomised trials. BMJ. 2019;366:l4898. doi:10.1136/bmj.l4898 31462531
105 Biostat. Comprehensive meta analysis. version 3.3.070. Biostat; 2014.
106 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539–1558. doi:10.1002/sim.1186 12111919
107 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557–560. doi:10.1136/bmj.327.7414.557 12958120
108 Higgins JP, Green S. Cochrane handbook for systematic reviews of interventions. Published 2011. Accessed 7 December 2022 www.handbook.cochrane.org
109 Rucker G, Schwarzer G, Carpenter JR, Schumacher M. Undue reliance on I(2) in assessing heterogeneity may mislead. BMC Med Res Methodol. 2008;8:79. doi:10.1186/1471-2288-8-79 19036172
110 Easterbrooks MA, Bartlett JD, Raskin M, . Limiting home visiting effects: maternal depression as a moderator of child maltreatment. Pediatrics. 2013;132 (Suppl 2):S126–133. doi:10.1542/peds.2013-1021K 24187114
111 Lowell DI, Carter AS, Godoy L, Paulicin B, Briggs-Gowan MJ. A randomized controlled trial of Child FIRST: a comprehensive home-based intervention translating research into early childhood practice. Child Dev. 2011;82(1):193–208. doi:10.1111/j.1467-8624.2010.01550.x 21291437
112 Barlow J, Davis H, McIntosh E, Jarrett P, Mockford C, Stewart-Brown S. Role of home visiting in improving parenting and health in families at risk of abuse and neglect: results of a multicentre randomised controlled trial and economic evaluation. Arch Dis Child. 2007;92(3):229–233. doi:10.1136/adc.2006.095117 17068074
113 Brayden RM, Altemeier WA, Dietrich MS, . A prospective study of secondary prevention of child maltreatment. J Pediatr. 1993;122(4):511–516.8463893
114 Brooten D, Kumar S, Brown LP, . A randomized clinical trial of early hospital discharge and home follow-up of very-low-birth-weight infants. N Engl J Med. 1986;315(15):934–939. doi:10.1056/NEJM198610093151505 3531852
115 Bugental DB, Schwartz A. A cognitive approach to child mistreatment prevention among medically at-risk infants. Dev Psychol. 2009;45(1):284–288. doi:10.1037/a0014031 19210009
116 Duggan A, Caldera D, Rodriguez K, Burrell L, Rohde C, Crowne SS. Impact of a statewide home visiting program to prevent child abuse. Child Abuse Negl. 2007;31(8):801–827. doi:10.1016/j.chiabu.2006.06.011 17822764
117 DuMont K, Mitchell-Herzfeld S, Greene R, . Healthy Families New York (HFNY) randomized trial: effects on early child abuse and neglect. Child Abuse Negl. 2008;32(3):295–315. doi:10.1016/j.chiabu.2007.07.007 18377991
118 Fergusson DM, Grant H, Horwood LJ, Ridder EM. Randomized trial of the Early Start program of home visitation. Pediatrics. 2005;116(6):e803–809. doi:10.1542/peds.2005-0948 16322138
119 Kitzman H, Olds DL, Henderson CR, Jr., . Effect of prenatal and infancy home visitation by nurses on pregnancy outcomes, childhood injuries, and repeated childbearing: a randomized controlled trial. JAMA. 1997;278(8):644–652.9272896
120 Marcenko MO, Spence M. Home visitation services for at-risk pregnant and postpartum women: a randomized trial. Am J Orthopsychiatry. 1994;64(3):468–478.7977669
121 Olds DL, Henderson CR, Jr., Chamberlin R, Tatelbaum R. Preventing child abuse and neglect: a randomized trial of nurse home visitation. Pediatrics. 1986;78(1):65–78.2425334
122 Siegel E, Bauman KE, Schaefer ES, Saunders MM, Ingram DD. Hospital and home support during infancy: impact on maternal attachment, child abuse and neglect, and health care utilization. Pediatrics. 1980;66(2):183–190.7402803
123 Lam WK, Fals-Stewart W, Kelley ML. Parent training with behavioral couples therapy for fathers’ alcohol abuse: effects on substance use, parental relationship, parenting, and CPS involvement. Child Maltreat. 2009;14(3):243–254. doi:10.1177/1077559509334091 19502478
124 Silovsky JF, Bard D, Chaffin M, . Prevention of child maltreatment in high-risk rural families: a randomized clinical trial with child welfare outcomes. Child Youth Serv Rev. 2011;33(8):1435–1444. doi:10.1016/j.childyouth.2011.04.023
125 Sadler LS, Slade A, Close N, . Minding the Baby: enhancing reflectiveness to improve early health and relationship outcomes in an interdisciplinary home visiting program. Infant Ment Health J. 2013;34(5):391–405. doi:10.1002/imhj.21406 24049219
126 Finello KM, Litton KM, deLemos R, Chan LS. Very low birth weight infants and their families during the first year of life: comparisons of medical outcomes based on after care services. J Perinatol. 1997;18(5):365–371.
127 Larson CP. Efficacy of prenatal and postpartum home visits on child health and development. Pediatrics. 1980;66(2):191–197.7402804
128 Quinlivan JA, Box H, Evans SF. Postnatal home visits in teenage mothers: a randomised controlled trial. Lancet. 2003;361(9361):893–900.12648967
129 Guyer B, Barth M, Bishai D, . Healthy Steps for Young Children Program and national evaluation overview. Published 2003. Accessed 10 January, 2024. https://ztt-healthysteps.s3.amazonaws.com/documents/139/attachments/2003_HS_National_Evaluation_Report.pdf?1539967824
130 Wiggins M, Oakley A, Roberts I, . The social support and family health study: a randomised controlled trial and economic evaluation of two alternative forms of postnatal support for mothers living in disadvantaged inner-city areas. Health Technol Assess. 2004;8(32):1–120.
131 Robling M, Bekkers M-J, Bell K, . Effectiveness of a nurse-led intensive home-visitation programme for first-time teenage mothers (Building Blocks): a pragmatic randomised controlled trial. Lancet. 2016;387(10014):146–155. doi:10.1016/S0140-6736(15)00392-X 26474809
132 Barnes J, Stuart J, Allen E, . Results of the First Steps Study: a randomised controlled trial and economic evaluation of the Group Family Nurse Partnership (gFNP) programme compared with usual care in improving outcomes for high-risk mothers and their children and preventing abuse. Public Health Research. 2017;5(9). doi:10.3310/phr05090
133 Green BL, Sanders MB, Tarte J. Using administrative data to evaluate the effectiveness of the Healthy Families Oregon home visiting program: 2-year impacts on child maltreatment & service utilization. Child Youth Serv Rev. 2017;75:77–86. doi:10.1016/j.childyouth.2017.02.019
134 Jacobs F, Easterbrooks MA, Goldberg J, . Improving adolescent parenting: results from a randomized controlled trial of a home visiting program for young families. Am J Public Health. 2016;106(2):342–349. doi:10.2105/ajph.2015.302919 26562107
135 Easterbrooks MA, Kotake C, Fauth R. Recurrence of maltreatment after newborn home visiting: a randomized controlled trial. Am J Public Health. 2019;109(5):729–735. doi:10.2105/ajph.2019.304957 30896990
136 McIntosh E, Barlow J, Davis H, Stewart-Brown S. Economic evaluation of an intensive home visiting programme for vulnerable families: a cost-effectiveness analysis of a public health intervention. J Public Health (Oxf). 2009;31(3):423–433. doi:10.1093/pubmed/fdp047 19497944
137 Caldera D, Burrell L, Rodriguez K, Crowne SS, Rohde C, Duggan A. Impact of a statewide home visiting program on parenting and on child health and development. Child Abuse Negl. 2007;31(8):829–852. doi:10.1016/j.chiabu.2007.02.008 17822765
138 DuMont K, Kirkland K, Mitchell-Herzfeld S, . A randomized trial of Healthy Families New York (HFNY): does home visiting prevent child maltreatment? 2010.
139 Kirkland K, Lee E, Smith C, Greene R. Sustained impact on parenting practices: year 7 findings from the Healthy Families New York randomized controlled trial. Prev Sci. 2020;21(4):498–507. doi:10.1007/s11121-020-01110-w 32162174
140 Fergusson DM, Boden JM, Horwood LJ. Nine-year follow-up of a home-visitation program: a randomized trial. Pediatrics. 2013;131(2):297–303. doi:10.1542/peds.2012-1612 23359575
141 Olds DL, Sadler L, Kitzman H. Programs for parents of infants and toddlers: recent evidence from randomized trials. J Child Psychol Psychiatry. 2007;48(3–4):355–391. doi:10.1111/j.1469-7610.2006.01702.x 17355402
142 Olds DL, Kitzman H, Cole R, . Effects of nurse home-visiting on maternal life course and child development: age 6 follow-up results of a randomized trial. Pediatrics. 2004;114(6):1550–1559. doi:10.1542/peds.2004-0962 15574614
143 Olds DL, Henderson CR, Kitzman H. Does prenatal and infancy nurse home visitation have enduring effects on qualities of parental caregiving and child health at 25 to 50 months of life? Pediatrics. 1994;39(1):89–98.
144 Olds DL, Eckenrode J, Henderson CR, Jr., . Long-term effects of home visitation on maternal life course and child abuse and neglect. Fifteen-year follow-up of a randomized trial. JAMA. 1997;278(8):637–643.9272895
145 Eckenrode J, Ganzel B, Henderson CR, Jr., . Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000;284(11):1385–1391.10989400
146 Zielinski DS, Eckenrode J, Olds DL. Nurse home visitation and the prevention of child maltreatment: impact on the timing of official reports. Dev Psychopathol. 2009;21(02):441–453. doi:10.1017/S0954579409000248 19338692
147 Minkovitz CS, Strobino D, Mistry KB, . Healthy Steps for Young Children: sustained results at 5.5 years. Pediatrics. 2007;120(3):e658–e668.17766506
148 Wiggins M, Oakley A, Roberts I, . Postnatal support for mothers living in disadvantaged inner city areas: a randomised controlled trial. J Epidemiol Community Health. 2005;59(4):288–295. doi:10.1136/jech.2004.021808 15767382
149 Robling M, Lugg-Widger F, Cannings-John R, . The Family Nurse Partnership to reduce maltreatment and improve child health and development in young children: the BB:2–6 routine data-linkage follow-up to earlier RCT. Pub Health Res. 2021;9(2):1–192. doi:10.3310/phr09020
150 Robling M, Lugg-Widger FV, Cannings-John R, . Nurse-led home-visitation programme for first-time mothers in reducing maltreatment and improving child health and development (BB: 2-6): longer-term outcomes from a randomised cohort using data linkage. BMJ. 2022;12(2):e049960. doi:10.1136/bmjopen-2021-049960
151 Barnes J, Stuart J, Allen E, . Randomized controlled trial and economic evaluation of nurse-led group support for young mothers during pregnancy and the first year postpartum versus usual care. Trials. 2017;18(1):508. doi:10.1186/s13063-017-2259-y 29092713
152 Sege R, Preer G, Morton SJ, . Medical-legal strategies to improve infant health care: a randomized trial. Pediatrics. 2015;136(1):97–106. doi:10.1542/peds.2014-2955 26034248
153 Home Visiting Evidence of Effectiveness. Project overview. Published n.d. https://homvee.acf.hhs.gov/about-us/project-overview
154 Kelly MP, Noyes J, Kane RL, . AHRQ series on complex intervention systematic reviews - paper 2: defining complexity, formulating scope and questions. J Clin Epidemiol. 2017;90:11–18. doi:10.1016/j.jclinepi.2017.06.012 28720514
155 Puls HT, Chung PJ, Anderson C. Universal child care as a policy to prevent child maltreatment. Pediatrics. 2022;150(2). doi:10.1542/peds.2022-056660
156 University of Tokyo, Graduate School of Medicine, Department of Mental Health. Behavioral activation therapy program via smartphone for postnatal mothers and babies. Cochrane Library ICTRP JPRN-UMIN000036864: World Health Organization International Clinical Trials Registry Platform; 27 May 2019: https://trialsearch.who.int/Trial2.aspx?TrialID=JPRN-UMIN000036864. Accessed 27 May.
157 Longhi E, Murray L, Hunter R, . The NSPCC UK Minding the Baby® (MTB) home-visiting programme, supporting young mothers (aged 14-25) in the first 2 years of their baby’s life: study protocol for a randomised controlled trial. Trials. 2016;17(1):486. doi:10.1186/s13063-016-1618-4 27717374
158 Longhi E, Murray L, Wellsted D, . Minding the Baby® (MTB) home-visiting programme for vulnerable young mothers: results of a randomised controlled trial in the UK. NSPCC; 2019.
159 NCT. Prevention of childhood maltreatment in families with young children. Cochrane Central Register of Controlled Trials NCT04341376; 31 October 2020: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-02091533/full. Accessed 30 April.
160 NCT. Study to understand risk and resilience opportunity for newborns after delivery. Cochrane Central Register of Controlled Trials NCT04438161; 31 October 2020: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-02180778/full.
161 NCT. Child-Adult Relationship Enhancement in Primary Care (PriCARE) / Criando Niños Con CARIÑO (CARIÑO). 2022: https://clinicaltrials.gov/show/NCT05233150.
162 NCT. Substance Use Treatment and Access to Resources (STARS) project. Cochrane Central Register of Controlled Trials NCT04459000; 31 October 2020: https://clinicaltrials.gov/show/NCT04459000. Accessed 31 October.
163 NCT. The Oklahoma Parent-Child Assistance Program. 2022: https://clinicaltrials.gov/show/NCT05534568.
164 NCT. MIO-CPP to improve the well-being, permanency, and safety outcomes for young children at risk of or in out-of-home placement in Philadelphia and Bucks Counties, and affected by maternal substance use. ClinicalTrials.gov; 2020: https://clinicaltrials.gov/show/NCT04294134.
165 NCT. New Parent Support Program evaluation. 2022: https://clinicaltrials.gov/show/NCT05236192.
166 Christian CW, Committee on Child Abuse and Neglect, American Academy of Pediatrics. The evaluation of suspected child physical abuse. Pediatrics. 2015;135(5):e1337–1354. doi:10.1542/peds.2015-0356 25917988
167 Kemp AM, Dunstan F, Harrison S, . Patterns of skeletal fractures in child abuse: systematic review. BMJ. 2008;337:a1518. doi:10.1136/bmj.a1518 18832412
168 Hamarman S, Pope KH, Czaja SJ. Emotional abuse in children: variations in legal definitions and rates across the United States. Child Maltreat. 2002;7(4):303–311. doi:10.1177/107755902237261 12408243
169 Anderst JD, Carpenter SL, Abshire TC, Section on Hematology/Oncology, Committee on Child Abuse and Neglect, American Academy of Pediatrics. Evaluation for bleeding disorders in suspected child abuse. Pediatrics. 2013;131(4):e1314–1322. doi:10.1542/peds.2013-0195 23530182
170 Flaherty EG, Perez-Rossello JM, Levine MA, . Evaluating children with fractures for child physical abuse. Pediatrics. 2014;133(2):e477–489. doi:10.1542/peds.2013-3793 24470642
171 Jenny C, Crawford-Jakubiak JE, Committee on Child Abuse and Neglect, American Academy of Pediatrics. The evaluation of children in the primary care setting when sexual abuse is suspected. Pediatrics. 2013;132(2):e558–567. doi:10.1542/peds.2013-1741 23897912
172 Flaherty EG, Macmillan HL, Committee on Child Abuse and Neglect. Caregiver-fabricated illness in a child: a manifestation of child maltreatment. Pediatrics. 2013;132(3):590–597. doi:10.1542/peds.2013-2045 23979088
173 The American College of Radiology. ACR–SPR practice parameter for the performance and interpretation of skeletal surveys in children. 2021. https://www.acr.org/-/media/ACR/Files/Practice-Parameters/Skeletal-Survey.pdf
174 Paine CW, Wood JN. Skeletal surveys in young, injured children: a systematic review. Child Abuse Negl. 2018;76:237–249. doi:10.1016/j.chiabu.2017.11.004 29154020
175 Thackeray JD, Crichton KG, McPherson P, . Identification of initial and subsequent injury in young infants: opportunities for quality improvement in the evaluation of child abuse. Pediatr Emerg Care. 2022;38(6):e1279–e1284. doi:10.1097/pec.0000000000002724 35504033
176 Henry MK, Schilling S, Shults J, . Practice variation in use of neuroimaging among infants with concern for abuse treated in children’s hospitals. JAMA Netw Open. 2022;5(4):e225005. doi:10.1001/jamanetworkopen.2022.5005 35442455
177 Oral R, Blum KL, Johnson C. Fractures in young children: are physicians in the emergency department and orthopedic clinics adequately screening for possible abuse? Pediatr Emerg Care. 2003;19(3):148–153. doi:10.1097/01.pec.0000081234.20228.33 12813297
178 Trokel M, Waddimba A, Griffith J, Sege R. Variation in the diagnosis of child abuse in severely injured infants. Pediatrics. 2006;117(3):722–728. doi:10.1542/peds.2004-2731 16510652
179 Ravichandiran N, Schuh S, Bejuk M, . Delayed identification of pediatric abuse-related fractures. Pediatrics. 2010;125(1):60–66. doi:10.1542/peds.2008-3794 19948569
180 Blatz AM, Gillespie CW, Katcher A, Matthews A, Oetgen ME. Factors associated with nonaccidental trauma evaluation among patients below 36 months old presenting with femur fractures at a level-1 pediatric trauma center. J Pediatr Orthop. 2019;39(4):175–180. doi:10.1097/bpo.0000000000000911 30839475
181 Lane WG, Dubowitz H. What factors affect the identification and reporting of child abuse-related fractures? Clin Orthop Relat Res. 2007;461:219–225. doi:10.1097/BLO.0b013e31805c0849 17415005
182 Laskey AL, Stump TE, Perkins SM, Zimet GD, Sherman SJ, Downs SM. Influence of race and socioeconomic status on the diagnosis of child abuse: a randomized study. J Pediatr. 2012;160(6):1003–1008.e1001. doi:10.1016/j.jpeds.2011.11.042 22221565
183 Feldman KW, Tayama TM, Strickler LE, . A prospective study of the causes of bruises in premobile infants. Pediatr Emerg Care. 2020;36(2):e43–e49. doi:10.1097/pec.0000000000001311 29040244
184 Lavin LR, Penrod CH, Estrada CM, . Fractures in the pediatric emergency department: are we considering abuse? Clin Pediatr (Phila). 2018;57(10):1161–1167. doi:10.1177/0009922818759319 29451007
185 Hendrix AD, Conway LK, Baxter MA. Legal outcomes of suspected maltreatment cases evaluated by a child abuse pediatrician as part of a multidisciplinary team investigation. J Forensic Sci. 2020;65(5):1517–1523. doi:10.1111/1556-4029.14463 32501610
186 Doswell A, Anderst J, Tieder JS, . Diagnostic testing for and detection of physical abuse in infants with brief resolved unexplained events. Child Abuse Negl. 2023;135:105952. doi:10.1016/j.chiabu.2022.105952 36423537
187 Schoneich S, Plegue M, Waidley V, . Incidence of newborn drug testing and variations by birthing parent race and ethnicity before and after recreational cannabis legalization. JAMA Netw Open. 2023;6(3):e232058–e232058. doi:10.1001/jamanetworkopen.2023.2058 36884249
188 Wood JN, Hall M, Schilling S, Keren R, Mitra N, Rubin DM. Disparities in the evaluation and diagnosis of abuse among infants with traumatic brain injury. Pediatrics. 2010;126(3):408–414. doi:10.1542/peds.2010-0031 20713477
189 Keenan HT, Campbell KA, Page K, Cook LJ, Bardsley T, Olson LM. Perceived social risk in medical decision-making for physical child abuse: a mixed-methods study. BMC Pediatr. 2017;17(1):214. doi:10.1186/s12887-017-0969-7 29273019
190 Rangel EL, Cook BS, Bennett BL, Shebesta K, Ying J, Falcone RA. Eliminating disparity in evaluation for abuse in infants with head injury: use of a screening guideline. J Pediatr Surg. 2009;44(6):1229–1235. doi:10.1016/j.jpedsurg.2009.02.044 19524746
191 Shum M, Asnes AG, Leventhal JM, . The impact of a child abuse guideline on differences between pediatric and community emergency departments in the evaluation of injuries. Child Abuse Negl. 2021;122:105374. doi:10.1016/j.chiabu.2021.105374 34737120
192 Tandon M, Jonson-Reid M, Constantino JN. Documenting opportunity for systematic identification and mitigation of risk for child maltreatment. J Am Acad Child Adolesc Psychiatry. 2022;61(11):1313–1316. doi:10.1016/j.jaac.2022.05.008 35690303
193 Hixenbaugh M, Khimm S, Philip A. Mandatory reporting was supposed to stop severe child abuse. It punishes poor families instead. Published 2022. Accessed 8 December 2022 https://www.propublica.org/article/mandatory-reporting-strains-systems-punishes-poor-families
194 Cooley DT, Jackson Y. Informant discrepancies in child maltreatment reporting: a systematic review. Child Maltreat. 2020:1077559520966387. doi:10.1177/1077559520966387
195 Wood JN, Christian CW, Adams CM, Rubin DM. Skeletal surveys in infants with isolated skull fractures. Pediatrics. 2009;123(2):e247–252. doi:10.1542/peds.2008-2467 19171576
196 Zerr AA, Newton RR, Litrownik AJ, McCabe KM, Yeh M. Household composition and maltreatment allegations in the US: deconstructing the at-risk single mother family. Child Abuse Negl. 2019;97:104123. doi:10.1016/j.chiabu.2019.104123 31473384
197 Rebbe R, Mienko JA, Brown E, Rowhani-Rahbar A. Hospital variation in child protection reports of substance exposed infants. J Pediatr. 2019;208:141–147.e142. doi:10.1016/j.jpeds.2018.12.065 30770194
198 Putnam-Hornstein E, Needell B, King B, Johnson-Motoyama M. Racial and ethnic disparities: a population-based examination of risk factors for involvement with child protective services. Child Abuse Negl. 2013;37(1):33–46. doi:10.1016/j.chiabu.2012.08.005 23317921
199 Parrish JW, Fleckman JM, Prindle JJ, Eastman AL, Weil LEG. Measuring the incidence of child maltreatment using linked data: a two-state comparison. Am J Prev Med. 2020;58(4):e133–e140. doi:10.1016/j.amepre.2019.11.007 32005593
200 Fisher MH, Epstein RA, Urbano RC, Vehorn A, Cull MJ, Warren Z. A population-based examination of maltreatment referrals and substantiation for children with autism spectrum disorder. Autism. 2019;23(5):1335–1340. doi:10.1177/1362361318813998 30523699
201 Putnam-Hornstein E, Prindle JJ, Leventhal JM. Prenatal substance exposure and reporting of child maltreatment by race and ethnicity. Pediatrics. 2016;138(3). doi:10.1542/peds.2016-1273
202 Hoerr JJ, Heard AM, Baker MM, . Substance-exposed newborn infants and public health law: differences in addressing the legal mandate to report. Child Abuse Negl. 2018;81:206–213. doi:10.1016/j.chiabu.2018.04.021 29753200
203 Flaherty EG, Sege RD, Griffith J, . From suspicion of physical child abuse to reporting: primary care clinician decision-making. Pediatrics. 2008;122(3):611–619. doi:10.1542/peds.2007-2311 18676507
204 Brennan B, Henry MK, Altaffer A, Wood JN. Prevalence of abuse and additional injury in young children with rib fractures as their presenting injury. Pediatr Emerg Care. 2021;37(12):e1451–e1456. doi:10.1097/pec.0000000000002071 32205804
205 Fong K. Neighborhood inequality in the prevalence of reported and substantiated child maltreatment. Child Abuse Negl. 2019;90:13–21. doi:10.1016/j.chiabu.2019.01.014 30716651
206 Thurston H, Miyamoto S. Disparity in child welfare referrals from public schools: an example of Simpson’s Paradox? Child Abuse Negl. 2020;102:104397. doi:10.1016/j.chiabu.2020.104397 32044584
207 van der Put CE, Assink M, Gubbels J, Boekhout van Solinge NF. Identifying effective components of child maltreatment interventions: a meta-analysis. Clin Child Fam Psychol Rev. 2018;21(2):171–202. doi:10.1007/s10567-017-0250-5 29204796
208 Dodge KA, Benjamin Goodman W, Bai Y, Murphy RA, O’Donnell K. Maximizing the return on investment in early childhood home visiting through enhanced eligibility screening. Child Abuse Negl. 2021;122:105339. doi:10.1016/j.chiabu.2021.105339 34560398
209 van der Put CE, Bouwmeester-Landweer MBR, Landsmeer-Beker EA, . Screening for potential child maltreatment in parents of a newborn baby: the predictive validity of an Instrument for early identification of Parents At Risk for child Abuse and Neglect (IPARAN). Child Abuse Negl. 2017;70:160–168. doi:10.1016/j.chiabu.2017.05.016 28618320
210 Chen XY, Lo CKM, Chan KL, Leung WC, Ip P. Association between Childhood Exposure to Family Violence and Telomere Length: A Meta-Analysis. Int J Environ Res Public Health. 2022;19(19). doi:10.3390/ijerph191912151
211 Enhancing executive functioning among toddlers in foster care with an attachment-based intervention. Dev Psychopathol. 2017;29(2):575–586. doi:10.1017/S0954579417000190 28401847
212 Chen CJ, Chen YW, Chang HY, Feng JY. Screening tools for child abuse used by healthcare providers: a systematic review. J Nurs Res. 2022;30(1):e193. doi:10.1097/jnr.0000000000000475 35050956
213 Pilla NI, Nasreddine A, Christie KJ, Hennrikus WL. Rate of orthopedic resident and medical student recognition of nonaccidental trauma: a pilot study. J Pediatr Orthop B. 2022;31(4):407–413. doi:10.1097/bpb.0000000000000948 34985011
214 Metz JB, Otjen JP, Perez FA, . Are complex skull fractures indicative of either child abuse or major trauma in the era of 3-dimensional computed tomography imaging? Pediatr Emerg Care. 2022;38(1):e200–e204. doi:10.1097/pec.0000000000002214 32868622
215 Vaithianathan R, Maloney T, Putnam-Hornstein E, Jiang N. Children in the public benefit system at risk of maltreatment: identification via predictive modeling. Am J Prev Med. 2013;45(3):354–359. doi:10.1016/j.amepre.2013.04.022 23953364
216 Green MJ, Watkeys OJ, Kariuki M, . Forecasting childhood adversities from conditions of birth. Paediatr Perinat Epidemiol. 2022;36(2):230–242. doi:10.1111/ppe.12828 35107846
217 Brownell MD, Chartier M, Santos R, Au W, Roos NP, Girard D. Evaluation of a newborn screen for predicting out-of-home placement. Child Maltreat. 2011;16(4):239–249. doi:10.1177/1077559511422942 22007033
218 Schols MWA, Serie CMB, Broers NJ, de Ruiter C. Factor analysis and predictive validity of the Early Risks of Physical Abuse and Neglect Scale (ERPANS): a prospective study in Dutch public youth healthcare. Child Abuse Negl. 2019;88:71–83. doi:10.1016/j.chiabu.2018.10.011 30447504
219 Ezpeleta L, Pérez-Robles R, Fanti KA, . Development of a screening tool enabling identification of infants and toddlers at risk of family abuse and neglect: a feasibility study from three South European countries. Child Care Health Dev. 2017;43(1):75–80. doi:10.1111/cch.12416 27726157
220 Korfmacher J. The Kempe Family Stress Inventory: a review. Child Abuse Negl. 2000;24(1):129–140.10660015
221 Murphy S, Orkow B, M. Nicola R. Prenatal prediction of child abuse and neglect: a prospective study. Child Abuse Negl. 1985;9(2):225–235. doi:10.1016/0145-2134(85)90015-8 4005663
222 Altemeier WA, O’Connor S, Vietze P, Sandler H, Sherrod K. Prediction of child abuse: a prospective study of feasibility. Child Abuse Negl. 1984;8(4):393–400. doi:10.1016/0145-2134(84)90020-6 6542812
223 Barber JG, Shlonsky A, Black T, Goodman D, Trocmé N. Reliability and predictive validity of a consensus-based risk assessment tool. J Public Child Welf. 2008;2(2):173–195. doi:10.1080/15548730802312701
224 Wells R, McCann J, Adams J, Voris J, Dahl B. A validational study of the structured interview of Symptoms Associated with Sexual Abuse (SASA) using three samples of sexually abused, allegedly abused, and nonabused boys. Child Abuse Negl. 1997;21(12):1159–1167. doi:10.1016/s0145-2134(97)00091-4 9429768
225 McNellan CR, Gibbs DJ, Knobel AS, Putnam-Hornstein E. The evidence base for risk assessment tools used in U.S. child protection investigations: a systematic scoping review. Child Abuse Negl. 2022;134:105887. doi:10.1016/j.chiabu.2022.105887 36152529
226 Pierce MC, Kaczor K, Lorenz DJ, . Validation of a clinical decision rule to predict abuse in young children based on bruising characteristics. JAMA Netw Open. 2021;4(4):e215832. doi:10.1001/jamanetworkopen.2021.5832 33852003
227 Berger RP, Saladino RA, Fromkin J, Heineman E, Suresh S, McGinn T. Development of an electronic medical record-based child physical abuse alert system. J Am Med Inform Assoc. 2018;25(2):142–149. doi:10.1093/jamia/ocx063 28641385
228 McCurdy K. Risk assessment in child abuse prevention programs. Soc Work Res. 1995;19(2):77–87.
229 Milner JS, Gold RG, Ayoub C, Jacewitz MM. Predictive validity of the child abuse potential inventory. J Consult Clin Psychol. 1984;52(5):879.6501673
230 Chang DC, Knight V, Ziegfeld S, Haider A, Warfield D, Paidas C. The tip of the iceberg for child abuse: the critical roles of the pediatric trauma service and its registry. J Trauma. 2004;57(6):1189–1198; discussion 1198. doi:10.1097/01.ta.0000145076.05111.e1 15625449
231 Pfeiffer H, Smith A, Kemp AM, . External validation of the PediBIRN clinical prediction rule for abusive head trauma. Pediatrics. 2018;141(5). doi:10.1542/peds.2017-3674
232 Hymel KP, Armijo-Garcia V, Foster R, . Validation of a clinical prediction rule for pediatric abusive head trauma. Pediatrics. 2014;134(6):e1537–1544. doi:10.1542/peds.2014-1329 25404722
233 Berger RP, Fromkin J, Herman B, . Validation of the Pittsburgh Infant Brain Injury Score for abusive head trauma. Pediatrics. 2016;138(1):e20153756. doi:10.1542/peds.2015-3756 27338699
234 Cowley LE, Morris CB, Maguire SA, Farewell DM, Kemp AM. Validation of a prediction tool for abusive head trauma. Pediatrics. 2015;136(2):290–298. doi:10.1542/peds.2014-3993 26216332
235 Pfeiffer H, Cowley LE, Kemp AM, . Validation of the PredAHT-2 prediction tool for abusive head trauma. Emerg Med J. 2020;37(3):119–126. doi:10.1136/emermed-2019-208893 31932397
236 Chang DC, Knight VM, Ziegfeld S, Haider A, Paidas C. The multi-institutional validation of the new screening index for physical child abuse. J Pediatr Surg. 2005;40(1):114–119. doi:10.1016/j.jpedsurg.2004.09.019 15868569
237 Kemp AM, Hollén L, Emond AM, Nuttall D, Rea D, Maguire SA. Raising suspicion of maltreatment from burns: derivation and validation of the BuRN-Tool. Burns. 2018;44 2:335–343.28918905
238 Hollen L, Bennett V, Nuttall D, Emond AM, Kemp A. Evaluation of the efficacy and impact of a clinical prediction tool to identify maltreatment associated with children’s burns. BMJ Paediatr Open. 2021;5(1):e000796. doi:10.1136/bmjpo-2020-000796
239 Louwers EC, Korfage IJ, Affourtit MJ, . Accuracy of a screening instrument to identify potential child abuse in emergency departments. Child Abuse Negl. 2014;38(7):1275–1281. doi:10.1016/j.chiabu.2013.11.005 24325939
240 Pierce MC, Kaczor K, Aldridge S, O’Flynn J, Lorenz DJ. Bruising characteristics discriminating physical child abuse from accidental trauma. Pediatrics. 2010;125(1):67–74. doi:10.1542/peds.2008-3632 19969620
241 Hoedeman F, Puiman PJ, van den Heuvel EAL, . A validated Screening instrument for Child Abuse and Neglect (SCAN) at the emergency department. Eur J Pediatr. 2023;182(1):79–87. doi:10.1007/s00431-022-04635-0 36198865
242 Sittig JS, Uiterwaal CS, Moons KG, Nieuwenhuis EE, van de Putte EM. Child abuse inventory at emergency rooms: CHAIN-ER rationale and design. BMC Pediatr. 2011;11:91. doi:10.1186/1471-2431-11-91 22008625
243 Schouten MCM, van Stel HF, Verheij TJM, . The value of a checklist for child abuse in out-of-hours primary care: to screen or not to screen. PLoS One. 2017;12(1):e0165641. doi:10.1371/journal.pone.0165641 28045904
244 Child Welfare Information Gateway. Home visiting programs. Published n.d. Accessed 9 November, 2021. https://www.childwelfare.gov/topics/preventing/prevention-programs/homevisit/homevisitprog/
245 U.S. Department of Health and Human Services. Early childhood home visiting models: reviewing evidence of effectiveness. OPRE Report #2021-185. 2021. https://homvee.acf.hhs.gov/sites/default/files/2021-11/HomVEE_ExecutiveSummary_Nov2021.pdf
246 Lorenc T, Lester S, Sutcliffe K, Stansfield C, Thomas J. Interventions to support people exposed to adverse childhood experiences: systematic review of systematic reviews. BMC Public Health. 2020;20(1):657. doi:10.1186/s12889-020-08789-0 32397975
247 ZERO TO THREE. Early childhood mental health: promotion, prevention and treatment. Published 2014. Accessed 11 February, 2016. http://www.zerotothree.org/child-development/early-childhood-mental-health/promotion-prevention-treatment.html
248 Temcheff CE, Letarte MJ, Boutin S, Marcil K. Common components of evidence-based parenting programs for preventing maltreatment of school-age children. Child Abuse Negl. 2018;80:226–237. doi:10.1016/j.chiabu.2018.02.004 29631254
249 Gubbels J, van der Put CE, Assink M. The effectiveness of parent training programs for child maltreatment and their components: a meta-analysis. Int J Environ Res Public Health. 2019;16(13). doi:10.3390/ijerph16132404
250 Community Preventive Services Task Force. Early childhood home visitation: to prevent child maltreatment. Published 2013. Accessed 10 February 2023. https://www.thecommunityguide.org/media/pdf/Violence-Early-Home-Vistation-Child-Maltreatment_0.pdf
251 Healthy People 2030. Social determinants of health. Published n.d. Accessed 4 January, 2023. https://health.gov/healthypeople/priority-areas/social-determinants-health
252 Cohn T, Harrison CV. A systematic review exploring racial disparities, social determinants of health, and sexually transmitted infections in black women. Nurs Womens Health. 2022;26(2):128–142. doi:10.1016/j.nwh.2022.01.006 35182482
253 Hill-Briggs F, Adler NE, Berkowitz SA, . Social determinants of health and diabetes: a scientific review. Diabetes Care. 2020;44(1):258–279. doi:10.2337/dci20-0053 33139407
254 Jilani MH, Javed Z, Yahya T, . Social determinants of health and cardiovascular disease: current state and future directions towards healthcare equity. Curr Atheroslcer Rep. 2021;23(9):55. doi:10.1007/s11883-021-00949-w
255 Khatib R, Glowacki N, Byrne J, Brady P. Impact of social determinants of health on anticoagulant use among patients with atrial fibrillation: systemic review and meta-analysis. Medicine (Baltimore). 2022;101(35):e29997. doi:10.1097/MD.0000000000029997 36107589
256 Powell-Wiley TM, Baumer Y, Baah FO, . Social determinants of cardiovascular disease. Circ Res. 2022;130(5):782–799. doi:10.1161/CIRCRESAHA.121.319811 35239404
257 Taylor L. Housing and health: an overview of the literature. Health Affairs Health Policy Brief. 2018. doi:10.1377/hpb20180313.396577
258 Walker RJ, Garacci E, Ozieh M, Egede LE. Food insecurity and glycemic control in individuals with diagnosed and undiagnosed diabetes in the United States. Prim Care Diabetes. 2021;15(5):813–818. doi:10.1016/j.pcd.2021.05.003 34006474
259 Wilder ME, Kulie P, Jensen C, . The impact of social determinants of health on medication adherence: a systematic review and meta-analysis. J Gen Intern Med. 2021;36(5):1359–1370. doi:10.1007/s11606-020-06447-0 33515188
260 Tran YH, Coven SL, Park S, Mendonca EA. Social determinants of health and pediatric cancer survival: a systematic review. Pediatr Blood Cancer. 2022;69(5):e29546. doi:10.1002/pbc.29546 35107854
261 Galea S, Tracy M, Hoggatt KJ, Dimaggio C, Karpati A. Estimated deaths attributable to social factors in the United States. Am J Public Health. 2011;101(8):1456–1465. doi:10.2105/AJPH.2010.300086 21680937
262 Karmakar M, Lantz PM, Tipirneni R. Association of social and demographic factors with COVID-19 incidence and death rates in the US. JAMA Netw Open. 2021;4(1):e2036462. doi:10.1001/jamanetworkopen.2020.36462 33512520
263 Yan AF, Chen Z, Wang Y, . Effectiveness of social needs screening and interventions in clinical settings on utilization, cost, and clinical outcomes: a systematic review. Health Equity. 2022;6(1):454–475. doi:10.1089/heq.2022.0010 35801145
264 Johnson-Motoyama M, Ginther DK, Oslund P, . Association between state supplemental nutrition assistance program policies, child protective services involvement, and foster care in the US, 2004-2016. JAMA Netw Open. 2022;5(7):e2221509. doi:10.1001/jamanetworkopen.2022.21509 35816315
265 Abbott LS, Elliott LT. Eliminating health disparities through action on the social determinants of health: a systematic review of home visiting in the United States, 2005-2015. Public Health Nurs. 2017;34(1):2–30. doi:10.1111/phn.12268 27145717
266 Barlow A, Mullany B, Neault N, . Effect of a paraprofessional home-visiting intervention on American Indian teen mothers’ and infants’ behavioral risks: a randomized controlled trial. Am J Psychiatry. 2013;170(1):83–93. doi:10.1176/appi.ajp.2012.12010121 23409290
267 Calheiros MM, Patrício JN, Graça J, Magalhães E. Evaluation of an intervention program for families with children at risk for maltreatment and developmental impairment: a preliminary study. J Child Fam Stud. 2018;27(5):1605–1613. doi:10.1007/s10826-017-0988-x
268 Demeusy EM, Handley ED, Manly JT, Sturm R, Toth SL. Building healthy children: a preventive intervention for high-risk young families. Dev Psychopathol. 2021;33(2):598–613. doi:10.1017/s0954579420001625 33757620
269 Dodge KA, Goodman WB, Bai Y, O’Donnell K, Murphy RA. Effect of a community agency-administered nurse home visitation program on program use and maternal and infant health outcomes: a randomized clinical trial. JAMA Netw Open. 2019;2(11):e1914522. doi:10.1001/jamanetworkopen.2019.14522 31675088
270 Goodman WB, Dodge KA, Bai Y, Murphy RA, O’Donnell K. Effect of a universal postpartum nurse home visiting program on child maltreatment and emergency medical care at 5 years of age: a randomized clinical trial. JAMA Netw Open. 2021;4(7):e2116024. doi:10.1001/jamanetworkopen.2021.16024 34232300
271 Abajobir AA, Kisely S, Williams G, Strathearn L, Najman JM. Risky sexual behaviors and pregnancy outcomes in young adulthood following substantiated childhood maltreatment: findings from a prospective birth cohort study. J Sex Res. 2018;55(1):106–119. doi:10.1080/00224499.2017.1368975 28972390
272 Duggan A, McFarlane E, Fuddy L, . Randomized trial of a statewide home visiting program: impact in preventing child abuse and neglect. Child Abuse Negl. 2004;28(6):597–622. doi:10.1016/j.chiabu.2003.08.007 15193851
273 Duggan AK, McFarlane EC, Windham AM, . Evaluation of Hawaii’s Healthy Start Program. Future Child. 1999;9(1):66–90; discussion 177-178.10414011
274 Norr KF, Crittenden KS, Lehrer EL, . Maternal and infant outcomes at one year for a nurse-health advocate home visiting program serving African Americans and Mexican Americans. Public Health Nurs. 2003;20(3):190–203.12716399
275 Infante-Rivard C, Filion G, Baumgarten M, Bourassa M, Labelle J, Messier M. A public health home intervention among families of low socioeconomic status. Child Health Care. 1989;18(2):102–107.