# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Sheena Harris, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Scientific Director, U.S. Preventive Services Task Force (USPSTF); current and former members of the USPSTF; expert reviewers Kenneth Dodge, PhD, Duke University; Wendy Lane, MD, MPH, University of Maryland; and one reviewer who wishes to remain anonymous; federal partner reviewers from the Centers for Disease Control and Prevention and National Institutes of Health; Roberta Wines, MPH, RTI-UNC EPC project manager; Christiane Voisin, MSLS, librarian; Sharon Barrell, MA, and Mary Gendron and Jessica Burch, editors; Teyonna Downing and Alex Cone, publications specialists; and Ina F. Wallace, PhD, editorial support.