# Chapter 4 Discussion

This chapter begins with a summary of review findings for the evidence; Table 3 provides additional details. We then present limitations of the evidence and our update review and end with conclusions and recommendations for future research. As noted in the introduction, SDOH such as poverty, food or housing insecurity, and lack of insurance serve as risk factors for child maltreatment.^96^ A comprehensive intervention approach may require societal changes including broad policy mandates that address structural drivers of these risk factors. For this report, the remit is narrower and specific to the USPSTF considerations, to interventions that are primary care relevant and their effect on direct or proxy measures of maltreatment.

Table 3 Summary of Evidence of Interventions to Prevent Child Maltreatment

Key Question | Population, Intervention | No. of Studies; No. of Observations | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Overall Quality of Studies | Body of Evidence Limitations | EPC Assessment of Strength of Evidence: For Outcome | Applicability
KQ 1: Reports to CPS | Caregivers of children at risk of maltreatment | 15; 8,513^110–112,114,116–118,121–126,131,133,135–140,143–146,149^ | CPS reports at or within 1 year of trial completion: OR, 1.03; 95% CI, 0.86 to 1.27; I^2^, 10.2%; 12.9% vs. 12.2% (k=11, 5,311 participants^*^); Mixed results for long-term followup^*^ | Consistent/imprecise short-term outcomes; inconsistent/imprecise for long-term outcomes | No evidence of reporting bias | Fair | Heterogeneity across studies in type of intervention | Low for no benefit for short-term outcomes, insufficient for long-term outcomes | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Removal of the child from home | Infants/toddlers age ≤3 years | 6; 3,657^112–114,120,128,133,136^ | Removals 0–3 years: 68/1751 (3.9%) vs. 55/1585 (3.5%); RR, 1.06; 95% CI, 0.37 to 2.99; I^2^, 49.9% (k=5, 3,336 participants); Removals at birth (for intervention started in pregnancy) in one study: calculated RR, 2.33; 95% CI, 0.66 to 8.20; 225 participants | Inconsistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity across studies in timing of outcome | Low for no benefit | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Other measures of abuse or neglect | Caregivers (mothers or families) | 3; 2,106^113,115,131^ | Abuse:^†^ 13/141 (9.2%) vs. 8/122 (6.6%); RR, 1.4; 95% CI, 0.58 to 3.62; k=1, 263 participants; Neglect:^ǂ^ 15/141 (10.6%) vs. 5/122 (4.1%); RR, 2.79; 95% CI, 0.98 to 7.91; 1 trial, 263 participants; Significantly higher safety scores in the intervention arm; 1 trial, 141 participants; Higher rates of safeguarding actions in the intervention arm: AOR, 1.85; 95% CI, 1.02 to 2.85; 1 trial, 945 participants | Inconsistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity across studies in outcome measures | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Injuries with a high specificity for abuse | Adolescent mothers | 1; 136^128^ | Nonaccidental injuries: 0/65 (0%) vs. 1/71 (1.4%); calculated RR: 0.36; 95% CI, 0.015 to 8.77 | Consistency unknown (single trial)/imprecise | No evidence of reporting bias | Fair | Single small trial | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Visits to the ED | Children | 14; 8,180^112,114,116,118,119,121,122,126,127,129–132,136,137,140,141,143–150,152^ | 2 of 4 studies reported a statistically significant difference in the mean difference of ED visits at 2 months^132^ and 6 months of age;^152^ the other 2 studies report results that are not statistically significant at 6 months of age^126,131^; 3 of 8 studies reported a statistically significant difference in mean number of all-cause ED visits from 1 to 2 years of followup^121,126,132^; all other studies report results that are not statistically significant^121,122,127,130,136,143–146,148,152^; 1 of 2 studies reported statistically significant results at the 2- to 4-year followup for each of the following: mean number of all-cause ED visits;^121^ mean number of ED visits for accidents, injuries, and ingestions;^121^ and number of children seen for accidents or injuries;^118,140^ 2 studies found no differences for number of children seen in the ER;^116,129,137^ 1 study found no difference in the proportion of children seen for injuries and ingestions^131^; 1 of 3 studies reported statistically significant differences at long-term followup^143^ | Inconsistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity across studies in outcome measures | Low for no benefit for short-term outcomes, insufficient for long-term outcomes | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Hospital-ization | Infants | 13; 7,475^112,114,116,118,119,122,126,128,131,132,137,140,143,147–150^ | 1 of 5 studies showed a reduction in number of children with all-cause hospitalization, but only for 1 of 4 outcome measures^126^; 1 study found a statistically significant mean difference in number of children hospitalized at 12 months in 1 of 5 hospital wards and no statistically significant differences in any of the 5 wards at 2 months^132^; 2 of 4 studies found a lower mean number of hospital days or fewer total days hospitalized of injuries or ingestions^119,143^; 1 trial found lower overall rates of hospital admission for unintentional injury at a 9-year followup^118,140^; All other outcomes are not statistically significantly different^§^ | Consistent/imprecise for results under 3 years; inconsistent/imprecise for long-term followup | No evidence of reporting bias | Fair | Heterogeneity outcome measures; each outcome/timing only presented in a single study | Low strength of evidence of no benefit | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Failure to thrive | Infants | 1; 79^114^ | 0% (0/39) vs. 2.5% (1/40); RR, 0.34; 95% CI, 0.01 to 8.14 | Consistency unknown (single trial)/imprecise | No evidence of reporting bias | Fair | Single small trial | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Failure to immunize | Adolescent mothers | 1; 136^128^ | No vaccinations at 6 months: 4/71 (5.6%) vs. 9/65 (13.8%); calculated RR, 0.41; 95% CI, 0.13 to 1.26 | Consistency unknown (single trial)/imprecise | No evidence of reporting bias | Fair | Single small trial | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Internalizing and externalizing behavior symptoms | Caregivers of children at risk of maltreatment | 6; 5,115^111,116–119,129,137–141,147^ | 3 of 6 trials reported reductions in behavior difficulties^ǁ^; Other outcomes are not statistically significantly different^¶^ | Inconsistent/imprecise | No evidence of reporting bias | Fair | Small number of trials; heterogeneity of outcome measures | Insufficient | Home-based intervention targeting high-risk families may be effective in decreasing behavior problems
KQ 1: Other social, emotional, and develop-mental outcomes | Infants/toddlers ≤3 years of age | 5; 4,439^111,112,129,136,138,141,147^ | 0 of 5 studes reported statistically signfiicant differences on a variety of social, emotional, and developmental measures^#^ | Consistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity outcome measures; each outcome/timing only presented in a single study | Low strength of evidence of no benefit for children ≤3 years | Unclear whether findings apply to subgroups defined by parent risk factors; one intervention may not be readily generalizable to other (pediatric practice) settings
KQ 1: Bayley Scales of Develop-ment | Caregivers and families | 4; 1,638^112,119,121,137^ | 1 of 4 trials reported higher scores in the intervention arm (mean difference between arms: 3.2; 95% CI, 1.2 to 5.2) | Consistent/imprecise | No evidence of reporting bias | Fair | Outcomes measured at different ages | Low for no benefit | All studies focused on at-risk caregivers and families
KQ 1: Other measures of develop-ment | Pregnant mothers | 5; 4,542^111,121,125,131,143,147^ | 3 of 5 trials reported statistically significant differences on other development outcomes but only for a subset of reported outcome measures and timing | Inconsistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity in outcome measures | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: School performance | School-age children | 3; 3,561^131,138,141,142,149,150^ | 3 studies found no difference on varied school performance measures (repeating a grade, test scores, academically focused behavior) assessed at varied times^131,138,141,142,149,150^; 1 of 3 studies reported statistically significant difference in mental processing (Kauffman Assessment Battery for children) at age 6 (mean 92.3 vs. 90.2; effect size, 0.18; p=0.03)^142^ | Inconsistent/Imprecise | No evidence of reporting bias | Fair | Heterogeneity in outcome measures | Insufficient | Unclear whether findings apply to groups not defined by parent risk factors
KQ 1: School attendance | School-age children/families | 2; 2,818^131,138,149,150^ | 1 study reported statistically significant difference in attendance based on child report: Child-reported school attendance at age 7: 9/388 (2.35%) vs. 26/405 (6.47%); RR, 0.36; 95% CI, 0.17 to 0.76^138^; No difference in maternal reports of skipping school or reports from school records^138,149,150^ | Inconsistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity in outcome measures; self-report, maternal report, pupil database; inconsistency between child and maternal reports | Insufficient | Unclear whether findings apply to groups not defined by parent risk factors
KQ 1: Death | Pregnant or postpartum women; 5 studies included only women at risk for maltreatment, 5 studies included home visiting, 1 study included group intervention | 6; 2,900^112,114,119,128,131,132,141,149,150^ | 0 of 6 trials reported statistically significant differences in death | Consistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity in included studies | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Composite maltreat-ment outcome^**^ | Mothers of newborns | 1; 136 mothers^128^ | 2/65 (3.1%) vs. 9/71 (12.7%); RR, 0.24; 95% CI, 0.05 to 1.08; Adjusted RR, 0.22 (95% CI, 0.02 to 0.98; p=0.04) | Consistency unknown (single trial)/imprecise | No evidence of reporting bias | Fair | Single small trial | Insufficient | Unclear whether findings apply to subgroups other than teenage first-time mothers
KQ 2: Harms | Pregnant women; 2 home-visiting studies | 2; 1,784^131,132,149–151^ | 0 of 2 trials reported statistically significant differences in harms | Consistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity in outcome assessment | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors

* Long-term CPS reports: AOR, 0.48; 95% CI, 0.23 to 1.0, in one study (3 year followup, 157 participants);^111^ calculated RR, 0.95; 95% CI 0.80 to 1.12 in second study (6-year followup; AOR, 1.13, 1,506 participants);^149,150^ p>0.1 in third study (5-year followup, 1,173 participants);^117,138,139^ p=0.04 in fourth study (13-year followup, 216 participants, no effect size provided).^144,145^

† Abuse is defined as “hitting with the hand or objects, biting, burning with objects or by immersion, twisting, shaking, throwing or pushing so as to cause a fall, or hair pulling;” identified from review of public agency documents from the Tennessee Department of Human Services.

ǂ Defined as abandonment, leaving a child with an inappropriate caretaker, gross failure to seek medical care, failure to provide shelter or nutrition, or gross failure to provide for normal intellectual development; identified from review of public agency documents from the Tennessee Department of Human Services.

§ Outcomes with no statistically significant results include number of hospitalizations because of nonaccidental injury to the neonate (1 study), number of children hospitalized because of child abuse and neglect (1 study), proportion of children hospitalized for injuries and ingestions (2 studies), number of children hospitalized for ambulatory-care sensitive conditions (1 study), number of children rehospitalized (1 study), mean number of all-cause hospitalizations (5 studies), and total count of hospital stays (2 studies).

ǁ One study reported statistically significant differences on each of the following: mean and proportion of children with higher externalizing behaviors at 12 months; internalizing behaviors at 2 years and 3 years; behavior problems at 5, 6, and 9 years.

¶ Outcomes with no statistically significant results include internalizing behaviors at 6 and 12 months (1 study); child behavior at 2 years (1 study), 30 to 33 months and 5.5 years (1 study), and 7 years (1 study); and internalizing and externalizing behaviors at 9 years (1 study).

# Outcomes included dysregulation, sleep problems, problems with social skills, attention and social problems, school-related conduct outcomes, and infant social and emotional adjustment.

** Defined as infant death, severe nonaccidental injury, and involuntary foster care placement.

Abbreviations: AOR=adjusted odds ratio; CI=confidence interval; CPS=child protective services; ED=emergency department; EPC=Evidence-based Practice Center; KQ=key question; OR=odds ratio; RR=relative risk; vs.=versus.

## Summary of Review Findings

### Benefits of Interventions (Key Question 1)

Table 3 provides a summary of the main findings in this evidence review organized by KQ, along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability. The evidence on the effect of interventions that are feasible in or referable from primary care settings on short-term outcomes for interventions to prevent child maltreatment on reports to CPS, removal of the child from the home, ED visits, and hospitalizations suggests no benefit (Table 3). Long-term results of the same outcomes are not consistent. At or beyond the 3-year followup, two trials reported fewer CPS reports^111,144,145^ and two did not.^117,138,149,150^ One^143^ of three trials^143,147,149,150^ reporting on ED visits at or beyond the 4-year followup found lower rates of ED visits in the intervention arm. Other concerns with long-term outcomes include risks of contamination (where elements of the intervention become part of usual care over time or where individuals in the usual care arm receive the intervention) or unmeasured co-interventions. Additionally, interpretation of some outcomes can be challenging. Lower rates of all-cause ED visits or hospitalization may represent changes in patterns of healthcare utilization as a result of the intervention rather than lower rates of abuse or neglect. The evidence was also inconclusive for other outcomes, based primarily on the limited number of trials reporting on each outcome and lack of statistically significant results. These include injuries, failure to thrive, failure to immunize, internalizing and externalizing behavior symptoms, child development, school attendance, school performance, prevention of death, and other measures of abuse or neglect.

Significant uncertainties persist in interpreting the evidence. Ethical study design demands comparisons of interventions to prevent child maltreatment with enhanced or active usual care. The extent to which interaction with observers and care providers in the usual care arm mutes intervention effects remains unclear. Surveillance bias in the intervention arm may also serve to raise the rates of negative outcomes (for example, safeguarding actions,^131^ reports to CPS,^133^ or ED visits^132^) in the intervention arm, further obscuring potential benefits of the interventions.

Despite the inclusion of a wide range of potential direct or proxy measures of child maltreatment outcomes and child well-being outcomes, we found no consistent evidence of benefit. For some outcomes, such as internalizing and behavior scores in one study,^118^ despite statistically significant evidence of improvement in the intervention arm, very small differences between arms raise questions of clinical significance.

The KQs for this update include an explicit focus on intervention effectiveness for populations of interest. Although we found evidence for positive effects on some education-related outcomes for populations with greater need (“low psychological resources,” defined as “limited intellectual functioning, poor mental health, and low sense of control over their life circumstances”^141,^ ^p. 3^), differences in the ways the samples were stratified limit our ability to come to conclusions. Outcomes for mothers with limited intellectual functioning may differ substantially from mothers with poor mental health for widely varying reasons.

Our evidence consisted entirely of RCTs and almost entirely of interventions that included home visits. Trials generally focused on young mothers and drew from populations characterized as vulnerable. These similarities permitted qualitative and quantitative syntheses. Some interventions, such as the Nurse Family Partnership and Healthy Families, were tested in multiple settings. Nevertheless, the 25 included trials may have differed in other characteristics, such as the populations of interest, baseline risk of maltreatment, intervention intensity and duration, and outcomes measured. These reported and unreported characteristics may explain variations in the effectiveness of the intervention, but the evidence base for each outcome was not extensive enough to identify any patterns, especially in the context of consistent lack of statistically significant effect on many included outcomes.

### Harms of Interventions (Key Question 2)

Two studies did not report statistically significant adverse events between study arms. However, the studies focused on rare harms (such as miscarriages, terminations, stillbirth, infant or neonatal death, maternal death), and as a result, the findings were inconclusive. No studies reported on harms such as stigma, labeling, legal risks, risks of further harm to the child, or dissolution of families, or worsening of inequities. In the context of the limitations on risk assessment as a tool for screening (and therefore as a tool for assessing eligibility for preventive interventions), the risk of surveillance bias in intervention arms leading to a higher risk of reporting to CPS and removal of the child from the home, and the presence of racial and ethnic disparities in reporting to CPS, the burden of these harms has the potential to fall disproportionately on families of color. No study, however, evaluated how harms varied according to factors such as race and ethnicity.

### Contextual Issues

CQs present information on the current practices in identification/diagnosis and reporting and variations by race and ethnicity in these practices (CQ 1), the accuracy of risk assessment tools (CQ 2), and the association between child maltreatment prevention interventions and SDOH (CQ 3) (Appendix A provides detailed results). In brief, our findings for CQ 1 highlight the wide variations in reporting practices, clear presence of disparities by race and ethnicity in reporting, and lack of clarity on reasons for these differences. They also suggest that guidelines, when clear and consistent as in the case of diagnosis, can help reduce racial and ethnic disparities in practice. Our findings for CQ 2 indicate poor to good accuracy of risk assessment tools. The potential risks of false-positives (e.g., family separation, trauma for the child and parent, costs) limit reliance on screening as an approach to identifying those at risk. Regarding the association between interventions to prevent child maltreatment and outcomes representing SDOH (CQ 3), 18 of the 25 studies included for this review addressed a SDOH-related outcome. Studies evaluated multiple, diverse SDOH-related outcomes, measured using disparate methods and at multiple time points. Overall, effects of interventions were mixed with some positive changes in some SDOH outcomes reported for intervention vs. control groups (e.g., receipt of well-child care and social support) and no group differences reported for other outcomes. Four studies reported SDOH-related outcomes in subpopulations defined by factors including socioeconomic status and intensity of intervention. Although subgroup definitions varied, one study suggested that groups characterized by higher socioeconomic need (as defined by greater use of social services) had higher risk of being reported for maltreatment, but other studies also found that those characterized by higher socioeconomic need experienced greater improvements in SDOH outcomes after receiving child maltreatment interventions than overall study populations. Because surveillance bias may be a factor in explaining the higher rates of maltreatment outcomes in intervention participants with greater social needs, more and better evidence is needed to clarify when and to what extent child maltreatment interventions are linked with improving SDOH and reducing child maltreatment outcomes.

## Limitations of the Review

A primary limitation of the scope of the review is its focus on primary care relevant interventions and their effect on direct or proxy measures of maltreatment. This scope is consistent with the remit of the USPSTF, but it does not address all potentially relevant policy solutions to prevent child maltreatment, such as changes in social policy at the national, State, county, or municipal level or community or universal interventions that are not primary care referable. In keeping with the intended scope of the review, we restricted inclusion to studies focused on preventive interventions for children who had not yet experienced maltreatment. Therefore, we are unable to determine whether child maltreatment prevention interventions are effective for children who have experienced maltreatment. Although our contextual assessment suggests at least some benefits for SDOH, our review does not address other outcomes such as family or maternal well-being or mental health.

In keeping with USPSTF methods, we summarize the results of trials rated as fair or good quality. In the previous update, we had also included a wide array of other trials rated as poor quality and found in sensitivity analyses that the inclusion of poor-quality trials did not materially change our findings of insufficient evidence or evidence of no benefit. Our restriction to English-language publications and very highly developed countries limits the applicability of the review to other countries.

Although the vast majority of included interventions included home visiting components, our specific focus on studies reporting direct and proxy measures of child maltreatment means that our report cannot speak to the efficacy of home visiting for other outcomes. Other sources address the evidence on overall effectiveness of home visiting directly.^153^

## Limitations of the Evidence

The limitations of the evidence are largely unchanged from the prior review. Even outcomes specified as “direct” measures of child maltreatment may be prone to under- and overreporting, leading to challenges in interpreting the evidence. A key limitation pertains to the diversity of the interventions and the resultant heterogeneity. Although all but two trials had a home-visiting component, several aspects of this particular activity differed. These included the nature and theoretical basis of the interventions delivered during the home visits, credentials of the home-visiting staff, and intensity and duration of the intervention.

In addition, all trials involved implementing multiple components. Complex, multicomponent interventions need to report the theoretical foundation for the intervention to help interpret the results and reproduce successful interventions.^154^ Study authors generally did not provide a theory of change or logic model that identified components essential to the success of the intervention. Without theoretical or contextual information on critical intervention components, we cannot determine how successful interventions are different from unsuccessful interventions. This lack of information limits our ability to understand when and how interventions work. Because of the link between SDOH and the risk of child maltreatment, analyses of effects in populations with greater need are of particular interest. Some stratified analyses of intervention effects in these populations of interest are available, but studies generally do not explain the reasoning behind grouping diverse participants. In interpreting the results for educational outcomes in a group of mothers with “low psychological resources,”^141^ the mechanism of action and specific needs may be vastly different for mothers with limited intellectual functioning and mothers with poor mental health.

The issue of applicability of the findings to other pediatric or caregiver populations (e.g., with lower or higher risk profiles) and other settings (e.g., with fewer resources) remains uncertain.

Studies focusing on short-term outcomes of relatively rare events such as hospitalizations, removal from the home, and reports to CPS generally did not find statistically significant results. The few trials that did assess measures over the long term reported mixed results. The extent to which positive results in long-term trials can be attributed to the interventions themselves, to contextual factors such as the resources and abilities of the investigators and sponsoring institutions, or to intervening factors is unclear.

## Future Research Needs

Child maltreatment causes undeniable harm to children and is relatively common. One in 58 children in the United States in 2005–2006 experienced harm from maltreatment, and one in 25 was at risk of harm.^68^ Preventive interventions offer an opportunity to decrease the risks of maltreatment and avert long-term sequalae for children and families. However, child maltreatment prevention trials in the United States operate in the context of inaccuracies in risk assessment, racial and ethnic bias in reporting and diagnosis of child maltreatment, and poor outcome measurement. Interventions to prevent maltreatment, in this context, may not always be offered to those in need. The process of identification of participants eligible for the intervention, when paired with “at-risk” terminology, may cause harms from stigma, labeling, legal risks, and family separation and dissolution. Multiple studies included in the review have raised surveillance bias in the intervention arm as a potential explanation for higher rates of direct or proxy measures of child maltreatment in the intervention arm. When interventions to prevent child maltreatment are implemented, difficulties around measuring child maltreatment directly or through proxies impede an accurate understanding of the benefits of the intervention. Future research on child maltreatment interventions that incorporate provider education about implicit bias offer another approach to addressing surveillance bias.

Another consideration for future research is that many root causes of maltreatment stem from unmet social needs. In fact, many included interventions in this review aim to address family well-being. Framing future work in the context of child and family well-being offers an opportunity to address a serious and potentially preventable problem while minimizing the constraints associated with measuring risk and outcomes of child maltreatment.

The work of ensuring child safety is not solely within the purview of the healthcare system. Child safety requires interfacing with the education system, childcare system, CPS, and law enforcement. The ability of primary care to intervene on an outcome like substantiated child abuse reports is limited by these interfaces where the work of healthcare ends and the work of other systems begins. Additionally, interventions that attempt to address multiple risk factors may require structural changes in the community and/or changes to policy to be fully implemented. These types of interventions (such as universal child care as a policy to prevent child maltreatment^155^), while likely effective, are outside the scope of the USPSTF. The suggested change to focus on child and family well-being reframes the question to focus on those components of ensuring child safety for which primary care and thus the USPSTF are best suited: coordination and support for children and families; active facilitation of and connection to services address SDOH; and provision of fundamental healthcare, like vaccines and well-child checks. Primary care–relevant research can focus on the components of child safety within the purview of healthcare rather than attempting to intervene indirectly on things that are not.

Research, in this expanded framework, must still be able to support causal links between the intervention and outcomes. Improving child and family well-being will require multiple, complex interventions. Designing studies to support causal claims and promote implementation requires articulating the mechanism of action, clarifying the effects of specific intervention components (such as intensity, duration, and modality), identifying the benefits in the group with the highest need, and following participants for a sufficient length of time to record relevant outcomes. For instance, the links between interventions that address social needs alongside child maltreatment prevention efforts, uptake of social needs, and improvement of child maltreatment outcomes need to be clearly articulated and examined. RCTs may face substantial challenges in design and recruitment, leading to the need for pragmatic trials (such as stepped-wedge designs) and observational study designs. Community-based participatory research approaches can enhance recruitment and ensure that interventions are designed to address patient and community social needs and risk factors.

Racial bias may influence the measurement of proxy and direct measures of maltreatment; low event rates further limit their ability to meaningfully measure change. Limitations in the validity and reliability of measurement of self- and parenting reporting serve as further challenges. Potential areas for research include more reliable and valid measures from youth self-report and the development and validation of composite outcomes with potentially higher event rates. Rates of harms, including those arising from surveillance, for racial and ethnic populations of interest will be important to document in future trials.

## Ongoing and Unpublished Studies

We identified several ongoing trials that are potentially relevant to this topic. One is a Japanese trial to evaluate the efficacy of an internet-based behavioral activation therapy program via smartphone (Smart Mama) for postnatal mothers; the program aims to reduce depression symptoms among mothers and reduce child abuse.^156^ No results have been published to date. A second trial implemented Minding the Baby, an interdisciplinary, home-visiting program to support first-time young mothers in the United Kingdom; no eligible outcomes were reported in initial results.^157,158^ One trial implementing Minding the Baby in the United States has been included in this review.^125^ Six ongoing trials conducted in the United States are currently enrolling participants. These trials include Enhanced First Connections, a short-term, perinatal, home-visiting program that aims to prevent child abuse and neglect and reduce child exposure to intimate partner violence;^159^ Personalized Education Regarding Clinical and Community Supports, which provides an enhanced level of engagement in resource navigation;^160^ and a group caregiver training program (PriCARE/CARIÑO) designed to improve child behaviors, caregiver-child relationships, parenting capacity, and reduce caregiver stress.^161^ Three of the six trials are being conducted among women with substance use disorders. In one trial, participants will be referred to the Substance Use Treatment and Recovery (STAR) prenatal clinic or to STAR plus home visits from a licensed therapist focused on attachment and positive parenting in substance exposed babies.^162^ In another ongoing trial (Parent-Child Assistance Program), case managers work closely with mothers who have used alcohol, opioids, or other drugs during pregnancy, meeting the mothers in their homes, when possible, to help them to set goals and take advantage of available resources.^163^ The third ongoing trial is enrolling mothers with substance use disorder and is evaluating a novel mother–child therapeutic model, with the goal of improving child well-being, permanency, and safety and reducing the risk for involvement in the child welfare system.^164^ We also identified one trial of the Navy and Marine Corps’ New Parent Support Program home-visiting program that is in the pre-recruitment phase, with an estimated study completion date of November 2024.^165^

## Conclusions

The evidence base on interventions feasible in or referable from primary care settings to prevent child maltreatment suggests no benefit for some outcomes (reports to CPS, removal of the child from the home, visits to the ED, hospitalization, child development) and is insufficient to demonstrate benefit for other direct or proxy measures of child maltreatment. Limited or no information was available about possible harms.