# Chapter 3 Results

## Literature Search

We identified 6,576 unique records and assessed 189 full texts for eligibility (Figure 2). We excluded 146 records for various reasons detailed in Appendix C and included 25 RCTs of good or fair quality (in 43 articles). Twenty-five trials addressed KQ 1, and 2 addressed KQ 2. Of the 25 included trials, 22 (in 33 articles) were included in the 2018 review. Details of quality assessments of included studies and excluded studies based on poor quality are provided in Appendix E. Appendix D Tables 1–5 present detailed background characteristics for included studies for KQ 1 and KQ 2; an overview of study characteristics is presented below, followed by detailed study results. Study results are organized by outcome and, within outcome, are summarized for the overall population and then populations of interest (child or caregiver socio-economic, demographic, or other characteristics).

Figure 2 Literature Flow Diagram

Abbreviations: KQ=key question; RCT=randomized controlled trial; USPSTF=U.S. Preventive Services Task Force.

This figure summarizes the search and selection of articles. There were 6,546 references identified through database searching and 30 citations identified from other sources, resulting in 6,576 citations screened for potential inclusion. Of these, 6,420 were excluded. We added 33 articles from the previous USPSTF review, resulting in 189 full-text articles assessed for eligibility. After full-text review, 146 articles were excluded: 3 for ineligible publication type, 12 for ineligible population, 8 for ineligible/no intervention, 4 for ineligible/no comparison, 77 for ineligible/no outcomes, 1 for ineligible/nonclinical setting, 14 for ineligible study design, 2 for ineligible country, 1 non-English full text, 17 for relevant protocol or ongoing study, 2 for duplicate, and 5 for poor quality. We included 25 RCTs from 43 publications. For RQ1, we included 25 RCTs from 43 publications. For RQ2, we included 2 RCTs from 5 publications.

### Study Characteristics

Twenty-five trials comprising 42 publications, reported on benefits;^110–152^ of these, two trials, comprising five publications reported on harms.^131,132,149–151^ Table 2 describes summary characteristics. The majority enrolled participants in the prenatal period or immediately after birth (60%). A minority of studies did not recruit participants based on risk of maltreatment (32%); the other studies either recruited participants based on parents being at risk of maltreating children or children being at risk of maltreatment because of prematurity or low birthweight. Although studies that included a majority of participants who had previously been reported for maltreatment were ineligible for the review, 24 percent of the studies included at least some but not a majority of participants who had previously been reported for maltreatment. Almost a third of the studies recruited young mothers (<20 years of age). Nearly two thirds of studies included a population that was ≥25 percent non-White, and nearly one quarter of studies included a population that was ≥25 percent Hispanic or Latina/o. All but two were home-visiting interventions.^123,132,151^ Home-visiting interventions included support and information related to topics such as positive parent-child interactions, child health and development, social support, child environmental safety, and health behavior during pregnancy and early childhood. Some interventions also included medical care, referrals, and linkages to community resources. Many of the interventions included weekly or monthly home visits; home-visiting intervention duration ranged from 3 months to 3 years. Of the two trials that were not home-visiting interventions, one was a clinic-based intervention for parents entering outpatient substance abuse treatment,^123^ and the other was a group Family Nurse Partnership intervention held in children’s centers, health centers, or other community facilities.^132,151^ A majority of trials included clinical personnel (e.g., nurses, midwives, social workers, therapists) (67%). All but three studies compared interventions with usual care.^115,123,127^

Table 2 Characteristics of Interventions to Prevent Child Maltreatment

Study Characteristics^*^ | Subcharacteristics | Number of Studies | Percentage
Study quality | Good-quality studies | 1 | 3.3%
| Fair-quality studies | 24 | 80%
| Poor-quality studies | 5 | 16.7%
Population characteristics: Enrollment | Enrolled in prenatal period or immediately after birth | 15 | 60%
| Enrolled prenatally, immediately after birth, and after the perinatal period | 1 | 4%
| Enrolled after the perinatal period | 9 | 36%
Population characteristics: Maltreatment reported at baseline | Reported maltreatment at baseline | 6 | 24%
| Did not report maltreatment at baseline | 19 | 76%
Population characteristics: Risk status | Parent identified to be at risk | 15 | 60%
| Child identified to be at risk because of birth status (premature or low birthweight) | 2 | 8%
| Participants not specifically identified to be at risk | 8 | 32%
Population characteristics: Age of mother | Most or all mothers younger than age 20 years | 7 | 28%
| Mothers age 20 years or older on average | 18 | 72%
Population characteristics: Race | Study population ≥25% non-White | 16 | 64%
| Study population <25% non-White | 5 | 20%
| Study population race NR | 4 | 16%
Population characteristics: Ethnicity | Study population ≥25% Hispanic or Latina/o | 6 | 24%
| Study population <25% Hispanic or Latina/o | 6 | 24%
| Study population % Hispanic or Latina/o NR | 13 | 52%
Intervention characteristics: Home visits | Home visit component | 23 | 92%
| No home visit component | 2 | 8%
Intervention characteristics: Personnel | Clinical personnel involved in care | 17 | 68%
| No clinical personnel | 8 | 32%
Comparator | Usual care comparator | 22 | 88%
| No usual care comparator^†^ | 3 | 12%
Geographic setting | United States of America | 18 | 72%
| United Kingdom | 4 | 16%
| Canada | 1 | 4%
| Australia | 1 | 4%
| New Zealand | 1 | 4%

* For all characteristics other than study quality, the table presents data from good- or fair-quality studies only.

† One study compared standard behavioral couples therapy or combined parent skills and behavioral couples therapy with individual-based treatment;^123^ a second study compared a cognitively based extension of the Healthy Start home visitation program with a visitation condition that did not include this component;^115^ and a third study compared home visits with no home visits or other forms or intervention.^127^

The other three compared child maltreatment–specific intervention variants with more intense care or with no care.^115,123,127^ Specifically, one study compared standard behavioral couples therapy or combined parent skills and behavioral couples therapy with individual-based treatment;^123^ a second study compared a cognitively based extension of the Healthy Start home-visitation program with a visitation condition that did not include this component;^115^ and a third study compared home visits with no home visits or other forms or intervention.^127^ Most included studies were conducted in the United States (72%);^110,111,113–117,119–126,129^ ^,133,137,138,141,143–147,152^ other studies were set in the United Kingdom,^112,130,131,132^ ^,136,148–151^ Canada,^127^ Australia,^128^ and New Zealand.^118^ ^,140^ Ten studies specified primary study outcomes, which included reports to CPS for child maltreatment, child injury, birthweight, emergency hospital attendance and admission for the child, mother-child interaction, maternal characteristics (mental health, substance use, smoking, dyadic adjustment, reflective functioning, incidence of rapid subsequent childbearing, knowledge of contraception, breastfeeding, and infant vaccination), intimate partner violence, and incidence of adverse neonatal outcomes (infant death, severe non-accidental injury, and non-voluntary foster care).^110,112,116,123,125,128,130–137,148–151^

## Results by Key Question

### Key Question 1 Benefits of Interventions to Prevent Child Maltreatment on Direct Measures of Maltreatment

#### Direct or Proxy Measures of Child Maltreatment

##### Reports to Child Protective Services

Fifteen trials analyzed reports to CPS (Appendix D Tables 6–9).^110–112,114,116–118,121–126,131,133,135–140,143–146,149,150^ All except one trial reported initial results during the intervention (1 year from baseline), at the end of the intervention, or within a year of the completion of the intervention. The exception was a study that reported safeguarding actions at the end of the intervention when the child was 2 years old (addressed under “other measures of abuse and neglect”) but reported referral to children’s social care for abuse or neglect when the child was 6 years old. A subset of trials reported outcomes at one or more time points after the first analysis of results. The timing of these reports varied, from within 6 months of the initial results^111,117,126^ to 1 to 2 years after the initial results^111^ or over a longer term (6 years after the initial results,^117^ when the child was 7 years of age,^138^ or 13 years after the initial results, when the child was 15).^144–146^

Results for first followup. The pooled odds ratio (OR) from 11 trials, all having reported results within about a year of completion, suggested no difference between study arms (OR: 1.03 [95% confidence interval {CI}, 0.84 to 1.27]; I^2^: 10.2%; 12.9% [341/2635 from 10/11 trials providing event rates] vs. 12.2% [307/2519 from 10/11 trials providing event rates]; N=5,311; Figure 3). All studies included in the meta-analysis reported results with no statistically significant benefit at first followup. Four trials did not contribute to the meta-analysis. One trial reported only relative risks (RR; i.e., no raw data) with asymmetric CIs that we could not recalculate (RR: 1.35 [95% CI, 0.86 to 2.11]).^136^ A second trial provided counts without standard deviations or frequencies (no statistically significant differences; results not reported).^122^ A third trial did not specify the time period of outcome measurement, reporting only that the arms did not differ significantly, with a reported p=0.769.^110^ A fourth trial reported safeguarding in the United Kingdom at 2 years, included under “other measures of abuse or neglect,” and measured referrals to children’s social services for abuse or neglect at 6 years;^131,149,150^ this outcome is summarized in the section on long-term followup below.

Figure 3 Child Protective Services Reports: Pooled Results

I^2^ = 10.2%

Abbreviations: CI=confidence interval.

This figure displays a forest plot of the pooled results for child protective services reports. The first study is Brooten et al., 1986. The intervention was home visits and followup was 18 months. The odds ratio (OR) was 0.49 (lower limit: 0.08; upper limit: 2.82). The second study is Duggan et al., 2007. The intervention was home visits and followup was 1 year. The OR was 1.31 (lower limit: 0.73; upper limit: 2.35). The third study is Dumont et al., 2008. The intervention was home visits and followup was 1 year. The OR was 1.35 (lower limit: 0.84; upper limit: 2.17). The fourth study is Fergusson et al., 2005. The intervention was home visits and followup was 3 years. The OR was 0.90 (lower limit: 0.55; upper limit: 1.47). The fifth study is Finello et al., 1998. The intervention was home health and followup was 6 months. The OR was 3.15 (lower limit: 0.12; upper limit: 82.16). The sixth study is Green et al., 2017. The intervention was home visits and followup was 2 years. The OR was 1.18 (lower limit: 0.94; upper limit: 1.47). The seventh study is Lam et al., 2009. The intervention was combined and followup was 12 months. The OR was 0.39 (lower limit: 0.04; upper limit: 3.77). The eighth study is Lowell et al., 2011. The intervention was home visits and followup was 6 months. The OR was 0.59 (lower limit: 0.25; upper limit: 1.38). The ninth study is Olds et al., 1986. The intervention was combined and followup was 2 years. The OR was 0.61 (lower limit: 0.22; upper limit: 1.65). The tenth study is Sadler et al., 2013. The intervention was home visits and followup was 2 years. The OR was 0.15 (lower limit: 0.01; upper limit: 3.15). The eleventh study is Silvosky et al., 2011. The intervention was home visits and followup was 2 years. The OR was 0.57 (lower limit: 0.23; upper limit: 1.39). The pooled OR was 1.03 (lower limit: 0.84; upper limit: 1.27). I2 = 10.2%.

Results for subsequent followup. Trials reporting additional results within 6 months^126^ or 1 year^111,117^ of the original results also reported no difference between the arms.

Trials measuring outcomes for later time points provided mixed results: two trials reported statistically significant differences and two reported no differences. One trial measured outcomes at 36 months from baseline and reported a statistically significant difference favoring the intervention arm; the trial reported a higher probability of no involvement with CPS in the intervention arm (adjusted odds ratio [AOR], 2.1 [95% CI, 1.0 to 4.4], N not reported).^111^ One trial reporting referral to children’s social care for abuse or neglect reported similar proportions between intervention and control arms by 6 years followup, 4 years after initial reports of safeguarding actions (198/760 [58.9%] vs. 205/746 [57.9%]; calculated RR, 0.95 [95% CI, 0.80 to 1.12]).^149,150^ A third trial reported outcomes at 7 years (5 years after the end of intervention^117,138^) and reported no differences between arms in the cumulative rate of the biological mother or the target child being confirmed as a subject (presumably perpetrator) or a victim in CPS reports through 7 years of age (27.1% vs. 29.6%; AOR, 1.13, p>0.1; CIs not reported [161/594 vs. 171/579; calculated OR, 1.13 {95% CI, 0.87 to 1.45}]).^138^ A fourth trial followed children through age 15 but did not provide sufficient details for independent calculation of effects. The authors noted that the intervention group had fewer child maltreatment reports involving the mother as perpetrator (p=0.01),^145^ fewer child maltreatment reports involving the study child (p=0.04),^145^ and fewer verified reports of parents as perpetrators of child abuse and neglect (p<0.001).^144^ This trial also evaluated time to event and found that the treatment effect by time period was significant, with longer periods without CPS reports for children ages 4 to 15 years than for children from birth to age 4 years.^146^

Intervention effectiveness for populations of interest. One study reported on subgroup analyses focusing on populations of interest.^117^ The study focused on a “High Prevention Opportunity” subgroup comprising young, first-time mothers who initiated home-visiting services prenatally.^117^ The results in the populations of interest were consistent with the results for the overall sample at age 7 years and did not demonstrate a statistically significant benefit for the intervention arm for substantiated CPS reports.^117^ A second study reported no statistically significant differences between intervention and control arms for reports to CPS between 25 and 48 months^143^ or substantiated child maltreatment reports involving mother as perpetrator at age 15 years^146^ for low-income, unmarried teens. These results were consistent with the results for the overall sample.

##### Removal of Child From Home

Six trials^112–114,120,128,133,136^ reported on outcomes relating to removal of the child from the home. Five trials contributed to a pooled analysis of removal of the child from the home across time points ranging from 12 months to 3 years after baseline (Appendix D Tables 10 and 11).^112–114,128,133,136^ The results show no statistically significant differences between study arms on this outcome (3.9% [68/1751] vs. 3.5% [55/1585]; RR, 1.06 [95% CI, 0.37 to 2.99]; I^2^, 49.9%; 5 trials; N=3,336; Figure 4). All studies included in the meta-analyses reported results with no statistically significant benefit at first followup. One study reported on number of days in out-of-home placement and reported no differences (15.2 days for the intervention vs. 12.7 days for the comparator arm, p=0.430).^133^

Figure 4 Removal of the Child From the Home: Pooled Results

I^2^ = 49.9%

Abbreviations: CI=confidence interval.

This figure displays a forest plot of the pooled results for removal of the child from the home. The first study is Barlow et al., 2007 and the timepoint is 12 months. The risk ratio is 8.35 (lower limit: 0.46; upper limit: 152.00). In the intervention, n=4 experienced removal out of a total of 68. In the control, n=0 experienced removal out of a total of 63. The second study is Brayden et al., 1993 and the timepoint is 36 months. The risk ratio is 4.33 (lower limit: 0.51; upper limit: 36.53). In the intervention, n=5 experienced removal out of a total of 141. In the control, n=1 experienced removal out of a total of 122. The third study is Brooten et al., 1986 and the timepoint is 12 months. The risk ratio is 0.21 (lower limit: 0.01; upper limit: 4.14). In the intervention, n=0 experienced removal out of a total of 39. In the control, n=2 experienced removal out of a total of 40. The fourth study is Green et al., 2017 and the timepoint is 24 months. The risk ratio is 1.16 (lower limit: 0.79; upper limit: 1.71). In the intervention, n=57 experienced removal out of a total of 1438. In the control, n=44 experienced removal out of a total of 1289. The fifth study is Quinlivan et al., 2003 and the timepoint is 12 months. The risk ratio is 0.27 (lower limit: 0.06; upper limit: 1.24). In the intervention, n=2 experienced removal out of a total of 65. In the control, n=8 experienced removal out of a total of 71. The pooled risk ratio is 1.06 (lower limit: 0.37; upper limit: 2.99). In the intervention, n=68 experienced removal out of a total of 1751. In the control, n=55 experienced removal out of a total of 1585. I2 = 49.9%.

One trial, reporting on removals at birth, included CPS-involved placements and informal care arrangements (type of placement by study group not specified).^120^ The trial also collected data on the percentage of women with one or more children in out-of-home care at followup but did not differentiate new removals from placements at the time of birth after the index pregnancy. Because of measurement issues with the followup outcome, we focused on removal rates only at birth and did not include results in the pooled analysis above. This trial reported results no statistically significant difference between study arms; 9 percent of the intervention group and 4 percent of the control group had been placed in out-of-home care at birth (the intervention began during pregnancy) (N=187/225; RR, 2.33 [95% CI, 0.66 to 8.20]).

Intervention effectiveness for populations of interest. No studies reported on intervention effectiveness for out-of-home placements for populations of interest.

##### Other Measures of Abuse or Neglect

Two RCTs^113,115^ reported on study-specific measures of abuse (Appendix D Tables 12 and 13). These measures included physical abuse (i.e., hitting with the hand or objects, biting, burning with objects or by immersion, twisting, shaking, throwing or pushing so as to cause a fall, or hair pulling; identified from review of public agency documents from the Tennessee Department of Human Services)^113^ and neglect (i.e., abandonment, leaving a child with an inappropriate caretaker, gross failure to seek medical care, failure to provide shelter or nutrition, or gross failure to provide for normal intellectual development; identified from review of public agency documents from the Tennessee Department of Human Services,^113^ and results from the Framingham Safety Survey about household hazards^115^). One trial reported no differences, finding 13/141 cases (9.2%) of physical abuse in the intervention arm vs. 8/122 (6.6%) in the comparator arm (RR, 1.45 [95% CI, 0.58 to 3.62]). The same study^113^ reported 15/141 (10.6%) cases of neglect in the intervention arm vs. 5/122 (4.1%) in the comparator arm (RR, 2.79 [95% CI, 0.98 to 7.91]).^113^ The second reported a statistically significant difference on the Framingham Safety Survey, but the clinical importance of the effect is unclear because the scale range is not reported. The trial reported mean values on the Framingham Safety score of 1.72 (intervention) vs. 1.68 (comparator); higher scores represent greater safety. The trial noted a p-value of 0.03 for this outcome but provided no measures of dispersion for us to calculate mean differences independently.^115^ A third trial reported safeguarding (that is, actions to protect children from harm and promote their welfare) in the United Kingdom. This outcome included actions beyond reports to child protection. The outcome came from any record in general practitioner notes indicating the initiation, progression, or closure of a safeguarding process.^131^ These records included initial assessment, being identified as a child in need, and child protection conferences. The study found higher rates of safeguarding in the intervention arm (AOR, 1.85 [95% CI, 1.02 to 2.85]).^131^

Intervention effectiveness for populations of interest. No studies reported on intervention effectiveness for out-of-home placements for populations of interest.

##### Injuries With a High Specificity for Abuse or Neglect

One trial reported only one nonaccidental injury in the control arm (0/65 vs. 1/71; calculated RR, 0.36 [95% CI, 0.015 to 8.77]) (Appendix D Table 14).^128^

Intervention effectiveness for populations of interest. No studies reported on intervention effectiveness for injuries with a high specificity for abuse or neglect for populations of interest.

##### Emergency Department Visits

Fourteen trials reported on ED visits (Appendix D Tables 15–18);^112,114,116,118,119,121,122,126,127,129–132,136,137,140,141,143–150,152^ when specified, lower ED visits in the intervention arm were interpreted as beneficial. The timing and type of outcome measurement varied substantially across trials; several trials presented outcomes at multiple time periods. To ensure that we captured all the evidence without inappropriately combining different periods of followup, we present the results by timing of outcome measurement first and then by type of outcome measurement for each time period. The results were generally inconsistent in direction of effect.

Results for followup <1 year. One trial reported infant “accident and emergency” (A&E) visits at 2 months of age and found a mean difference of 0.19 greater ED visits in the intervention arm compared with the control arm (calculated 95% CI, 0.02 to 0.36).^132^ Two of three trials that reported outcomes at 6 months of corrected gestational age found no statistically significant difference in the percentage of infants in each of four arms who visited the ED from age 0 to 6 months (p=0.637 in one study^126^ and AOR, 1.52 [95% CI, 0.86 to 2.70] in the second study^131^). A third study reported statistically significant differences favoring the intervention arm in the number (mean not reported, p=0.023) and proportion of patients with ED visits (36.5% vs. 49.7%, p=0.021) at 6 months when compared with the control arm.^152^ The same trial found that benefits were no longer statistically significant at 1 year (presented below).

Results for followup from 1 to <2 years. Of these 13 trials, eight reported ED visit outcomes between 1 and 2 years after enrollment or recruitment.^112,121,122,126,127,130,132,136,143–146,148,152^ Measurement of outcomes varied and included (1) mean number of all-cause ED visits, (2) mean number of ED visits for accidents and poisonings, (3) number of children using the ED for any reason, and (4) total ED visits. Overall, the results are inconsistent in demonstrating benefit.

Because four of seven trials reporting on the mean number of all-cause ED visits do not provide measures of dispersion, the results cannot be pooled.^122,127,136,152^ Six trials reported no statistically significant differences.^122,127,130,132,136,148,152^ One study found that the nurse home-visiting group had fewer total ED visits at 12 months with a mean difference of 0.28 (95% CI, 0.08 to 0.48; p=0.04).^121^

One trial reported the mean number of ED visits for accidents and poisonings at 12 months.^121^ For ED visits for accidents and poisonings, there was no statistically significant difference between study arms.^121,143–146^

Three trials calculated RRs for the number of children in each group who visited the ED for any reason.^126,130,148,152^ Two trials found no statistically significant differences for intervention arms compared with usual care at 12 months^130,148,152^ or 18 months.^130,148^ One trial found a statistically significant difference at 12 months (reported p=0.048) with a greater number ED visits in the intervention arm than the control arm.^126^

One trial of extended contact between mothers and neonates with or without home visits, when compared with usual care, reported on total number of ED visits per arm (rather than means; no standard deviations were reported). The study authors noted a lack of statistical significance.^122^

Results for followup from 2 to <4 years. Of these 13 trials, 6 reported ED visit outcomes at 2 to <4 years of followup.^116,118,119,121,129,131,137,140,141,143–147^ Variations in the type of outcome reported again precluded pooling. Outcomes included (1) mean number of all-cause ED visits; (2) mean number of ED visits for accidents, injuries, and ingestions; (3) number of children seen in the ED; (4) number of children seen for accidents or injuries; and (5) number of children seen for injuries or ingestions. Overall, the results are inconsistent in demonstrating benefit.

Two trials reported the mean number of all-cause ED visits over the 2-year study period.^116,121^ One trial reported a statistically significant difference with a reduced number of ED visits for the nurse-visited arm compared with the control arm (p=0.01);^121^ the second reported no statistically significant differences.^116^

Two trials reported the mean number of ED visits specifically for accidents, injuries, or ingestions.^119,121,141,143–146^ One reported no difference;^119^ the other reported a statistically significant reduction in mean number of ED visits for the nurse-visited arm compared with the control arm (p=0.03).^121^

Two trials^116,129,137^ reported the number of children seen in the ED for any reason but found no statistically significant differences between study arms (AOR, 1.23 [95% CI, 0.74 to 2.05];^116,137^ AOR, 1.21 [95% CI, 0.96 to 1.52^129^]).

Two trials reported the number of children seen specifically for accidents or injuries.^118,129,140,147^ One study found a statistically significant difference (OR, 0.59 [95% CI, 0.36 to 0.98]) with fewer visits in the intervention arm compared to the control arm,^118,140^ and the other found no statistically significant differences (AOR, 0.94 [95% CI, 0.65 to 1.34]).^129,147^

One trial found no statistically significant difference in the proportion of children seen specifically for injuries and ingestions (AOR, 1.16 [95% CI, 0.92 to 1.46]).^131^ This study also combined ED visits and hospitalizations and did not find any statistically significant differences (AOR, 1.32 [97.5% CI, 0.99 to 1.76]).

Long-term followup (≥4 years). Three trials reported long-term outcomes at 4 years,^143^ 5 to 5.5 years,^147^ and 6 years^149,150^ and yielded mixed results. One trial, which evaluated outcomes at 4 years for three groups,^143^ reported a 35 percent reduction in ED visits of all types for children in the nurse-visited group (p=0.0008) compared with rates for the control group but no difference in the number of ED visits for injuries or ingestions (p>0.05); the trial did not report raw numbers, RRs, or CIs. One trial, which reported the proportion of children who had used the ED in the past year at the 5- to 5.5-year followup,^147^ found no statistically significant difference between groups (10% vs. 9.2%; AOR, 0.96 [95% CI, 0.73 to 1.27]). One trial, which evaluated visits to the ED for injuries and/or ingestions through 6 years of age^149,150^ also did not find a statistically significant difference between groups (54.7% vs. 58.3%; AOR, 1.17 [95% CI, 0.95 to 1.45]).

Intervention effectiveness for populations of interest. Two studies^121,129,143^ reported on subgroup analyses focusing on populations of interest.

One study reported outcomes from subgroup analyses by low, middle, or high income; first-time vs. second-time mothers; and maternal age.^129^ The percentage of children with ED visits in the last year decreased with increasing levels of income and maternal age, but comparisons were not significantly different between the intervention and control groups or across any subgroups for ED visits at age 30 to 33 months.^129^

One study reported total ED visits and ED visits for accidents and poisonings by risk subgroups at 1, 2, and 4 years.^121,143^ The high-risk subgroup was comprised of single-parent mothers under the age of 19 of low socioeconomic status. Members of the nurse home visit group had fewer total ED visits at 1 year for the whole sample (p=0.04) and the high-risk subgroup (p=0.04).^121^ This difference was explained by a reduction in visits for upper respiratory tract infections in the nurse home visit group. The study found no statistically significant difference by study arm in ED visits for accidents and poisonings in the first year of life the high-risk subgroup; the results were consistent with the findings for the entire sample.^121^ There was also no statistically significant difference for total ED visits or ED visits for accidents and poisoning at 2 years of age for the high-risk subgroup (p>0.05).^121^ Members of the nurse home visit group had fewer total ED visits at 4 years (25 to 50 months of life) in the whole sample (p=0.0008) and in the high-risk subgroup (p<0.05).^143^ There was no statistically significant difference for the high-risk subgroup for ED visits for injuries or ingestions during this same time frame.^143^

##### Hospitalization

Thirteen trials reported on hospitalization outcomes (Appendix D Tables 19–22).^112,114,116,118,119,122,126,128,131,132,137,140,143,147–150^ Because of substantial heterogeneity in outcome definitions and time periods of interest, results could not be pooled.

Outcomes varied in their degree of specificity to child abuse and neglect. They included (1) the number of children with hospital admission as a result of an injury that were referred for independent investigation by the Family and Children’s Services staff and whose injuries were concluded to be nonaccidental, (2) the number of children hospitalized because of child abuse and neglect, (3) the proportion of children hospitalized because of injury or ingestion, (4) the number of children hospitalized for ambulatory-care sensitive conditions, (5) the number of children rehospitalized, (6) the number of children with all-cause hospitalization, (7) the mean number of all-cause hospitalizations, (8) the mean number of hospitalizations for injury or ingestion, (9) the total counts of hospital visits, (10) the mean number of hospital days, and (11) the types of injuries reported among those hospitalized. In general, the evidence did not demonstrate benefit for the active intervention arm(s).

The most specific outcomes showed no significant differences with one trial each finding no difference in (1) the number of children hospitalized with nonaccidental injuries and referred for investigation,^118^ and (2) the number of children hospitalized because of child abuse and neglect. Less specific outcomes also did not consistently demonstrate benefit in the intervention arm. Three studies reported on (3) the proportion of children hospitalized because of injury or ingestion. Of these studies, two reported no difference;^118,149,150^ neither specified whether injuries were intentional or accidental. One trial found that the home visitation group had lower overall rates of hospital admission for unintentional injury than the control group at the 9-year followup (28.3% vs. 42.1%; p<0.05).^118,140^

One trial each found no difference (4) the number of children hospitalized for ambulatory-care sensitive conditions,^116^ and (5) the number of children rehospitalized at 14 days and 18 months (the original cause was not specified).^114^

Four^112,130,136,137,147^ of five trials^112,126,130,136,137,147^ reporting on (6) the proportion of children hospitalized for any reason found no differences. The specific definition, timing, and details related to these outcomes precluded synthesis. One trial reported four outcomes for the number of children hospitalized (6 months’ followup, 12 months’ followup, less than 24 hours’ stay, more than 24 hours’ stay);^126^ the investigators reported no statistically significant differences for three of these outcomes. The exception was the number of children hospitalized for more than 24 hours at 6 months (lower numbers in the intervention arm when compared with the control arm, p=0.017).^126^

Two of three trials found no statistically significant differences in (7) the mean number of all-cause hospitalization (the results were not pooled because measures of dispersion were not reported).^119,130,143^ One trial showed no difference in the mean number of hospitalized between groups from baseline to 2 months or for the whole followup period (baseline to 12 months) for most measures of hospitalization (hospitalization in the special care baby unit, high-dependency unit, neonatal intensive care unit; the children’s ward; and other hospitalizations).^132^ The only exception was a mean difference of 0.14 fewer children’s ward hospitalizations for the whole followup period in the intervention arm (mean of 0.03 for children’s ward hospitalization) compared with the control arm (mean of 0.17 for children’s ward hospitalizations) (calculated 95% CI, −0.23 to −0.05).^132^ One trial found no statistically significant difference in (8) the number of hospitalizations for injuries or ingestions.^119^

One trial reported no differences in (9) the total counts of hospital visits (measures of dispersion not reported).^122^

Four trials reported on (10) the mean number of hospital days. Of these, two trials found that children receiving home visits spent fewer days hospitalized.^119,143^ In one trial the nurse-visited children in a home health program had fewer mean hospital days than the children in the usual care arm (log incidence difference, −0.66 [95% CI, −1.21 to −0.13]; p<0.05).^143^ In another trial the home-visited children had fewer total days hospitalized for injuries or ingestions (log incidence difference, 1.64 [95% CI, 0.78 to 2.50]; p<0.01).^119^ The other two home visitation trials did not find between-group differences in hospital days.^112,130^

One trial reported differences in (11) the nature of injuries between home visitation program groups.^119^ The three nurse-visited children from this trial who were hospitalized had burns to the face, coin ingestion, and ingestion of iron medication; the 13 children in the control group were hospitalized for fractures (fibula, tibia, skull [two children]), head trauma without skull fracture [three children]), strangulated hernia with delay in care, coin ingestion, suspected child abuse and neglect, burns (face and neck, both legs), and finger injury with osteomyelitis.^119^

Intervention effectiveness for populations of interest. Two studies^121,129,143,147^ reported on subgroup analyses focusing on populations of interest.

One study reported outcomes from subgroup analyses by low, middle, or high income; first-time vs. second-time mothers; and maternal age.^129,147^ The comparisons showed no significant differences between the intervention and control groups across subgroups, for injuries or hospitalizations at 30 to 33 months; these results were consistent with the findings for the overall sample. One study reported total number of hospital admissions by risk subgroup from 25 to 50 months of age.^121,143^ The high-risk subgroup was comprised of single-parent mothers under the age of 19 of low socioeconomic status. There was no statistically significant difference (p>0.05) seen in hospital admission in the high-risk subgroup or in the whole sample.^121,143^

##### Failure to Thrive

One trial reported on the outcome of failure to thrive (Appendix D Table 23). There were no statistically significant differences between study arms for the outcome of failure to thrive (0% [0/39] for the intervention group vs. 2.5% [1/40] for the control group; calculated RR, 0.34 [95% CI, 0.01 to 8.14]).^114^

Intervention effectiveness for populations of interest. The included study did not report on intervention effectiveness on failure to thrive for populations of interest.

##### Failure to Immunize

One trial reported on failure to immunize (Appendix D Table 24). It found no statistically significant differences between study arms in the rate of no vaccinations at 6 months (calculated RR, 0.41 [95% CI, 0.13 to 1.26]).^128^

Intervention effectiveness for populations of interest. No studies reported on intervention effectiveness for failure to immunize for populations of interest.

#### Behavioral, Developmental, Emotional, Mental, or Physical Health and Well-Being

##### Internalizing and Externalizing Behavior

Six trials reported on internalizing (depression, anxiety) and externalizing (disruptive, aggressive, or delinquent) behavioral outcomes in children (Appendix D Tables 25–27).^111,116–119,129,137–141,147^ As with other outcomes, the evidence included substantial heterogeneity in the timing and type of outcome measurement. Overall, the findings are inconsistent. Three of six trials found a reduction in behavior difficulties in children in primary care or primary care–referable interventions to prevent child maltreatment.^111,116,118,137,140^

Results for followup <2 years. One trial^111^ reported behavior outcomes at 6 months and 12 months^111^ on the internalizing and externalizing scales of the Infant-Toddler Social Emotional Adjustment Scale (ITSEA). The study presented results that adjusted for baseline values and repeated measures and found a significant effect of the intervention on the proportion of children with ITSEA externalizing behaviors (p<0.05) and mean ITSEA externalizing behaviors at 12 months (mean score, 13.8 vs.18.4; effect size, 0.094) but not at 6 months (T scores ≥65 indicate clinical problems). The study found no statistically significant differences between arms for proportion of children with ITSEA internalizing behaviors or mean ITSEA internalizing behavior scores at 6 months or at 12 months.

Results for followup for 2 to <4 years. Four trials reported outcomes between 2 and 4 years of followup;^116,118,119,129,137,140,141,147^ two found no differences and two found statistically significant differences. One trial^119,141^ of nurse home visits examining child behavior outcomes at 2 years of age using the Child Behavior Checklist (CBCL) found no difference between arms. One trial reported outcomes at 30 to 33 months^129,147^ and found no statistically significant differences between intervention and control arms for the proportion or mean scores of children with aggressive behavior problems or anxious or depressed problems based on CBCL.

One trial^116,137^ found that children in the intervention group were more likely to have a higher percentage of participants with CBCL internalizing score in the “normal range” (T score <60) at age 2 years (87% vs. 79%; AOR, 2.06 [95% CI, 1.31 to 3.25]), and they had significantly lower mean scores of internalizing behavior problems on the CBCL than usual care (48.2 vs. 51.0; mean difference, −2.8 [95% CI, −4.2 to −1.5]). More participants in the intervention group were found to have CBCL externalizing scores in the normal range (82% vs. 77%; AOR, 1.48 [95% CI, 1.14 to 1.94]), but no statistically significant differences were found for externalizing behavior problems on the mean CBCL score.

One trial examined outcomes at 36 months.^118,140^ At 36 months of age, the study reported lower mean scores for internalizing problems on the ITSEA (scores were normalized to a mean of 10) (mean score, 9.86 vs. 10.12; correlation ratio, 0.13; 95% CI, 0.03 to 0.23; Cohen’s d, 0.26 [95% CI, 0.06 to 0.47]; p<0.01) and lower overall mean scores of behavior problems on the ITSEA (mean score, 9.87 vs. 10.11; correlation ratio, 0.12; 95% CI, 0.02 to 0.22; Cohen’s d, 0.24 [95% CI, 0.04 to 0.44]) but no differences in mean scores for externalizing behaviors as assessed by ITSEA.

Long-term followup (≥4 years). Four trials evaluated long-term outcomes.^118,119,129,138–141,147^ One trial reported lower overall behavioral scale scores in the intervention when compared with the control arm, and three reported no statistically significant effects.

One trial reported outcomes again at ages 5, 6, and 9 years using the 30-item Strengths and Difficulties Questionnaire.^118,140^ The intervention group demonstrated fewer overall behavior problems (mean score across 5, 6, and 9 years, 9.91 vs. 10.08; Cohen’s d, 0.17 [95% CI, 0.06 to 0.29]; p<0.05).

One trial reported on child internalizing and externalizing behavior problem outcomes at age 9 years, 7 years after the intervention ended, using the Computerized Diagnostic Interview Schedule for Children and found no statistically significant differences between arms for mother or teacher reports of conduct failures (incidence ratio, 0.56 [95% CI, −1.26 to 0.11]); depressive and anxiety disorders (0.64 [95% CI, −0.99 to 0.11]); and disruptive behavior disorders with impairment (1.15 [95% CI, −0.19 to 0.47]).^119,141^

In one trial at 5.5 years,^129,147^ mothers in the intervention group reported no statistically significant differences in borderline or clinical behavioral concerns on the CBCL (20.2 vs. 16.5%; AOR, 1.26 [95% CI, 0.94 to 1.69]) when compared with the control group.

One trial examined outcomes of a paraprofessional home visitation program at age 7 years on five subscales of the CBCL measuring rule-breaking, aggressive behaviors, social problems, and anxious depressed and withdrawn depressed behaviors but found no significant differences between arms.^138,139^

Intervention effectiveness for populations of interest. One study reported on subgroup analyses focusing on populations of interest.^138^ The study focused on a “High Prevention Opportunity” subgroup comprising young, first-time mothers who initiated home-visiting services prenatally.^138^ The results in the populations of interest were consistent with the results for the overall sample at age 7 years and did not demonstrate a statistically significant benefit for the intervention arm for rule-breaking, aggressive behaviors; social problems; and anxious depressed and withdrawn depressed behaviors.^138^

##### Social, Emotional, and Other Developmental Outcomes Not Otherwise Categorized

Five trials evaluated discrete social, emotional, or other developmental outcomes separately from overall measures of externalizing or internalizing problems (Appendix D Tables 28–30).^111,112,129,136,138,141,147^ The heterogeneity of outcomes precluded meta-analysis, but no trials reported statistically significant differences between treatment and control groups.

One trial evaluated dysregulation midway through the intervention period and at intervention completion and found no significant differences between study arms at 6- or 12-months post-baseline.^111^

Another trial^129,147^ reported sleep problems as an outcome, assessed toward the end of the intervention period when the children were 30 to 33 months of age.^129^ The mean scores were not significantly different between the intervention group and control group (mean difference on CBCL, 0.12 [95% CI, −0.13 to 0.36]), although the proportion of parents of intervention children reporting sleep problems was higher than the proportion of parents of control children (AOR, 1.37 [95% CI, 1.01 to 1.86]). Longer-term outcomes from this same trial examined children’s social skills when the children were 5 to 5.5 years of age, again finding no difference between the intervention and control groups (p=0.40).^147^

In a third trial,^138^ researchers assessed attention and social problems using subscales of the CBCL when children were 7 years of age, 5 years after the intervention had been completed.^138^ The trial demonstrated no significant differences between the intervention and control groups for either attention or social problems.

A fourth trial found no significant differences between study arms in a few school-related outcomes (conduct, antisocial behavior, and peer affiliation) at a followup 7 years after the intervention had been completed, when children were 9 years of age.^141^

One trial assessed but did not report infant or toddler social and emotional adjustment outcomes.^112^ A subsequent cost evaluation alluded to self-reported results not being significant but did not report specific outcome data.^136^

Intervention effectiveness for populations of interest. Two studies reported on subgroup analyses focusing on populations of interest.^138,141^ One study reported on findings in a subgroup of women defined as having low psychological resources (defined by limited intellectual functioning, poor mental health, and low sense of control over their life circumstances).^141^ A second study focused on a “High Prevention Opportunity” subgroup comprising young, first-time mothers who initiated home-visiting services prenatally.^138^ Both studies reported that the results in the populations of interest were consistent with the results for the overall sample and did not demonstrate a statistically significant benefit for the intervention arm for attention or social problems^138^ or school-related outcomes (conduct, antisocial behavior, academically focused behavior, and peer affiliation).^141^

##### Child Development as Measured by the Bayley Development Scales

Four trials^112,116,119,121,136,137,141,143–146^ reported on child development as measured by the Bayley Scales of Child Development (Appendix D Tables 31–33). The results generally indicated no differences between intervention and control groups, with the exception of some results from one trial.^137^

Two trials reported Bayley Scale outcomes at 1 year of age; both reported no statistically significant differences.^112,121,136^

Two trials reported on Bayley Scale outcomes when children were 2 years of age.^119,137^ One trial reported no difference in the Bayley mental index at 2 years of age.^119^ The other evaluated the Bayley mental and psychomotor indices at 2 years of age and reported scores as a continuous measure of development and as a categorical measure using the recommended cutoff (<85) for mild delay. The mean difference between the two groups for the mental development index was significantly different with those in the experimental group, having a 3.2-point higher mean score (mean score, 88.0 vs. 84.8 [95% CI, 1.2 to 5.2]).^137^ The experimental group had higher adjusted odds of being in the normal range on the mental index than the control group. For the mental index, 58 percent of the experimental group and 48 percent of the control group were in the normal range, with an AOR of 1.55 (95% CI, 1.01 to 2.37). The unadjusted odds were not statistically significant (calculated OR, 1.50 [95% CI, 0.91 to 2.47]).

The mean difference between the two groups was not significant for the psychomotor index. The percentage of children in the normal range on the psychomotor index was also similar between the two groups, with 85 percent of the experimental group and 80 percent of the control group in the normal range. The differences were not statistically significant (AOR, 1.36 [95% CI, 0.72 to 2.58]).^137^

Intervention effectiveness for populations of interest. One study^121^ reported on subgroup analyses focused on maternal and sociodemographic characteristics. The study reported that babies of highest risk mothers, defined as poor, unmarried teenagers who were assigned to the nurse-visited condition, did not have statistically significant differences on the Bayley mental development index at 12 months than babies whose mothers were assigned to a developmental screening and free transportation comparator group (115.01 vs. 104.13; p=0.06).

##### Other Development Outcomes

Five trials reported on other development outcomes, which varied substantially in constructs (mother-infant communication, attachment, clinically concerning language development, intelligence quotient [IQ], maternal concerns regarding cognition) and specific measures by study (Appendix D Tables 34–37).^111,121,125,131,143,147^ Although the results cannot be compared across studies, three of five studies suggested at least some benefit on different measures of outcomes.^111,125,131^

Four of five studies reported at least some nonsignificant results.^121,125,131,147^ Specifically, one trial reported no measures of variance but noted that the overall results for a group of infant development tests at 2 years was not statistically significantly different;^121^ tests of IQ using the Stanford-Binet test at 3 and 4 years were also not statistically significantly different.^143^ Another trial found no statistically significant differences in the proportion of parents with a significant concern regarding the child’s development on the Parents’ Evaluation of Development Status (calculated RR, 0.94 [95% CI, 0.76 to 1.16]).^147^ A third trial found no statistically significant differences between study arms in maternal concerns regarding cognitive development at 12 months.^131^ Subsequent measures showed fewer concerns in the intervention arm by 24 months. The same study demonstrated better early language scores (the Early Language Milestone Scale score) at 24 months and fewer language concerns at 12 and 18 months in the intervention arm. A fourth study found that infants in the intervention arm were statistically significantly less likely to have disordered attachment than infants in the control arm at 12 months (measured with the Strange Situation Procedure-Secure Attachment Classification).^125^ Mother-child communication at 4 months (measured with the Atypical Maternal Behavior Instrument for Assessment and Classification) was not statistically significantly different.^125^ Finally, a fifth study reported that children in the intervention arm were less likely to have clinically concerning problems with language (measured by the Infant-Toddler Developmental Assessment) at 6 and 12 months than children in the control arm.^111^

Intervention effectiveness for populations of interest. Two studies reported on subgroup analyses focusing on populations of interest.^121,125,143^ One study that demonstrated a lower likelihood of disordered attachment among intervention infants when compared with infants in the control arm at 12 months (measured with the Strange Situation Procedure-Secure Attachment Classification) did not report a statistically significant difference among teen mothers.^125^ As with the overall results, mother-child communication at 4 months (measured with the Atypical Maternal Behavior Instrument for Assessment and Classification) was not statistically significantly different between intervention and control arms.^125^ A second study reported no statistically significant differences between intervention and control arms for cognitive measures (on the Cattell scale score^121^ and the Stanford-Binet test^143^) for low-income, unmarried teens. These results were consistent with the results for the overall sample.

##### School Performance

Three trials assessed varied school performance outcomes and reported few between-group differences for the overall sample (Appendix D Tables 38–41). One trial reported no statistically significant differences in the percentage of children repeating a grade in the home-visiting intervention arm compared with the control arm at the child’s age of 7.^138^ At age 6 years, groups did not differ in teacher-reported academic engagement (mean 6.16 vs. 6.86; effect size, −0.03; p=0.72), arithmetic achievement (mean 89.7 vs. 88.6; effect size, 0.25; p=0.30), or reading achievement (mean 93.8 vs. 93.6; effect size, 0.02; p=0.84) on child-completed assessments, but children in the intervention group had higher mental processing scores compared with children in the control arm (mean 92.3 vs. 90.2; effect size, 0.18; p=0.03).^142^

At 9 years of age, this same study found no statistically significant differences on grade point averages (GPAs) averaged across reading and math. The study also found no statistically significant differences on math and reading achievement test scores in grades 1 through 3 or in academically focused behavior in grade 3.^141^ Groups also did not differ in academic failures, retention in/repeating a grade, or special education placements in grades 1 through 3.^141^

A third trial, based in the United Kingdom, reported no differences in the number of children in the intervention vs. control group reaching at least the expected standards for reading (65% vs. 61%; AOR, 1.23 [95% CI, 0.99 to 1.53]; p=0.051), arithmetic (62% vs. 61%, AOR, 1.04 [95% CI, 0.84 to 1.28]; p=0.73), science (73% vs. 70%, AOR, 1.14 [95% CI, 0.91 to 1.43]; p=0.25), and writing (2016/17 academic year, 48% vs. 43%; AOR, 1.24 [95% CI, 0.97 to 1.60]; p=0.09).^131^

Intervention effectiveness for populations of interest. One study reported that fewer children in the intervention arm repeated a grade compared with the control arm in a high-prevention opportunity sample (first-time mothers ≤age 19 years who could initiated home-visiting services prenatally [gestational age ≤30 weeks]) at age 7 years (12.4% vs. 23.9%; AOR, 0.45; p≤0.10), but the difference between the arms was not statistically significant.^138^ These findings align with results for the whole sample, in which the number of children repeating a grade did not differ between intervention and control arms.

Another trial^119,141,142^ with followup at ages 6 and 9 years also reported school performance outcomes for mothers with “low psychological resources,” defined as “limited intellectual functioning, poor mental health, and low sense of control over their life circumstances.”^141,^ ^p. 3^ At the age 6 years followup, children of low psychological resource mothers who received nurse visiting had significantly higher scores on the mental processing composite scale (mean 90.5 vs. 87.6; effect size, 0.25; p=0.03) and arithmetic achievement scale (mean 88.6 vs. 85.4; effect size, 0.25; p=0.04) compared with control children in this sample.^142^ As in the whole sample, differences between groups in other school performance measures (academic engagement, reading achievement) were not significant.

In the 9-year followup, children of low psychological resource mothers who received nurse visiting had higher reading and math GPAs (mean 2.7 vs. 2.4, p=0.02) and higher reading and math achievement scores (mean 44.9 vs. 35.7, p=0.002) compared with control children at 9 years; effect sizes from analyses adjusting for covariates were small (0.22, 0.33, respectively). These findings were different from outcomes in the whole sample, in which GPAs did not differ between intervention and control groups. This study also reported academically focused behavior at 9 years. As in the whole sample, differences in academically focused behavior in grade 3 were not significant between groups in the low psychological resources sample.^141^

In the trial conducted in the United Kingdom,^131,149,150^ most education outcomes did not differ by subgroup (child sex; maternal age; maternal employment, education, or training or no employment, education, or training; deprivation quintile). The findings are similar to findings for the whole sample. However, this U.K. study did report some differences by sex, maternal age, maternal employment or education status, and deprivation quintile in the number of children reaching some educational standards: differences were seen in the number of males achieving the minimum writing standards in the intervention vs. control arms (43% vs. 32%; AOR, 1.62 [95% CI, 1.13 to 2.33]; p=0.009). The number of females achieving writing standards did not differ.

The U.K. study also reported differences in some educational outcomes for children of mothers who were less than age 16 years at baseline: 66 percent of children of young mothers in the home-visiting group vs. 42 percent of control (AOR, 3.23 [95% CI, 1.36 to 7.67]; p=0.008) reached expected standards for math. Intervention vs. control differences for children of mothers greater than age 16 were not significant; however, the interaction between maternal age subgroups did reach significance (p=0.01). More children of younger mothers also reached expected standards for writing in the intervention group vs. control (55% vs. 23%; AOR, 5.28 [95% CI, 1.49 to 18.73]; p=0.010) with no intervention vs. control differences in children of mothers older than age 16 and a significant interaction between maternal age groups (p=0.02). More children of mothers greater than age 16 years in the intervention group reached reading standards compared with control children of mothers greater than age 16 years (66% vs. 62%; AOR, 1.25 [95% CI, 0.99 to 1.57]; p=0.07); reading outcomes did not differ for children of mothers younger than age 16.^149,150^

In the U.K. study, 49 percent of children of mothers who were not in education, employment, or training met writing standards compared with 38 percent of control group children whose mothers who were not in education, employment, or training (AOR, 1.56 [95% CI, 1.05 to 2.30]; p=0.03). Writing outcomes did not differ for children of mothers who were in education, employment, or training; the study reported a significant interaction between these education or employment subgroups (p=0.028).^149,150^

In the least deprived quintile (measured on the Index of Multiple Deprivation), significantly more children in the intervention arm reached reading, science, and writing standards compared with the control arm (68% vs. 61%; AOR, 1.75 [95% CI, 1.00 to 3.07]; p=0.05; 77% vs. 68%; AOR, 1.94 [95% CI, 1.13 to 3.30]; p=0.015; 54% vs. 43%; aOR, 1.83 [95% CI, 0.95 to 3.51]; p=0.07, respectively). Outcomes did not differ in other deprivation quintiles.^149,150^

##### School Attendance

Two trials evaluated school attendance outcomes and reported few differences in outcomes between intervention and comparison groups (Appendix D Tables 42 and 43). One trial^138^ reported on school attendance and found that children at age 7 in the intervention group self-reported skipping school significantly less often than children in the usual-care group (2.35% [9/388] vs. 6.47% [26/405]; RR, 0.36 [95% CI, 0.17 to 0.76]). The same study reported no statistically significant differences using maternal reports of skipping school more than once.

In another, U.K.-based study, the number of children with no school absences at ages 6 to 7 did not differ between the intervention and control group (1.9% in each group), nor did the percentage with at least one absence (98% in each arm; AOR, 1.00 [95% CI, 0.47 to 2.12]; p=0.99) or the percentage with authorized (97% per group; AOR, 1.01 [95% CI, 0.58 to 1.75]; p=0.98) or unauthorized absences (66% per group; AOR, 0.95 [95% CI, 0.76 to 1.18]; p=0.62).^131,149,150^

Intervention effectiveness for populations of interest. In contrast to findings in the whole sample, in which intervention group children reported skipping school less often than control children, differences in skipping school were not significant in a high-prevention opportunity sample in the first trial: 1.85 percent (1/62) of intervention group children and 4.53 percent (3/60) of control group children reported skipping school “often” (p=not significant). Differences in maternal reports of skipping school more than once were not significant in the high-prevention opportunity subgroup, which aligns with findings for the whole sample.^138^

##### Unintended Pregnancy, Sexually Transmitted Infections, or Termination of Pregnancy

No studies reported on intervention effectiveness for unintended pregnancy, sexually transmitted infections, or termination of pregnancy.

Intervention effectiveness for populations of interest. No studies reported on intervention effectiveness for unintended pregnancy, sexually transmitted infections, or termination of pregnancy for populations of interest.

#### Other Outcomes

##### Death

Of the six eligible studies, none reported statistically significant differences in the rates of child death between intervention and usual-care groups (Appendix D Table 44). Five trials reported a lower but nonsignificant difference in rate of child death among children in their intervention groups.^112,119,128,131,132,141,149,150^ One trial reported a higher but nonsignificant rate of death among children in the intervention group.^114^ In the longest study (9 years of followup),^119,141^ one death occurred in the intervention group (222 participants) and 10 deaths in the control group (498 participants). The OR was 0.22 but with wide CIs (95% CI, 0.03 to 1.74).^119,141^ These were rare events even among these mostly high-risk children recruited for risk factors also associated with increased risk of infant mortality. Also, these studies often include small samples. For example, the 3 percent reported neonatal death rate was in a control arm of a trial in which 2 infants died in a sample of 72 (2/71, 2.8%).^128^

Intervention effectiveness for populations of interest. No studies reported on intervention effectiveness for deaths for populations of interest.

##### Composite Outcome (Infant Death, Severe Nonaccidental Injury, and Involuntary Foster Care Placement)

One trial reported on a composite outcome comprising infant death, severe nonaccidental injury, and involuntary foster care placement (Appendix D Table 45).^128^ The investigators found a lower but not statistically significant risk for this measure outcome in the intervention group (3% [2/65] vs. 12.7% [9/71] in the usual-care group; RR, 0.24 [95% CI, 0.05 to 1.08]). When adjusted for baseline covariates, the RR was 0.22 (95% CI, 0.02 to 0.98).^128^

Intervention effectiveness for populations of interest. No studies reported on intervention effectiveness for composite outcome of child abuse and neglect for populations of interest.

### Key Question 2 Harms of Interventions to Prevent Child Maltreatment

#### Adverse Events

Two trials comprising five publications reported on harms but did not report on any prespecified harm outcomes such as stigma, labeling, legal risks, risks of further harm to the child, or dissolution of families or worsening of inequities (Appendix D Table 46).^131,132,149–151^ In one study (with 99 participants randomized to the intervention arm and 67 to the control arm), adverse events included miscarriage/terminations (5 events in the intervention arm vs. 1 in the control arm), late miscarriage (1 vs. 0), suspected miscarriage/termination (1 vs. 0), and infant death (0 vs. 1).^132,151^ These events occurred before the participants could begin attending group family nurse partnership sessions and are so are unlikely to be related to the intervention. The calculated RR is 2.37 (95% CI, 0.51 to 11.06). The second study, with 810 women analyzed in the intervention and 808 in the usual care arm, reported that 357 (43%) participants (mothers or children) had a serious adverse event (defined as primarily clinical events associated with pregnancy and infancy period) in the intervention arm vs. 310 in the usual care arm (38%) (calculated RR, 1.15 [95% CI, 1.02 to 1.25]).^131^ However, none were judged to be related to the intervention. The study also reported numbers (rather than rates) of miscarriages/terminations (24 in the intervention arm vs. 27 in the control arm), stillbirth/neonatal/infant death (5 in the intervention arm vs. 7 in the control arm), death of the mother/infant pair (1 in the intervention arm vs. 0 in the control arm) and adoption of the child (7 in the intervention arm vs. 7 in the control arm).

Harms for Populations of Interest. No studies reported on harms of intervention for populations of interest.