# Chapter 2 Methods

## Key Questions and Analytic Framework

The investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope, KQs, and analytic framework (Figure 1) that guided the literature search and review. Two KQs guide this review:

1. For children without obvious signs and symptoms of abuse or neglect, do primary care–feasible or referable preventive interventions reduce exposure to abuse or neglect; improve behavioral, developmental, emotional, physical, or mental health and well-being; or reduce mortality? Does the effectiveness of interventions differ by populations of interest (e.g., defined by child or caregiver characteristics such as age, developmental stage of the child, sex, gender identity, race and ethnicity, sociodemographic characteristics [rural/urban location, place of residence, family income or wealth], or special healthcare needs)?
2. What are the harms from interventions intended to prevent child maltreatment? Do the harms of interventions differ by populations of interest (e.g., defined by child or caregiver characteristics such as age, developmental stage of the child, sex, gender identity, race and ethnicity, sociodemographic characteristics [rural/urban location, place of residence, family income or wealth], or special healthcare needs)?

Figure 1 Analytic Framework

Abbreviations: KQ=key question.

The framework begins on the left with the population of interest: children or adolescents from birth to less than age 18 without signs or symptoms of current or past abuse or neglect. To the right is an overarching arrow for the framework representing KQ1. It begins with “Primary care–feasible or referable interventions” of child maltreatment on the left and ends with a box on the far right that represents the final outcomes: “Reduced exposure to abuse or neglect; improved behavioral, developmental, emotional, mental, or physical health and well-being; and reduced mortality.” From this main arrow is a second arrow descending to an oval with the text “Harms” to illustrate the focus of KQ2.

In addition to the KQs, this review included three CQs to help inform the report:

1. What are current practices for a) identifying children at risk of maltreatment, b) referring children or families to prevention programs, c) reporting children or families to CPS, and d) diagnosing child maltreatment outcomes? Do current practices in identification, referral, reporting, and diagnosis of outcomes of child maltreatment differ by race or ethnicity of the child or caregiver? If evidence exists of practice differences, what factors might explain these differences?
2. What are the validity and reliability of risk assessment tools to identify children and adolescents who are at risk of child maltreatment? Does the reported validity and reliability (of risk assessment tools) differ by race and ethnicity? If yes, what might explain these differences? Is there evidence that these tools alter or increase inequity?
3. What are the effects of primary care–feasible or referable preventive interventions that report on child maltreatment outcomes on SDOH? Do primary care–feasible or referable preventive interventions that report on child maltreatment outcomes examine the association between SDOH and child maltreatment outcomes?

These CQs were not a part of our systematic review. They are intended to provide additional background information. Literature addressing the CQs is summarized in Appendix A.

### Data Sources and Searches

We searched MEDLINE® (via PubMed), the Cochrane Library, and Health and Psychosocial Instruments for English-language articles published from June 18, 2016, through January 3, 2022. We conducted a bridge search on February 2, 2023. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, screening tests, interventions, outcomes, and study designs. Appendix B1 describes the complete search strategies.

To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria and added all previously unidentified relevant articles. We reassessed all articles in the 2018 report.

We also conducted targeted searches for unpublished literature by searching ClinicalTrials.gov, Cochrane Clinical Trials Registry, and the WHO International Clinical Trials Registry Platform. We conducted ongoing surveillance of the literature from February 2023 onward through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on December 6, 2023, and identified no additional unique studies.

## Study Selection

We selected studies on the basis of inclusion and exclusion criteria developed for each KQ for identifying populations, interventions, comparators, outcomes, timing, settings, and study designs (PICOTS) (Appendix B2). Appendix C lists studies excluded at the full-stage review stage. We imported all citations identified through searches and other sources into EndNote X9™. In addition to searches for the updated literature, we incorporated all references from the previous report from 2018.^72^

Two investigators independently reviewed titles and abstracts. We dually and independently reviewed the full text of abstracts marked for potential inclusion by either reviewer. We resolved disagreements by discussion and consensus.

### Population

The focus of the review is on children and adolescents (younger than age 18 years) with no known exposure to maltreatment and no specific signs or symptoms of current or past maltreatment. We required included studies to have a majority of children (>50%) without known exposure to maltreatment and no signs or symptoms of current or past maltreatment. We excluded studies consisting entirely of symptomatic children and adolescents undergoing diagnostic evaluation for conditions related to abuse or neglect, children with known exposure to child maltreatment, children of caregivers who perpetrated maltreatment toward them, and perpetrators of maltreatment. For this update, we included populations of interest defined by child or caregiver characteristics such as age, developmental stage of the child, sex, gender identity, race and ethnicity, sociodemographic characteristics (rural/urban location, place of residence, family income or wealth), or special healthcare needs.

### Interventions

We included studies that evaluated services that were feasible in a primary care setting or to which primary care provider could refer children (Table 1). These services may have been implemented by a non-clinician; they may also have included one or more of a complex package of programs such as home-visiting programs, primary care–based programs, respite care, parent education programs, and family support and family-strengthening programs. We excluded communitywide programs, such as public awareness campaigns or public service announcements, without specific interventions linked to clinical settings.

### Comparators

Eligible comparators included usual care and delayed interventions. We also included active interventions that allowed for assessment of the independent contribution of the primary care–feasible or referable preventive intervention (e.g., clinical interventions plus media campaigns vs. media campaigns).

### Outcomes

We required that all studies report direct or proxy measures of abuse or neglect. Direct measures include those reflecting physical, sexual, or emotional abuse perpetrated by a parent or caregiver. We excluded self-report but included reports to CPS and removal of the child from the home as outcome measures. Because these measures of abuse or neglect were likely to be rarely observed, we also included proxies for maltreatment such as injuries, visits to the ED and hospitalizations, failure to thrive, and failure to immunize. These proxy measures have low specificity to abuse or neglect, but their inclusion in the report was intended to capture a broad array of outcomes that might reflect potential benefits from the intervention. For studies that reported direct or proxy measures of abuse or neglect (other than self-report), we then evaluated behavioral, developmental, emotional, mental, or physical health and well-being; mortality; and harms. Compared to the previous review, we added two new types of eligible outcomes (quality of life or functional status measures; unintended pregnancy, sexually transmitted infections, or termination of pregnancy of the child) and further specified examples of eligible outcomes (e.g., added community involvement in examples of social–emotional results). As with our inclusion of proxy measures of abuse or neglect, we intended to be broadly inclusive of health and well-being outcomes to collect evidence of benefit.

### Settings

We included studies that occurred in primary care or school-based clinics or other settings (such as the home). We required that studies were conducted in countries categorized as “very high” on the Human Development Index.^103^

### Study Designs

We limited KQ 1 to randomized, controlled trials (RCTs). For KQ 2, we also searched for eligible cohort trials with a control group and case-control studies.

## Data Abstraction and Quality Rating

For each newly included study, one investigator extracted pertinent information about the PICOTS and study designs (Appendix D). A second investigator checked all data extractions for completeness and accuracy. Among included studies from the 2018 report, one reviewer checked for relevant data based on newly included outcomes as well as the accuracy of previously generated abstraction tables and updated them as needed.

We assessed the quality of studies as good, fair, or poor using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B3) using the Cochrane ROB 2.0 for randomized studies of interventions^104^ (individual study ratings provided in Appendix E). Two investigators independently evaluated the risk of bias of each newly included study. We checked the quality ratings of all eligible studies from 2018 to ensure that studies met our current quality rating criteria. Only results from fair- and good-quality studies were included in the synthesis. We resolved disagreements by discussion and consensus. We rated studies as poor quality (i.e., high risk of bias) for the following reasons: outcome assessors not masked, concerns about missing outcome data, inadequate randomization, and no intention-to-treat analysis.

## Data Synthesis and Analysis

We evaluated the findings for each outcome, first using a qualitative approach that considered the clinical and methodological characteristics of the evidence base. We paid close attention to PICOTS criteria in evaluating heterogeneity and summarized study characteristics for the evidence base for each outcome in Appendix F. With relatively rare outcomes such as reports to CPS, removal from the home, and hospitalizations, a longer time period for observation of outcomes allows for a greater accumulation of events, but it also increases both the likelihood of unmeasured co-interventions that vary differentially between arms and the attenuation of intervention effects overall. Because of the potential heterogeneity of combining longer-term outcomes with studies reporting results at or close to the end of the intervention, we generally limited meta-analyses to the first report of outcomes from studies (generally within a year of study completion) and stratified results by timing of followup.

We then presented results either qualitatively or quantitatively. We generated pooled estimates when at least three similar studies were available, using the Comprehensive Meta Analysis program.^105^ For all meta-analyses, we used random effects models using the inverse-variance weighted method (DerSimonian and Laird) and calculated the chi squared statistic and the I^2^ statistic (the proportion of variation in study estimates due to heterogeneity) to assess statistical heterogeneity in effects between studies.^106,107^ An I^2^ from 0 to 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and 75 to 100 percent represents considerable heterogeneity.^108^ The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence for heterogeneity (e.g., p-value from the chi squared test or a confidence interval for I^2^). However, as precision and the number of participants increase, I^2^ may become inflated toward 100 percent and may not reflect clinically relevant heterogeneity.^109^

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from February 17, 2022, through March 16, 2022. In response to comments, we added greater specificity to the analytic framework and KQs 1 and 2 by adding “developmental health” as an outcome. We also added, to population characteristics of interest for KQs 1 and 2, developmental stage of the child; we specified that sociodemographic characteristics include rural/urban location, place of residence, and family income or wealth. We added “worsening of inequities” as a potential harm in KQ 2. Reviewers also suggested including SDOH as outcomes; we added CQ 3 to explore this issue.

The draft evidence review was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments received. Specifically, we expanded the section on prevalence to include information on American Indian/Alaska Native youth. We removed data on some maternal outcomes (unintended pregnancy, pregnancy termination, sexually transmitted infections) to focus attention on child outcomes as intended in our protocol. We revised the report for clarity and expanded the section on review limitations. The draft evidence review was also posted for public comment, and a newly identified study was added to the report as a result of public comments..

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis. AHRQ staff provided oversight for the project, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.