# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF or Task Force) will use this report to update its 2018 recommendation on primary care–based or referable interventions to prevent child maltreatment. In 2018, the USPSTF concluded that the evidence was insufficient to assess the balance of benefits and harms of primary care interventions to prevent child maltreatment.^1^ This report will summarize the evidence for the benefits and harms of interventions to prevent maltreatment among children and youth younger than 18 and identify key gaps in the scientific literature. Assessing the evidence on interventions for children with signs and symptoms of maltreatment or known exposure to child maltreatment is outside of the scope of this report. In 2004, this topic included evidence on screening, but poor accuracy of screening coupled with harms of screening (e.g., legal consequences, stigma) led to a change in scope to behavioral counseling.

## Condition Background

### Condition Definition

Child maltreatment, which includes child abuse and neglect, has profound consequences for health and well-being. The World Health Organization (WHO) defines child maltreatment as “the abuse and neglect that occurs to children younger than 18 years of age. It includes all types of physical and/or emotional ill-treatment, sexual abuse, neglect, negligence and commercial or other exploitation, which results in actual or potential harm to the child’s health, survival, development or dignity in the context of a relationship of responsibility, trust or power.”^2^ In 2008, the Centers for Disease Control and Prevention recommended a set of uniform definitions to support public health surveillance of maltreatment.^3^ These definitions differentiate between child abuse as “acts of commission” and child neglect as acts of “omission.” Child abuse is defined as “words or overt actions that cause harm, potential harm, or threat of harm to a child. Acts of commission are deliberate and intentional.”^3,^ ^p. 11^ Physical abuse, sexual abuse, and psychological abuse constitute child abuse. Child neglect is defined as “the failure to provide for a child’s basic physical, emotional, or educational needs or to protect a child from harm or potential harm.”^3,^ ^p. 11^ Physical, emotional, medical and dental, and educational neglect constitute failure to provide. Inadequate supervision and exposure to violent environments constitute failure to supervise. For both acts of commission and omission, harm to a child might not be the intended consequence.

The Federal Child Abuse Prevention and Treatment Act (CAPTA), passed in 1974, was the first attempt in the United States to advance nationwide efforts in identifying, preventing, and treating child maltreatment.^4^ In its most recent reauthorization bill (November 2021), the term “child abuse and neglect means, at a minimum, any recent act or failure to act on the part of a parent or caretaker, which results in death, serious physical or emotional harm, sexual abuse or exploitation (including sexual abuse)” or “an act or failure to act which presents an imminent risk of serious harm.” The bill states that sexual abuse includes, “(A) the employment, use, persuasion, inducement, enticement, or coercion of any child to engage in, or assist any other person to engage in, any sexually explicit conduct or simulation of such conduct for the purpose of producing a visual depiction of such conduct; and (B) the rape, and in cases of caretaker or inter-familial relationships, statutory rape, molestation, prostitution, or other form of sexual exploitation of children, or incest with children).”^5^

The CAPTA definition serves as a minimum standard nationally, but each State provides its own definition of child abuse and neglect.^6^ Minimum standards vary across States and within States across time as new legislation is adopted. The Child Welfare Information Gateway, a service of the Children’s Bureau of the U.S. Department of Health and Human Services’ Administration for Children and Families, summarizes State definitions of child abuse and neglect that determine when State child protective agencies intervene.^7^ These definitions, as of March 2019, are summarized in Appendix A. Although CAPTA offers a minimum threshold, variations in State laws and definitions result in a heterogeneous landscape of definitions, operationalization, and research. An Institute of Medicine report on child abuse and neglect noted that this heterogeneity has impeded full understanding of the scope of child maltreatment but also offers an opportunity to conduct and learn from natural experiments.^8^

### Etiology and Natural History

Maltreatment—that is, abuse and neglect in childhood—can result in serious negative physical, psychological, and behavioral consequences that can span a life course and influence subsequent generations.^8^ The immediate aftermath of abuse can include injuries, brain trauma, disabilities, and death, while neglect can result in failure to thrive, infections, malnourishment, lack of needed medical care, and death.^9^ In fact, in 2019, 73 percent of children who died from maltreatment suffered from neglect alone or in combination with another type of maltreatment.^10^

Although neglect may not be as apparent as abuse, it also has profoundly negative consequences on children.^9^ Child maltreatment can also lead to long-term chronic health problems such as diabetes, high blood pressure, obesity, brain or vision problems, lung disease, and functional limitations and increase the risk for heart attack, cancer, stroke,^11,12^ and premature death.^13^ Evidence suggests that child maltreatment can be associated with epigenetic changes in stress response with potential lifetime effects.^14,15^

Psychological consequences of maltreatment include diminished executive functioning,^16,17^ diminished school performance,^18^ weakened cognitive skills, poor mental and emotional health, attachment and social difficulties, and posttraumatic stress.^19–24^ Child maltreatment appears to alter the response to treatment for depression, resulting in differential^23^ or poor response^24^ to treatment. Behavioral consequences of maltreatment include unhealthy sexual practices leading to earlier initiation of sex, multiple sexual partners, transactional sex, unprotected sex, and the risk of sexually transmitted infections.^25–28^ Adverse childhood experiences, including abuse and neglect, are associated with unwanted pregnancies.^29,30^ Behavioral consequences can also include juvenile delinquencies and adult criminality,^31^ alcohol and other drug use,^32,33^ and future perpetration of maltreatment^11^ and intimate partner violence.^11,34,35^

#### Risk and Protective Factors

Child maltreatment is rarely caused by a single risk factor and more often is the result multiple risk factors.^36^ However, the presence of risk factors does not guarantee that maltreatment will occur, nor does their absence eliminate the chance that maltreatment will occur.^37,38^ As a result, risk assessment tools have poor to good accuracy (Appendix A CQ 2), with areas under the receiver operating characteristic curve ranging from 0. 31 to 0.89; sensitivities range from 14.8 to 97.0 percent, and specificities range from 16.6 to 98.5 percent. Instruments in settings that are not applicable to primary care (emergency departments [EDs] and hospitals) have consistently higher accuracy (areas under the receiver operating characteristics curve [AUCs] range from 0.78 to 0.89) than instruments in settings applicable to primary care (AUCs range from 0.31 to 0.85). Instruments can be classified as actuarial (instruments based solely on empirically established relationships of risk factors and child maltreatment) or clinical (instruments based on the judgment of a professional or a group of experts).^39^ Actuarial instruments may be better at predicting the onset of maltreatment than clinical instruments, but both have poor to good accuracy. Actuarial sensitivity ranges from 61.1 to 96.8 percent, and specificity ranges from 16.6 to 98.5 percent. Clinical sensitivity ranges from 14.8 percent to 97.0 percent, and specificity ranges from 21.0 to 98.25 percent. Differences in the accuracy of these instruments by race or ethnicity are unclear (Appendix A CQ 2).

Several studies have assessed characteristics that may increase a child’s risk for maltreatment. Risk factors can be broadly grouped into the categories of parental risk factors, child risk factors, and societal/community risk factors. Parental characteristics associated with increased risk of child maltreatment include substance use, mental health problems, presence of intimate partner violence in the home, lack of social supports, the parent/caregiver being maltreated as a child, financial stress, and the parent being emotionally absent.^38,40–42^ Child risk factors include the child experiencing prior maltreatment, developmental delays and other special healthcare needs,^43^ disabilities,^44^ and gender (female children are more likely to be victims of sexual abuse).^45^ The risk of maltreatment with respect to the child’s age varies depending on the type of maltreatment; younger children and infants are at higher risk of neglect,^46^ and older children and adolescents are at higher risk for physical and sexual abuse.^45^ Regarding community factors, high rates of poverty, high rates of community and neighborhood violence, high local unemployment rates, and weak social networks within communities are associated with higher rates of child maltreatment, particularly when measured by verified reports by child protective services (CPS).^37,38,47^

More recent research has assessed factors that may play a role in mitigating risk of the occurrence of child maltreatment and mitigating the negative outcomes of child maltreatment after it has occurred. These factors are believed to exert their effect by strengthening families; strengthening connections with peers and community members; and, as a result, increasing parent or child resilience.^48^

Several studies have looked at the characteristics of children that seem to promote positive outcomes after maltreatment, which include self-regulation skills, adaptive functioning, social competence, and self-esteem.^49,50^ Parent and family factors that reduce risk of maltreatment include family connection, which is associated with children thriving, even in the setting of other adverse circumstances. Strong family supports are also associated with reduced risk of maltreatment, including in the prevention of intergenerational transmission of harsh parenting.^49,51–57^ Social and environmental protective factors include easy access to healthcare and social services and neighborhood social cohesion.^58,59^ Societal factors also appear to have a role with mitigating risk of child maltreatment. Paid family leave has been found to be associated with reduced hospitalizations for abusive head trauma,^60^ and increases in the minimum wage have been associated with fewer CPS investigations.^43,61^

### Prevalence and Burden of Disease

Because measures of prevalence rely on known or self-reported cases of maltreatment, substantiated numbers likely are an underestimate of prevalence. In the United States, child maltreatment reports to CPS are one important measure of prevalence of maltreatment. In 2021, data from the National Child Abuse and Neglect Data System (NCANDS) indicated that nationally, CPS received 4.0 million referrals for suspected abuse or neglect, representing 7.2 million children (27.6 screened-in referrals per 1,000 children nationwide).^62^ Fewer than half of these children (3.0 million), or 42 percent, received an investigation or an alternative response, identifying approximately 600,000 victims of abuse or neglect. Of these children, 76.0 percent were victims of neglect, 16.0 percent were victims of physical abuse, and 10.1 percent were victims of sexual abuse.^62^ Rates for other forms of neglect were not reported in 2021. In 2020, 6.4 percent were victims of psychological maltreatment, 1.9 percent were victims of medical neglect, and 6.4 percent were victims of other forms of abuse or neglect (such as lack of supervision, threatened abuse or neglect, or parent drug/alcohol addiction).^63^ Young children are the most vulnerable. More than a quarter of victims (27.8%) are between birth and 2 years of age. Victimization rates decrease with age from a high of 25.3/1,000 for children under 1 year of age, sharply at first, to a rate of 10.7/1,000 for children between ages 1 and 2 and then to a relatively steady rate in older children and younger adolescents ranging from 7.7/1,000 for 7-year-old children to 5.0/1,000 for 16-year-old youth. Rates of victimization were slightly higher for girls (8.7/1,000) than for boys (7.5/1,000); the average rate is 8.1 per 1,000 children.^62^ Rates of victimization also vary by race/ethnicity; they were highest among American Indian or Alaska Native children (15.2/1,000), followed by Black children (13.1/1,000), children of multiple races (10.3/1,000), Pacific Islander children (8.5/1,000), Hispanic children (7.7/1,000), White children (7.1/1,000), and Asian children (1.4/1,000).^62^ Structural, institutional, and interpersonal racism can contribute to variations in risk factors and differential identification and reporting to CPS which then lead to differences in prevalence by race; a detailed discussion follows in the section below on racial patterns in prevalence.. An estimated 1,820 children died from abuse and neglect in 2021.^62^ Child abuse mortality rates are consistently among the highest rates in in highly developed nations.^64,65^ The total lifetime cost of substantiated fatal and nonfatal cases of child maltreatment incurred annually in the United States in 2015 was estimated to be $428 billion,^66^ up from a prior estimate of $124 billion in 2010.^67^

Reports, investigations, and substantiated victims are one important way to understand the prevalence of maltreatment. However, not all acts of maltreatment are reported to authorities. The National Incidence Study of Child Abuse and Neglect (NIS)^68^ is a congressionally mandated effort to provide estimates of the incidence of child abuse and neglect in the United States. The NIS obtains data on children who were investigated by CPS and on children who were recognized as maltreated by community professionals but not reported to CPS. The fourth and most recent wave of data collection was completed in 2005–2006. Approximately 1.25 million children (17/1,000) were harmed by maltreatment (harm standard), and nearly 3 million children were at risk of harm from maltreatment (40/1,000 by the endangerment standard).^68^ Estimates of childhood maltreatment obtained via self-report were even larger than rates reported by CPS and NIS. Approximately 11,000 participants ages 18 to 26 years in the National Longitudinal Study of Adolescent Health self-reported on maltreatment experienced before sixth grade. Forty-two percent reported supervision neglect, 28 percent reported physical assault, 12 percent reported physical neglect, and 5 percent reported contact sexual abuse.^69^

Some surveys and many primary studies of interventions commonly documented parent-reported measures of abuse or neglect. In surveys, these measures are heterogeneous and have the potential to underreport abuse and neglect.^70^ One study compared rates of maltreatment types across four different data sources: the National Survey of Children Exposed to Violence, or NatSCEV (caregiver and child reports on the Juvenile Victimization Questionnaire); Gallup (parent only, Parent–Child Conflict Tactics Scale); NIS (cases investigated by CPS and known to community professionals); and NCANDS (cases substantiated by child protection agencies) in the United States.^71^ The study reported higher rates in parent-only or caregiver-and-child reported measures when compared with known or substantiated cases for physical, emotional, or sexual abuse or neglect. These results were roughly consistent despite differences in the measure, respondent, and time period for NatSCEV and Gallup for physical (4.0% vs. 4.9%) and sexual abuse (2.2% vs. 1.9%). For emotional abuse and neglect, however, the studies reported inconsistent rates (5.6% in NatSCEV vs. 19.1% in Gallup for emotional abuse; 4.7% in NatSCEV vs. 27.0% in Gallup for neglect). Variations in measures and respondents could explain these differences. These results suggest that measurement issues are a likely ongoing concern for emotional abuse and neglect, which are large contributors to child maltreatment.

A contextual synthesis of parent-reported measures in the 2018 evidence synthesis for the USPSTF found wide heterogeneity of measures, inconsistent results within studies across different measures, use of selected subscales without clear reporting on an a priori selection of measures, and potential for chance findings.^72^

#### Racial Patterns in Prevalence

A systematic review of disparities in the child welfare system found evidence of overrepresentation of Black children in the source of referral, the reason for investigation, caregiver risk factors, and outcomes of being in the child welfare system in the United States.^73^ One study reported higher rates of both false-positives and false-negatives in referrals leading to substantiation, suggesting lower accuracy for Black children at the “front-end” of the child welfare system.^74^ The latest round of NIS data, drawing from a 2005–2006 survey, found higher rates of maltreatment (cases investigated by CPS and known to community professionals) among Black children when compared with White children, even after controlling for predictors of maltreatment. Further exploration of these results suggested correlation with socioeconomic status.^75^ Studies have also demonstrated overrepresentation of children from minoritized groups, more missed cases among White children, and differences in evaluation when assessing outcomes such as head injury and fractures.^76–78^

Although Black children are disproportionately represented in the child welfare system, the reasons for this disparity are complex and continue to be debated. Explanations for these differences center around racism in reporting arising from subjectivity, inconsistency, and implicit bias,^79–81^ including in diagnosis and reporting on the part of pediatricians;^82^ institutional racism arising from policies and processes that are biased against Black children;^83^ and structural factors putting Black families at greater disadvantage and higher exposure to risk factors for maltreatment,^84–86^ such as poverty and single parenthood. Exploring these risk factors further reveals additional overlays of structural factors, including geography. For example, the links between poverty, race, and reporting for maltreatment are complex; individual, familial, community, and structural issues may serve as confounders between poverty and reporting for maltreatment. These relationships are further complicated by segregation by race or ethnicity.^81^ Neighborhood effects may also play a role: Black families are more likely than White families to live in impoverished neighborhoods and tend to have greater exposure to social service agencies and law enforcement.^81,87^ Spatial effects can also be complex, with greater disparity in maltreatment in most and least densely populated counties.^84^ Studies examining geographic distributions have found associations between geography, race, and overrepresentation of Black children in the welfare system, suggesting a complex set of mechanisms that include risk factors, behavior, differences in definition and application of child maltreatment standards, and structural racism.^81,84^

The more limited evidence on reasons for the disproportionate rates of victimization among American Indian or Alaska Native children also point to the co-occurrence of factors such as poverty and public health insurance that could lead to a higher rate of reporting among American Indian/Native Alaskan children.^88^ One study continued to find a higher rate of American Indian/Native Alaskan children being assigned maltreatment diagnosis codes even after adjusting for other factors such as public health insurance, age of the mother, sex of the child, and admission year.^88^ Whether the differential could be attributed to the severity of the presenting problem or racial bias or not was unclear. Factors such as higher rates of adverse childhood experiences, including family substance abuse and family interpersonal violence that are risk factors for maltreatment, are higher among American Indian/Alaska Native persons.^89,90^ Historic racial trauma,^91^ forced removal of children from families to boarding schools, and cycles of generational trauma^92^ serve as a backdrop to higher rates of adverse childhood experience and risk factors for maltreatment.

Although rates of victimization among Hispanic children are higher than White children nationally (7.7/1,000 vs. 7.1/1,000 in 2021), state-level analyses suggest a more complex picture where Hispanic children may be either under- or overrepresented for child maltreatment when compared to White children. The term “Hispanic” covers a very heterogeneous population in terms of immigration status, income, culture, and assimilation. The spatial concentrations of these factors may result in overrepresentation of Hispanic children among those reported to CPS in some states and underrepresentation in others.^93^

The potential for disparities in the child welfare system exists at every stage but particularly prior to entry, at the front-end (that is, prior to intake into the child welfare systems), which suggests the need for more contextual information on differences in race and ethnicity in current practices for identifying children at risk of maltreatment (Appendix A Contextual Question [CQ] 1) and the validity and reliability of risk assessment tools (Appendix A CQ 2).

Appendix A CQ 1 presents contextual information on current practices and variations in these practice by race and ethnicity of the child in the identification/diagnosis and reporting of child maltreatment. In brief, when comparing the accuracy of reporting to child protective services (CPS) against substantiation of maltreatment from the 2006 NCANDS, the ratio of false-positives to false-negatives was higher in Black children (1.71) than in White children (1.54) suggesting a clear pattern of disparity by race.^74^ Variations in approach to the diagnosis of physical abuse may have led to higher rates of missed diagnoses of physical abuse for White children (37%) than children overall (31%).^77^ Differences in insurance and clinician bias may be contributing to discrepancies in diagnosis by race, but the use of guidelines appear to reduce variations in care. Regarding reporting, differences by State, individual characteristics such as informant type and Medicaid-eligibility or lack of insurance, household composition, and structural factors such as occupancy rate and proportion of Medicaid patients in hospitals could explain wide variations in overall reporting. Evidence to explain these disparities is not clear or consistent. Maternal risk factors (such as prenatal care, maternal education, and number of children), socioeconomic status, insurance status, clinician judgment, and community-level factors may play a role in explaining these racial and ethnic differences in reporting.

### Rationale for Intervention

The field of public health has been instrumental in the development of a framework for organizing three levels of intervention services for preventing child maltreatment and neglect.^94^ The focus of this review is on prevention programs relevant to primary care. Included interventions focus on children who are at risk for maltreatment or neglect without signs and symptoms of maltreatment, with a goal of preventing abuse or neglect from occurring. Interventions without links to the clinical setting are ineligible for the review.

Eligible interventions are primary care–feasible or referable; in other words, they may be (1) delivered in primary care settings, (2) feasible for delivery in primary care, or (3) referable from primary care settings. To be feasible in primary care, the USPSTF guidance notes that “the intervention could target patients seeking care in primary care settings, and the skills to deliver the intervention are or could be present in clinicians and/or related staff in the primary care setting.”^95,^ ^p. 15^ To be referable from primary care, “the intervention could generally be ordered/initiated by a primary care clinician.”^95,^ ^p. 15^

Primary care–feasible or referable prevention programs may be implemented in settings including the home, primary care, school, and community-based settings. Social determinants of health (SDOH), such as poverty, food or housing insecurity, and lack of insurance, are associated with child maltreatment.^96^ The rationale for screening for SDOH and referral of those at risk to programs to ameliorate basic needs aligns with national and State approaches focused on promoting protective factors to mitigate risks for child maltreatment and improve well-being.^97^ Interventions comprising multiple components to address these varied needs may be delivered in person (as is the case with many home visitation programs) and additionally include telehealth support. Table 1 and Appendix A list potential types of interventions to prevent child maltreatment. Key questions (KQs) address the effectiveness of interventions to prevent child maltreatment and harms of such interventions. Whether these interventions change the SDOH that are associated with child maltreatment is unclear and is the subject of CQ 3 (Appendix A).

Table 1 Types of Child Maltreatment Prevention Programs

Type of Program | Description of Program
Home visitation programs | Aim to improve parenting and parent–child relationships by building positive parent–child relationships and attachment, reducing harsh parenting, increasing nurturing parenting, and improving safety in the home.; Components may support parents in meeting basic needs (e.g., employment) and help them gain access to social support and community services.
Pediatric primary care programs | Train health professionals to identify risk factors placing infants or children at high risk for maltreatment or neglect and to make referrals to community resources.; Components include comprehensive parent education and support interventions.
Psychotherapy interventions | May target high-risk groups.; May focus on improving the parent’s mood and coping skills, using cognitive behavioral therapy strategies.; Components include strengthening the parent–child relationship and addressing attachment problems between caregiver and child.; May be offered in the home as a home-visiting service, included as a component of a home visitation program, or be clinic-based.
Respite care programs | Offer short-term, temporary relief to families caring for children with developmental disabilities or serious emotional disturbances that place them at risk for maltreatment or neglect.; Offer families a break while providing a safe environment for the child.; May be provided for several hours, overnight, or for a few weeks at a time and may be provided in the home, a foster home, or a facility in the community.
Parent education programs | Improve parents’ understanding of children’s developmental needs and normal developmental behaviors, improving their capacity to provide nurturing care and increasing the use of positive discipline strategies.; Are often didactic and delivered via parent groups.
Community-based programs | Aim to reduce barriers created by a lack of community support and other negative forces within a community by both reducing risks and enhancing protective factors.; Components include fostering partnerships with other local programs serving young children and working to create more supportive relationships among community residents.; May also include achieving policy-level changes that increase resources available at the level of clinical care.

## Recommendations and Clinical Practice

Existing guidelines either recommend against screening because of insufficient evidence,^98^ note the risk of false-positives or mislabelling,^99^ or make no statement on screening.^100^ Guidelines vary substantially in their confidence in interventions to prevent child maltreatment (Appendix A Table 4). The American Academy of Family Physicians reaffirms the USPSTF’s position of insufficient evidence to recommend preventive interventions in a clinical setting to prevent child maltreatment in children without signs and symptoms of maltreatment. Other guideline groups such as the Canadian Task Force on Preventive Health Care and the Community Preventive Services Task Force recommend home visitation programs.^99,100^ The American Academy of Pediatrics recognizes the pediatrician’s unique role in identifying and protecting children and recommends offering anticipatory guidance and referring families to programs and resources to promote safe, stable, nurturing relationships with the aim of preventing maltreatment.^101^ The American Academy of Family Physicians offers a list of steps that primary care physicians can take, while acknowledging insufficient evidence on screening and behavioral interventions.^102^