# Appendix F Study Characteristics

## Key Question 1 Benefits of Interventions to Prevent Child Maltreatment

### Study Characteristics

#### Child Protective Services Reports

Fifteen fair-quality studies reported on CPS outcomes.^110–112,114,116–118,121–126,131,133,135–140,143–146,149^ One was a newly published trial;^133^ additionally, we identified four new publications^135,139,149,150^ associated with already published trials.^110,117,131^

Seven of the 14 included trials recruited participants during pregnancy or immediately after birth.^112,114,116,121,122,126,131^ The other eight trials either included a subset of participants recruited in the perinatal period or focused recruitment on families of infants or children. Four trials reported child maltreatment at baseline,^111,117,123,125^ although, in accordance with our inclusion criteria, no study had more than 50 percent of participants with substantiated reports. Other trials either did not specify prior experience of maltreatment or had participants who had not perpetrated or experienced maltreatment. Most trials (11 of 15) identified participants based on the risk of maltreatment, although the specific risk factors varied across studies.^111,112,114,116–118,121,123,124,126,133,140^ The other studies did not specify maltreatment risk status or recruited from a low-risk population;^110,122,125,131^ participants may have had risk factors for vulnerability such as being pregnant adolescents^131^ or having health or developmental risks.^126^ Four studies targeted teen mothers.^110,121,125,131^

All but one study^123^ included a home-visiting component. The exception was a study set in a clinic for parents entering outpatient substance abuse treatment. Many (6 of 14) had clinical teams (nurses, psychologists) delivering the active intervention.^111,114,121,123,125^ Nearly all studies included a usual-care arm, with one exception, which compared active treatments for alcohol abuse with or without parent skills training.^123^

All but three studies were based in the United States; the exceptions were set in the United Kingdom^112,131^ and New Zealand.^118,140^ Three were primarily clinic-based interventions.^114,122,123^

#### Removal of Child From Home

Six studies, one good-quality trial^113^ and five fair-quality studies,^112,114,120,128,133,136^ reported on child removal outcomes. We identified one new fair-quality study published in 2017.^133^

Four studies recruited persons during pregnancy,^112,113,120,128,136^ one recruited mothers of very low–birth weight infants postpartum,^114^ and one study enrolled families either prenatally or immediately post-delivery through 3 months after birth. One study sample comprised only first-time, adolescent mothers,^128^ and one study predominantly comprised mothers younger than age 20 years.^112^ All other parents (typically mothers) were older than 21 years, on average. One trial recruited only low-income participants (<200% Federal poverty limit).^113^ In all other trials, participants were predominantly low-income populations,^112,114,128,136^ were on public welfare benefits,^120^ or were experiencing financial stress.^133^ In four of five studies reporting partner status,^112–114,120,133^ the majority of participants were single mothers.^113,114,120,133^ Two of the six studies reported that mothers had previous involvement with CPS,^113,120^ and neither study had more than 50 percent of participants with substantiated reports. All six studies screened and selected participants based on the presence of demographic risk factors associated with child maltreatment,^112–114,120,128,133^ with risk factors varying by study.

One study evaluated a comprehensive prenatal and pediatric program,^113^ and five studies evaluated home-visiting interventions.^112,114,120,128,133,136^ Four of the five intervention approaches offering detailed descriptions^112–114,120,128^ involved a multidisciplinary clinical team.^113,114,120,128^ One trial did not describe the intervention in detail.^133^ The prenatal and pediatric program, which was clinic-based but included home visits in some cases following missed appointments, was provided through the child’s second birthday.^113^ The home-visiting interventions varied in duration, intensity, and timing: weekly, biweekly, then monthly visits beginning prenatally through 12 months postpartum;^120^ weekly home visits for at least 6 months;^133^ weekly home visits beginning at 6 months postpartum and provided up to 18 months postpartum;^112,136^ five home visits from birth through 18 months postpartum, supplemented by nurse consultation while the infant was in the hospital and weekly phone contact during the first 8 weeks postpartum;^114^ and five home visits during the first 4 months postpartum.^128^

All six trials compared the active intervention to routine care. The context for the routine care varied: in one study, both arms were conducted in high-risk groups, so the control was also characterized as a “high-risk control.”^113^ In a second study, early-discharge interventions for very low–birth weight infants were compared with routine care.^114^

The studies varied in their definitions of and data sources for evaluating removals. Four of six trials used child welfare and/or court data documenting removal and placement in out-of-home care.^112,113,128,133,136^ One trial included both removal of the child’s siblings or the target child as the outcome but did not specify sibling or target child in reporting the outcome.^113^ Similarly, another trial defined removal as placement in foster care with or without the mother or because of the mother’s incarceration but did not specify this data in reporting outcomes.^128^ Another study assumed removal had occurred if a child’s records showed substantiated child abuse or neglect but did not gather documentation on removal per se.^112,136^ The two trials that did not report child welfare or court records as data sources either relied solely on mothers’ self-report^120^ or provided no information.^114^ Additionally, although one of these studies^120^ reported the number of children in foster care at followup, specific data on how many children had been removed prior to the study was not provided.

All trials focused on outcomes during the first 3 years of the child’s life, each with assessment at different time points: at birth and at 6 months;^120^ 6 months with removal data for the period between 6 months and 12 months also reported;^128^ 12 months (assessing the period between the 6-month and 12-month assessment time points);^112,136^ 18 months;^114^ and 36 months^113^ after the study child’s birth, 2 years after randomization.^133^

Four studies were set in the United States,^113,114,120,133^ one in the United Kingdom,^112,136^ and one in Australia.^128^ One intervention was provided primarily in the clinic.^113^

#### Other Measures of Abuse or Neglect

Three RCTs, of good^113^ and fair^115,131^ quality, reported on study-specific measures of neglect. All studies selected participants based on explicit or implicit considerations of risk. The good-quality study randomized 314 pregnant women in Metropolitan Nashville General Hospital (1984 to 1986) with income less than 200 percent of the Federal poverty level who were identified to be at high risk of maltreatment based on responses to a structured interview, the Maternal History Interview-2.^113^ The interview included questions on knowledge of parenting skills, philosophy about discipline, personality, positive and negative feelings about pregnancy, and the mother’s perception of her nurture as a child.^113^ One fair-quality study randomized 147 families of children born at medical risk (preterm or with a medical condition) in California.^115^ A second fair-quality study selected pregnant adolescents.^131^ None had prior history of maltreatment. All three studies had home-visiting components over 1 to 2 years in addition to usual care and were compared with usual care. In two studies, the usual care was described as comprehensive clinical care.^113,131^ The third study compared a cognitively based extension of the Healthy Start home-visitation program with a home-visitation condition that did not include a cognitively based component.^115^ In the intervention arm, the parents learned to recognize children’s distress and learned problem-solving techniques.

Regarding outcomes, in the good-quality trial, abuse and neglect were identified based on review of public agency documents from the Tennessee Department of Human Services through 36 months of age. Specifically, abuse was defined as “hitting with the hand or objects, biting, burning with objects or by immersion, twisting, shaking, throwing or pushing so as to cause a fall, or hair pulling.” Neglect could arise from “abandonment, leaving a child with an inappropriate caretaker, gross failure to seek medical care, failure to provide shelter or nutrition, or gross failure to provide for normal intellectual development.”

One fair-quality study reported neglect, reported at 1 year following intake, based on the Framingham Safety Survey, which included questions about exposed electrical outlets, crib sides left down, and the presence of windows lacking screens.

#### Failure to Thrive

One fair-quality trial reported on failure to thrive.^114^ In this study, which was conducted in the United States, children born weighing 1500 g or less were randomized to early discharge (prior to infant weighing 2200 g) with home nurse visits after discharge vs. discharge once the infant weighed at least 2200 grams with usual home care after discharge. The intervention arm, which was delivered by nurses with masters-training in neonatal and perinatal medicine, included a home safety assessment done prior to discharge, phone calls after discharge, and home visits after discharge.

#### Failure to Immunize

One fair-quality study of pregnant Australian adolescents that examined home visits versus usual care (1998 to 2000) reported on the proportion with no vaccinations at 6 months.^128^

#### Injuries With a High Specificity for Abuse or Neglect

One fair-quality study reported on the risk of injury with a high specificity for abuse or neglect. Specifically, this study of pregnant Australian adolescents examined the effect of home visits versus usual care (1998 to 2000) on severe nonaccidental injury at 6 months. This outcome was defined as hospital admission as a result of an injury that was “referred for independent investigation by the Family and Children’s Services staff and concluded to have arisen as a result of a nonaccidental injury to the neonate.”^128^

#### Emergency Department Visits

Fourteen fair-quality studies reported on ED visits.^112,114,116,118,119,121,122,126,127,129–132,136,137,140,141,143–150,152^ We did not include studies that reported measures that could potentially have included nonemergency care (“acute care visits” that did not specify whether these were ED visits).^114^ Two of the 14 studies were newly included for this update.^132,152^

Eleven of the 14 fair- or good-quality trials recruited participants during pregnancy or immediately after birth.^112,114,116,119,121,122,126,127,129,131,132,136,137,141,143–147,149,150^ Three of the included trials recruited participants in early infancy.^118,130,140,148,152^ None of the studies reported on child maltreatment at baseline. Eleven of the 14 trials identified participants based on the risk of maltreatment, with specific risk factors varying across the studies.^112,114,116,118,119,121,122,126,127,130,132,136,137,140,141,143–146,148^ The remaining trials randomized all newborns at the study site regardless of baseline risk for maltreatment.^129,131,147,149,150,152^ One study specifically targeted very low–birth weight infants.^114,126^ In three studies, the majority of all mothers were younger than age 20 years.^119,121,131,141,143–146,149,150^ One study only included mothers younger than age 25 years.^132^

All studies included a home-visiting component. Home visits ranged from 4 weeks to 5 years postnatally. The study of very low–birth weight infants paired early discharge and home visits.^114,271^ All studies had a usual-care arm, except one that provided transportation to and from prenatal clinic visits to the control group.^119,141^ Six of the 14 studies had multiple active comparisons against the usual-care arm.^119,121,122,126,127,130,141,143–146,148^

Eight of the 14 studies were based in the United States. The exceptions were four studies set in the United Kingdom,^112,130–132,136,148–150^ one in New Zealand,^118,140^ and one in Canada.^121,127,143,145,146,271^

Nine of 14 included studies reported ED visit outcomes at 1 to <2 years after enrollment or recruitment.^112,121,122,126,127,130–132,136,143–146,148–150,152^ Three of these studies reported only medical record data.^121,131,143–146,149,150,152^ Two used a combination of parental report and medical record data,^122,126^ and four fair- or good-quality studies used parental report only.^112,127,130,132,136,148^

Six of 14 included studies reported ED visit outcomes at 2 to >4 years of followup.^116,118,119,121,129,131,137,140,141,143–147,149,150^ With one exception,^116,118,119,121,129,131,137,140,141,143–147,149^ outcomes were taken from medical records.

#### Hospitalization

Thirteen fair-quality studies reported on hospitalization outcomes.^112,114,116,118,119,122,126,128,131,132,137,140,143,147–150^ One of the 12 studies was newly included for this update.^112,114,116,118,119,122,126,128,131,132,137,140,143,147–149^

Eleven of the 13 fair- or good-quality trials recruited all participants during pregnancy or immediately after birth.^112,114,119,122,126,128,131,132,143,147–150^ Other fair- or good-quality trials focused recruitment on families of infants or children often identified as high risk during the prenatal or perinatal period.^116,118,137,140^ The trials either did not specify prior experience of maltreatment or had participants who had not perpetrated or experienced maltreatment. Most trials (8 of 13) identified participants based on the risk of maltreatment, although the specific risk factors varied across studies.^112,114,116,118,119,126,132,137,140,143^ The other studies did not specify risk status or recruited from a low-risk population.^122,128,131,147–150^ In four studies, the majority of or all mothers were under age 20 years.^119,128,131^ One study only included mothers under the age of 25 years.^132^ All but two studies^122,147^ included a home-visiting component. Many (9 of 13) had clinical teams delivering the active intervention.^114,118,119,128,131,132,140,143,147–150^ All studies included a usual-care arm. Five studies had multiple active comparisons against the usual-care arm.

Seven of the 13 studies were based in the United States; the exceptions were four set in the United Kingdom,^112,131,132,148^ one in New Zealand,^118,140^ and one in Australia.^128^ Four were primarily clinic-based interventions.^114,122,132,147^

#### Internalizing and Externalizing Behaviors

Six fair-quality studies reported on internalizing and externalizing behavioral outcomes in children.^111,116–119,129,137,138,140,141,147^ The primary outcome measures used by most studies to assess behavior symptoms were the CBCL and the ITSEA. In addition to the CBCL and ITSEA, several other measures were used, including the Strengths and Difficulties Questionnaire, the Social Skills Rating System, and the Computerized Diagnostic Interview Schedule for Children.^119,141^

We identified one new publication^139^ of a previously included study.^117,138^

Five of the six fair- or good-quality trials recruited participants during pregnancy or immediately after birth.^116–119,129,137,138,140,141,147^ One good-quality study recruited mothers of children ages 6 to 36 months.^111^ Two of the six fair- or good-quality trials reported child maltreatment at baseline,^111,117,138^ but no study had more than 50 percent of participants with substantiated reports of abuse or neglect. Other trials did not have participants with a history of maltreatment. Five of six fair- or good-quality trials identified participants based on level of risk, either for child maltreatment^116,117,137,138^ or on general sociodemographic and psychosocial risk and/or the presence of child social–emotional/behavioral problems.^111,118,140,141^ One fair-quality study^129,147^ offered services to all families in a primary care setting regardless of vulnerability. For five of the six studies, most or all of the mothers were older than age 20 years.^111,116–118,129,137,138,140,141,147^

All of the six trials included a home-visiting component.^116–119,129,137,138,140,141,147^ Four of the six trials were conducted by clinicians or clinical teams delivering the actual intervention.^111,118,119,129,140,141,147^ Two interventions relied on trained paraprofessionals.^116,117,137–139^ All of the studies included a usual-care arm or no treatment group comparator. One study^141^ randomized participants into four arms: free transportation to prenatal care appointments (group 1); development screening and referral services for the child at 6, 12, and 24 months plus free transportation for prenatal care (group 2); nurse visitation during pregnancy, one postpartum visit in the hospital before discharge, one postpartum visit in the home plus group 2 services (group 3); and nurse visitation through the child’s first 2 years of life plus the group 3 services (group 4). The study compared group 4 with group 2 for the analysis. Another study provided control group participants with information and referrals to other appropriate services in the community.^117,138^

Four fair- or good-quality studies reported on behavior symptoms using the Internalizing and Externalizing Scales of the CBCL^116,117,119,129,137,138,141,147^; two fair- or good-quality studies reported on internalizing and externalizing behavior problems in children using ITSEA.^111,118,140^ One study also used the Strengths and Difficulties Questionnaire.^118,140^ One study later used the Computerized Diagnostic Interview Schedule for Children to assess for behavior symptoms.^119,141^

The timing of assessments varied considerably across the studies, with three studies reporting long-term followup results.^118,138,147^ One trial reported outcomes at 6 and 12 months post-baseline assessment.^111^ Four trials evaluated outcomes between 2 and 4 years of followup.^116,118,119,129,137,140,141,147^ One study evaluated outcomes close to the end of the 3-year intervention period (when children were 30 to 33 months old).^129^ The studies evaluating longer-term effects reported outcomes at different developmental and followup time points: 5 to 5.5 years (approximately 2 years post-intervention completion);^147^ measured and reported as an average at 5, 6, and 9 years (2, 3, and 6 years post-intervention completion);^140^ 7 years (5 years post-intervention completion);^138^ and 9 years (7 years post-intervention completion).^141^

All but two of the studies were based in the United States; one study took place in New Zealand.^118,140^ One fair-quality study took place in a primary care setting with a home-visiting component.^129,147^

#### Social, Emotional, and Developmental Outcomes Not Otherwise Categorized

Five fair- or good-quality trials evaluated discrete social, emotional, or other developmental outcomes separately from overall measures of externalizing or internalizing problems.^111,112,129,136,138,141,147^ All were previously included; no new publications or studies reported on these outcomes.

Two studies recruited women during pregnancy,^112,141^ one study recruited women during pregnancy or up to 3 months postpartum,^117,138^ one study recruited families of newborns up to 4 weeks of age,^129,147^ and one study recruited mothers of children between the ages of 6 and 36 months.^111^

Two studies were conducted with a predominantly low-income population;^111,112,136,141^ the other two studies had a socioeconomically mixed population.^117,129,138,147^ One study sample was predominantly African American.^141^ Three trials had study samples comprised predominantly of single mothers.^111,117,138,141^ Two trials included mothers with a previous history of CPS involvement, which met the threshold for inclusion in this review.^111,117,138^ Four trials screened and selected participants based on level of risk, either for child maltreatment^117,138^ or on general sociodemographic and psychosocial risk and/or the presence of child social–emotional/behavioral problems.^111,112,141^

All five trials included a home-visiting component. Four studies evaluated home-visiting models that focused on intervening for a substantive period starting before and/or during some portion of the child’s first 3 years and that varied on frequency, intensity, and duration.^111,112,117,136,138,141^ Of these, one program initiated visits with children between the ages of 6 and 36 months, providing 12 months of weekly home visits, with the number of visits individualized based on participants’ needs (an average of 22 visits during a 1-year period).^111^ A second trial evaluated a 2-year intervention program that began during pregnancy and provided home visits through the child’s second birthday (an average of 22 home visits during a 2-year period).^117,138^ A third home-visiting study evaluated a program that began during pregnancy and provided biweekly home visits through the child’s second birthday.^141^ A fourth home-visiting trial evaluated a program of weekly visits beginning 6 months postpartum and provided up to 18 months postpartum.^112,136^ A fifth trial evaluated an enhanced pediatric well-childcare model that provided families with a developmental specialist and multiple services including up to six home visits during the child’s first 3 years, including developmental assessments, written materials, parent groups, and linkages to community resources.^129,147^ Two trials used a clinical team in the intervention approach;^111,129,147^ one of these interventions involved a developmental and mental health specialist teaming with a paraprofessional, reflective of the ethnic and cultural diversity of the family, providing care coordination.^111^ One study intervention was delivered solely by nurses,^141^ another by community midwives,^112,136^ while another intervention relied on trained paraprofessionals.^117,138^

Three of the five trials compared the active intervention to usual care.^111,112,129,136,147^ One study^141^ randomized participants into four arms: free transportation to prenatal care appointments (group 1); development screening and referral services for the child at 6, 12, and 24 months plus free transportation for prenatal care (group 2); nurse visitation during pregnancy, one postpartum visit in the hospital before discharge, one postpartum visit in the home plus the group 2 services (group 3); and nurse visitation through the child’s first 2 years of life plus the group 3 services (group 4). The study compared group 4 with group 2 for the analysis. Another study provided control group participants with information and referrals to other appropriate services in the community.^117,138^

Each of the five studies reported different social, emotional, or other developmental outcomes that fell outside the categories of externalizing or internalizing behavior or that were combined with internalizing and/or externalizing outcomes in their measurement. One trial examined dysregulation (i.e., problems with sleep, eating; sensory sensitivities; negative emotionality) as an outcome.^111^ Another study reported on children’s sleep problems^129^ and social skills (i.e., positive social behaviors such as cooperation, empathy, assertion, and self-control; externalizing, internalizing, and hyperactivity problem behaviors; and academic competence).^147^ A third trial evaluated outcomes using the attention and social problems subscales of a measure used to assess problem behavior;^117,138^ this study also reported these outcomes for a subgroup of young, first-time mothers who engaged in the program prenatally. A fourth trial examined children’s conduct problems (1st to 3d grade), antisocial behavior, academically focused behavior, and peer affiliation using either school records or teacher reports and teacher-structured observation.^141^ One study included a measure of infant/toddler social and emotional adjustment but did not report any specific outcomes associated with that measure;^112^ however, a subsequent cost evaluation of the trial^136^ reported generally on outcomes.

The timing of assessments varied considerably across the studies, with three studies reporting long-term followup results.^138,141,147^ One trial reported outcomes at 6 and 12 months post-baseline assessment.^111^ One trial assessed outcomes at 12 months into an 18-month intervention (reflecting the period between the 6-month and 12-month time points).^112,136^ One study evaluated outcomes close to the end of the 3-year intervention period (when children were 30 to 33 months old).^129^ The studies evaluating longer-term effects reported outcomes at different developmental and followup time points: 5 to 5.5 years (approximately 2 years post-intervention completion),^147^ 7 years (5 years post-intervention completion),^138^ and 9 years (7 years post-intervention completion).^141^

Four studies were set in the United States.^111,117,129,138,141,147^ One study was conducted in the United Kingdom.^112,136^

#### Child Development as Measured by the Bayley Scales of Child Development

Four fair- or good-quality studies reported on child development as measured by the Bayley Scales of Child Development.^112,116,119,121,136,137,141,143–146^ In addition, three poor-quality studies reported on child development as measured by the Bayley Scales of Child Development.^272–275^ All previous studies were included in this update. No new studies were identified.

All four of the fair- to good-quality studies recruited participants during pregnancy or immediately after birth.^112,116,119,121,136,137,141,143–146^ Two of the fair-quality studies specifically recruited first-time mothers.^119,121,141,143–146^ The four fair- to good-quality studies identified participants based on risk factors, though different risk factors were used. Three studies reported that a majority of mothers were unmarried.^116,119,121,137,141,143–146^ Three studies reported that a majority of mothers were living at or below the poverty line.^112,116,119,137,141^ Two studies reported that a majority of mothers were younger than age 20,^119,121,141,143–146^ and one study reported that 20 percent of mothers were younger than age 17.^112,136^ Two studies reported that a majority of mothers were experiencing mental health challenges.^112,116,136,137^ Two studies reported on maternal substance use behaviors and exposure to domestic violence.^112,116,136,137^ Maternal substance use ranged from approximately 10^112,136^ to 50^116,137^ percent, and exposure to domestic violence ranged from approximately 30^112,136^ to 50^116,137^ percent across both studies.

All studies included a home-visiting component. This was compared to usual care,^112,136^ developmental screening and referral services for the child at 6, 12, and 24 months of age,^119,141^ referral to other services,^116,137^ and free transportation to well-child visits plus developmental screening for the child at 1 and 2 years of age.^121,143–146^ One study compared a group consisting of participants who got developmental screening at 1 and 2 years of age with or without transportation assistance to two active comparison groups.^121,143–146^ The two active comparison groups in this study got the developmental screening and transportation assistance as well as prenatal visits for one of the active comparison groups and prenatal and postnatal visits for the other active comparison group.

One of the studies was in the United Kingdom,^112,136^ and the others^116,119,121,137,141,143–146^ were in the United States.

#### Other Development Outcomes

Five fair-quality studies reported on other outcome measures.^111,121,125,129,131,143–147,149,150^ We abstracted additional evidence from three trials^111,125,143^ previously included in the review to address an expanded list of developmental outcomes. Four studies recruited participants prenatally or shortly after childbirth;^121,125,131,143,147^ one study recruited participants with children between the ages of 6 and 36 months.^111^ White participants comprised the majority in three trials^121,131,143,147^ and Latinas in two trials.^111,125^ Two trials included mothers with a previous history of CPS involvement, which met the threshold for inclusion in this review.^111,125^ Three studies recruited participants based on level of risk based on general sociodemographic and psychosocial risk and/or the presence of child social–emotional/behavioral problems.^111,121,131^ One study also admitted other pregnant women into the study.^121^

All five studies included a home-visiting component. One study included both a randomized and quasi-experimental component (Healthy Steps for Young Children; 1996 to 1998); this review focuses on the randomized component comparing usual care with a comprehensive pediatric care model with developmental specialists, enhanced developmental services, and home visits.^147^ A second study randomized participants into four arms: sensory and development screening for children at 12 and 24 months (group 1), free transportation to regular prenatal and well-child visits plus the group 1 services (group 2), nurse visitation during pregnancy plus group 2 services (group 3), and nurse visitation through the child’s first 2 years of life plus group 3 services (group 4). The study then combined groups 1 and 2 for the comparator group.^121^ All other studies compared the intervention with usual care.

Each of the five studies reported on development outcomes other than school attendance, school performance, or the Bayley school. One study reported mean scores on the Cattell Scale at 6, 12, and 24 months of age^121^ and on the Stanford-Binet scale at 36 and 48 months.^143^ A second study reported the proportion of parents with a significant concern regarding the child’s development on the Parents’ Evaluation of Development Status at 5 to 5.5 years of age.^147^ A third study reported the number of mothers with concerns on cognitive and language development and also reported results on an early language scale (Early Language Milestone Scale) at 24 months.^131^ Another study reported on child language status using ITSEA at 6 and 12 months.^111^ Finally, one study reported on mother–infant communication at 4 months and infant attachment at 12 months.^138^

#### School Performance

Two U.S.-based trials and one U.K.-based trial, all fair-quality studies reported in multiple publications, addressed school performance outcomes.^117,119,131,138,139,141,142,149,150^ All trials recruited women in the prenatal period; one also included women with infants younger than 3 months old,^117^ and two included nulliparous women^119,131^ who were required to be younger than age 19 in one study.^131^ The majority of women (64%) were younger than age 18 in the other study, but younger age was not required.^119^

Participants in both U.S. studies had sociodemographic risk factors for abuse (e.g., limited education, high score on Kempe Family Stress checklist), and the U.K. study included young (age <19), first-time mothers.^131^ Twenty percent of participants had prior substantiated or unsubstantiated reports of child maltreatment in one study.^117^ The two additional trials included nulliparous women.^119,131^

The overall mean age of women in one study was 22.5 (SD=5.5) years;^117^ mean age per group in the second trial ranged from 17.9 to 18.1 years,^119^ and mean age in both arms in the U.K trial was 17.9.^131^ The majority of participants in one trial were African American or Latina,^117^ majority African American in the second,^119^ and majority White in the U.K. trial.^131^

Interventions in all trials included home-visiting components: one trial evaluated a Healthy Families America–based intervention, Healthy Families New York, which included home visiting by support workers with similar cultural backgrounds as participants, linkage to social services, and parenting education.^117,138,139^ Women randomized to the comparison arm received information and referral to community services. The study also included analyses of a “high prevention opportunity” subgroup, which included first-time mothers younger than age 19 who were enrolled in the study at or before 30 weeks gestation, and a “psychologically vulnerable” subgroup, which included women with depressive symptoms and low mastery of psychological coping.^117^ The study measured school performance outcomes (percentage repeating a grade) at year 7 via interviews with mothers and children.^138^

The second trial attempted to replicate the Elmira nurse home-visiting intervention with a low-income population in Tennessee.^119,141,142^ Women were assigned to one of four conditions: transportation to prenatal care; transportation to prenatal care plus developmental screening and referral services for the child at 6, 12, and 24 months of age; transportation to prenatal care plus developmental screening and referral services for the child at 6, 12, and 24 months of age plus nurse home visitation during pregnancy, one postpartum hospital visit, and one postpartum visit in the home; transportation to prenatal care plus developmental screening and referral services plus nurse home visitation during pregnancy and through the child’s second birthday.^119^ The trial also included analyses of a “low psychological resources” subgroup, defined based on measures of intelligence, mental health, and sense of mastery or self-efficacy. School performance outcomes were evaluated at ages 6 and 9. At age 6, these included a cognitive assessment (Kauffman Assessment Battery for Children [K-ABC]), academic engagement based on teacher report using a scale derived from the Hightower Teacher-Child rating scale; and arithmetic and reading achievement on the K-ABC.^142^ At age 9, school performance assessment included reading and math grade point averages (GPAs) measured from school records; achievement test scores (primarily the Tennessee Comprehensive Assessment Program Achievement Test); the number of times children were retained in grades 1 to 3 based on school records; and teacher-rated “academically focused behavior” derived from the Social Competence Scale, the Social Health Profile, and the Teacher Observation of Child Adjustment.^141^ One study conducted in the United Kingdom randomized young (age <19), nulliparous women at less than 25 weeks gestation (N=1,645) to either intensive home visiting (Family Nurse Partnership) plus standard primary care public health and social care services or usual primary care public health and social care services alone.^131,149,150^ The study reported subgroup analyses for maternal age at recruitment (younger than or older than 16 years); for maternal deprivation measured on the Index of Multiple Deprivation; and for mothers who were or were not in employment, education, or training at the time of recruitment. School performance outcomes were assessed at ages 6 or 7 and included the percentage of children obtaining expected standards in English reading, writing, mathematics, and science measured on national “Key Stage 1” assessments. This study also included subgroup analyses for the number of children reaching expected educational standards by child sex; maternal age (younger than or older than age 16 at recruitment); maternal employment, education, or training or no maternal employment, education, or training at baseline; and by deprivation quintile (1=least deprived to 5=most deprived).^149,150^

#### School Attendance

One U.S.-based trial and one U.K.-based trial, both fair-quality studies reported in multiple publications, addressed school performance outcomes.^117,131,138,139,149,150^ Both trials recruited women in the prenatal period; one also included women with infants younger than 3 months old,^117^ and one included nulliparous women younger than age 19.^131^

Participants in the U.S. trial had sociodemographic risk factors for abuse (high score on Kempe Family Stress checklist), and the U.K. study included young (age <19), first-time mothers.^131^ Twenty percent of participants had prior substantiated or unsubstantiated reports of child maltreatment in the U.S. study,^117^ and the U.K. trial included nulliparous women.^131^

The overall mean age of women in the U.S. study was 22.5 (SD=5.5) years,^117^ and the mean age in both arms in the U.K trial was 17.9.^131^ The majority of participants in the U.S. trial were African American or Latina,^117^ and the majority were White in the U.K. trial.^131^

Interventions in both trials included home-visiting components: the U.S. trial evaluated a Healthy Families America–based intervention, Healthy Families New York, which included home visiting by support workers with similar cultural backgrounds as participants, linkage to social services, and parenting education.^117,138,139^ Women randomized to the comparison arm received information and referral to community services. The study also included analyses of a “high prevention opportunity” subgroup, which included first-time mothers younger than age 19 who were enrolled in the study at or before 30 weeks gestation and “psychologically vulnerable” subgroup, which included women with depressive symptoms and low mastery of psychological coping.^117^ The study measured school attendance outcomes (percentage skipping school “often” or more than once) at year 7 via interviews with mothers and children.^138^

In the U.K. trial, women (age <19, nulliparous, at less than 25 weeks gestation) were randomized to either intensive home visiting (Family Nurse Partnership) plus standard primary care public health and social care services or primary care public health and social care services alone (usual care).^131,149,150^ School attendance outcomes were assessed at ages 6 or 7 and included the rate of school absences and authorized (e.g., missing school because of illness) or unauthorized absences as recorded in the National Pupil Database. The study did not report subgroup analyses for school attendance outcomes.

#### Death

Six studies of fair quality reported on the outcome of child death.^112,114,119,128,131,132,141,149–151^ All studies identified in the previous review are included in this review. We identified two fair-quality studies not previously summarized in the 2004, 2013, or 2018 report.^131,132,149–151^

All six fair-quality studies recruited all participants during pregnancy or immediately after birth.^112,114,119,128,131,132,141,149–151^ Only one fair-quality trial reported child maltreatment at baseline.^119,141^ Other trials did not specify experience of prior maltreatment. Five of the six studies identified participants based on risk of maltreatment, although the specific risk factors varied across studies.^112,114,119,131,132,141,149–151^ The other study recruited from a low-risk population.^128^ In three studies, the majority of or all mothers were younger than age 20 years.^119,128,131,141,149,150^

Five fair-quality studies included a home-visiting component.^112,114,119,128,131,141,149,150^ One study was delivered exclusively in a group setting.^112,114,119,128,131,141,149^ Five had clinical teams delivering the active intervention.^114,119,128,131,132,141,149–151^ All six fair-quality studies included a usual-care arm.

Three of the fair-quality studies took place in the United Kingdom,^112,131,132,149–151^ two were set in the United States,^114,119,141^ and one in Australia.^128^ In these studies, cause of death ranges widely including congenital causes, effects of prematurity, and sudden infant death syndrome, among others.^112,114,119,128,131,132,141,149–151^ A single death across all studies is ruled homicide by firearm.^141^ The vast majority of deaths across studies occur in the first year of life, in part because of limited duration of followup in most studies.^112,114,119,128,131,132,141,149–151^

##### Composite Outcome (Infant Death, Severe Nonaccidental Injury, and Involuntary Foster Care Placement)

One fair-quality trial of home visits by nurse-midwives to teenage mothers recruited from an Australian public-care teenage pregnancy clinic (1998 to 2000) reported on a composite outcome of child abuse and neglect, which the study defined as the pooled incidence of infant death, severe nonaccidental injury, and involuntary foster care placement (N=136 adolescents, mostly low-income mothers and infants).^128^ Participants were not identified to be at risk, and no baseline child maltreatment was reported. Mothers presenting for antenatal visits were recruited and then, after delivery, randomized to receive a set of postnatal visits from the nurse-midwives at 1 week, 2 weeks, 1 month, 2 months, 4 months, and 6 months after delivery or not at all. Visits with the nurse-midwives lasted 1 to 4 hours. The composite outcome was assessed at 6 months.

## Key Question 2 Harms of Interventions to Prevent Child Maltreatment

### Study Characteristics

Two fair-quality U.K.-based studies reported on harms.^131,132,149–151^ One study is new to the update,^132,151^ and the other includes newly abstracted data from a previously included study.^131^ One study randomized young women (25 years of age or younger) to an intensive, nurse-led group 40-session curriculum delivered in child centers, health centers, or community centers, in addition to routine prenatal and child care.^132,151^ The second study randomized pregnant teenagers to a nurse home-visiting program or usual care.^131^ Both studies reported on adverse events.