# Appendix E Quality Ratings

Appendix E Table 1 Quality Ratings, Domain 1: Risk of Bias From Randomization Process

Author, Year, Program/Trial Name | Overall RoB | Comments | 1.1 Random Allocation Sequence | 1.2 Allocation Sequence Concealed | 1.3 Baseline Differences | Domain 1 RoB | Domain 1 Comments
Barlow et al, 2007^112^; McIntosh et al, 2009^136^; (Family Partnership Model) | Some concerns^*^ | For abuse outcomes, the methods only stated that “participating health visitors provided data relating to case conferences, children on the protection register, children removed from the home and child deaths.” Because health visitors had far more contact with the intervention group, it is unclear how this method is equally valid for each group. It is unclear where health visitors got the information about these outcomes (e.g., via health records or purely self-report). | Y | Y | N | Low | None
Barlow et al, 2013^266^; (Family Spirit) | High | No blinding of participants and care providers, no description of adverse event outcomes so cannot judge risk of bias from attrition or measurement bias | Y | Y | PN | Low | None
Barnes et al, 2017^132^; Barnes et al, 2017^151^; (Group Family Nurse Partnership) | Some concerns | Participants and caregivers unblinded, some attrition but no ITT analysis | Y | Y | N | Low | None
Brayden et al, 1993^113^ | Low | Low potential bias arising from each domain | Y | PY | PN | Low | None
Brooten et al, 1986^114^ | Some concerns | Limited information about missing data | PY | NI | PN | Some concerns | No information on some items, but no signal of inadequate randomization
Bugental and Schwartz, 2009^115^; (Healthy Start+) | Some concerns | Study groups were different at baseline, and ITT analysis was not possible because participants who initially accepted the program and then dropped out were unavailable | PY | NI | Y | Some concerns | The education level of mothers at intake was lower in G1 than in G2. In addition, there were significantly more immigrant families in G1 than in G2. To control for these differences, immigration status was included as a between-participants variable and maternal education as a covariate.
Calheiros et al, 2018^267^; (Family Support Program) | High | Randomization scheme inadequate and no evidence that randomization worked, no blinding of participants and care providers | PN | N | NI | High | Odd and even number scheme with no concealed allocation and no information about differences between arms
Demeusy et al, 2021^268^; (Building Healthy Children) | High | No details on randomization or allocation concealment, no CONSORT diagram to confirm N randomized and retained, participants and care providers not blinded | NI | NI | PY | High | No information about randomization or allocation concealment, reported difference in groups by race
Dodge et al, 2019^269^; (Family Connects) | High | Inadequate randomization (alternate day of birth), no evidence of allocation concealment, differential retention and high overall attrition, failure to analyze results by intention to treat | N | N | NI | High | Alternate day of birth randomization, no evidence of concealment (and likely not possible given type of randomization)
Duggan et al, 2007^116^; Caldera et al, 2007^137^; (Healthy Families Alaska) | Some concerns | Some attrition that was not accounted for in the analysis (analysis limited to those present at baseline); those who dropped out were different than those who remained but whether reasons for attrition was differential between arms is unclear | PY | NI | PN | Low | At baseline, intervention mothers were less likely than controls to have poor psychological resources and to have enrolled prenatally. However, this difference does not appear to be the result of poor or failed randomization and would bias the effect measure toward the null
DuMont et al, 2008^117^; DuMont et al, 2010^138^; Kirkland et al, 2020^139^; (Healthy Families New York) | Some concerns | Those who dropped out were different than those who remained but whether reasons for attrition were differential between arms is unclear | PY | NI | N | Low | None
Easterbrooks et al, 2013^110^; Jacobs et al, 2016^134^; Easterbrooks, 2019^135^; (Healthy Families Massachusetts) | Some concerns | Limited information about bias due to randomization, missing data departures from intended intervention | NI | NI | PN | Some concerns | No information on some items, but no signal of inadequate randomization
Fergusson et al, 2005^118^; Fergusson et al, 2013^140^; (Early Start Program) | Some concerns | Some concerns regarding lack of blinding, potential bias in CAN self-report only data, and lack of information about intervention delivery and fidelity | Y | NI | N | Low | None
Finello et al, 1998^126^ | Some concerns | Randomization not described, nonblinded, not powered adequately, significant differential attrition, skeletal information about the implementation of the interventions | NI | NI | PN | Some concerns | The authors report that at the first weekly discharge meeting following the infant’s birth, those infants meeting birth weight criteria for enrollment were discussed and assigned at random to one of the four groups. There was no attempt to assign infants by “‘risk” status to any particular group. However, the randomization process does not provide specific information about the randomization method.
Goodman et al, 2021^270^; (Family Connects) | High | Inadequate randomization based on date of birth, concerns about missing outcome data | N | N | NI | High | Alternate day of birth randomization, no evidence of concealment (and likely not possible given type of randomization)
Green et al, 2017^133^; (Healthy Families Oregon) | Some concerns | Potential for ascertainment bias and bias from process of ascertaining outcomes using administrative data. Because the authors did not have access to unique identifiers, they used probabilistic matching to assign outcomes to participants; potential for error; no blinding of participants or care providers | Y | Y | N | Low | None
Guyer et al, 2003^129^; Minkovitz et al, 2007^147^; (Healthy Steps) | Some concerns | This was a complex multisite study. The intervention entailed a defined core of interventions based on written protocols and guidelines. The program design provided for adapting elements of the package to the needs of the individual families. Some program components could have been implemented at control sites due to the spreading of best/new practices in the HS model. High attrition for longer-term outcomes | Y | Y | N | Low | None
Kitzman et al, 1997^119^; Olds et al, 2007^141^; Olds et al, 2004^142^; (The Memphis Trial) | Some concerns | Long-term attrition, lack of ITT analysis | Y | Y | PN | Low | None
Lam et al, 2009^123^ | Some concerns | Several domains with little or no information | NI | NI | PN | Some concerns | No information on some items, but no signal of inadequate randomization
Larson, 1980^127^ | Some concerns | Differential attrition rates | N | NI | N | Some concerns | Assignment not fully random. Assignment to groups B (G3) and C (G1) was random, ended when 80 participants entered. Then group A (G2) mothers were entered until predetermined date; analysis in this review limited to randomized groups.
Lowell et al, 2011^111^; (Child FIRST) | Some concerns | No allocation concealment | Y | N | PN | Some concerns | Assigned families by coin toss, suggesting no concealment of allocation. Some differences in maternal education and family CPS involvement history, differences do not appear to be the result of poor randomization.
Marcenko and Spence, 1994^120^ | Some concerns | No mention of masking or blinding. Some concerns in the missing outcome data domain because ITT analysis was not used; differences in reasons for attrition and rates of attrition between arms. | NI | NI | N | Some concerns | No information on some items, but no signal of inadequate randomization
Olds et al, 1986^121^; Olds et al, 1994^143^; Olds et al, 1997^144^; Eckenrode et al, 2000^145^; Zielinski et al, 2009^146^; (The Elmira Trial) | Some concerns | Some concern about potential deviation from the intervention during the study duration. | PY | PN | PN | Some concerns | Some randomization overridden to avoid having women in the same house have different treatment assignments.
Quinlivan et al, 2003^128^ | Some concerns | Some baseline imbalance, details not reported | Y | Y | N | Some concerns | Authors note that the following factors seemed imbalanced between the two groups at baseline: ethnic origin, social isolation, involvement of the father of the baby, and homelessness. Analyses controlled for these factors.
Robling et al, 2016^131^; Robling et al, 2021^149^; Robling et al, 2022^150^; (Nurse Family Partnership) | Some concerns | No blinding to allocation, some attrition, and no sensitivity analyses; usual care received co-interventions that diluted the effect of the active intervention; poor fidelity | Y | Y | Y | Low | None
Sadler et al, 2013^125^; (Minding the Baby) | Some concerns | Attrition >20%, no imputation for missing data, unclear whether CPS outcome measurement was record-based or self-report | NI | Y | Y | Some concerns | No information on some items, but no signal of inadequate randomization
Sege et al, 2015^152^; Project DULCE | Some concerns | High but nondifferential attrition | PY | Y | N | Low | None
Siegel et al, 1980^122^; Siegel et al, 1980^122^ | Some concerns | High attrition | NI | NI | PN | Some concerns | Method of randomization is not described. Baseline data are only shown for those who had 4- and 12-month assessments completed. However, a larger group of participants was used for determining health outcomes, and their baseline data are not shown. Authors report that there were not significant differences. Also, the mothers in the intervention group had higher scores on the vocabulary test that was given. In addition, there was some concern about the 41 participants who did not receive the intervention. If they were randomized, they should have been included, but it is not clear whether they were randomized or not.
Silovsky et al, 2011^124^; (SafeCare+) | Some concerns | High attrition | Y | NI | Y | Some concerns | No information on some items, but no signal of inadequate randomization
Wiggins et al, 2005^148^; Wiggins et al, 2004^130^; (The Social Support and Family Health Study) | Some concerns | Some concerns about lack of blinding and poor uptake of second active intervention (CGS). Also, CAN outcomes are based solely on parent self-report and not verified against medical records. Otherwise, fair quality study. | Y | Y | PN | Low | None

* Some concerns for abuse outcomes. Low for behavioral outcomes.

Abbreviations: CAN=child abuse and neglect; CGS=community group support; CONSORT= Consolidated Standards of Reporting Trials; CPS=child protective services; DULCE=Developmental Understanding and Legal Collaboration for Everyone; G1=group 1; G2=group 2; G3=group 3; ITT=intention-to-treat; N=no; NI=no information; PN=probably no; PY=probably yes; ROB=risk of bias; Y=yes.

Appendix E Table 2 Quality Ratings, Domain 2: Risk of Bias Due to Deviations from Intended Interventions

Author, Year, Program/Trial Name | 2.1 Participant Awareness | 2.2 Delivery Awareness | 2.3 Deviations Due to Context | 2.4 Deviation Balancing | 2.5 Affected Outcome | 2.6 Appropriate Analysis | 2.7 Substantial Impact | Domain 2 RoB | Domain 2 Comments
Barlow et al, 2007^112^; McIntosh et al, 2009^136^; (Family Partnership Model) | Y | Y | PN | NA | NA | Y | NA | Low | None
Barlow et al, 2013^266^; (Family Spirit) | Y | Y | PN | NA | NA | PY | NA | Some concerns | Participants and care providers not blinded
Barnes et al, 2017^132^; Barnes et al, 2017^151^; (Group Family Nurse Partnership) | Y | Y | PN | NA | NA | PY | NA | Some concerns | Participants and care providers not blinded
Brayden et al, 1993^113^ | Y | Y | PN | NA | NA | Y | NA | Low | None
Brooten et al, 1986^114^ | Y | Y | PN | NA | NA | Y | NA | Low | None
Bugental and Schwartz, 2009^115^; (Healthy Start+) | Y | Y | PN | NA | NA | Y | NA | Low | None
Calheiros et al, 2018^267^; (Family Support Program) | Y | Y | PN | PN | PN | NA | NA | Some concerns | Participants and care providers not blinded
Demeusy et al, 2021^268^; (Building Healthy Children) | Y | Y | PN | NA | NA | PY | NA | Some concerns | Participants and care providers not blinded
Dodge et al, 2019^269^; (Family Connects) | Y | Y | PN | NA | NA | N | PY | High | Per-protocol analysis that excluded randomization participants who did not receive interventions; trialists and participants were unblinded
Duggan et al, 2007^116^; Caldera et al, 2007^137^; (Healthy Families Alaska) | Y | Y | PN | NA | NA | Y | NA | Low | None
DuMont et al, 2008^117^; DuMont et al, 2010^138^; Kirkland et al, 2020^139^; (Healthy Families New York) | Y | Y | PN | NA | NA | Y | NA | Low | None
Easterbrooks et al, 2013^110^; Jacobs et al, 2016^134^; Easterbrooks, 2019^135^; (Healthy Families Massachusetts) | Y | Y | PN | NA | NA | Y | NA | Some concerns | No information
Fergusson et al, 2005^118^; Fergusson et al, 2013^140^; (Early Start Program) | Y | Y | PN | NA | NA | Y | NA | Low | None
Finello et al, 1998^126^ | Y | Y | NI | NA | NA | Y | NA | Some concerns | The different interventions were “systems” interventions already in place at the hospital. There is very limited information provided about the intended intervention and no information about implementation.
Goodman et al, 2021^270^; (Family Connects) | Y | Y | PN | NA | NA | PN | NA | High | Per-protocol analysis of a subsample that excluded randomization participants who did not receive interventions; trialists and participants were unblinded
Green et al, 2017^133^; (Healthy Families Oregon) | PY | PY | PN | NA | NA | Y | NA | Some concerns | Participants and care providers not blinded
Guyer et al, 2003^129^; Minkovitz et al, 2007^147^; (Healthy Steps) | Y | Y | PY | PN | NI | Y | NA | Some concerns | Authors noted that the sites participating in this clinical trial might not be comparable to all pediatric practices and cautioned that the randomization design might introduce possible spillover effects. Healthy Steps incorporated into its package of services a number of strategies that were already in use in pediatric practices or other agencies in the community. The evaluation gathered information on the number of duplicate services as well as changing practice patterns that might have influenced the findings.
Kitzman et al, 1997^119^; Olds et al, 2007^141^; Olds et al, 2004^142^; (The Memphis Trial) | Y | Y | PN | NA | NA | Y | NA | Low | None
Lam et al, 2009^123^ | Y | Y | PN | NA | NA | Y | NA | Low | None
Larson, 1980^127^ | Y | Y | PN | NA | NA | Y | NA | Low | None
Lowell et al, 2011^111^; (Child FIRST) | Y | Y | PN | NA | NA | Y | NA | Low | None
Marcenko and Spence, 1994^120^ | Y | Y | PN | NA | NA | Y | NA | Low | None
Olds et al, 1986^121^; Olds et al, 1994^143^; Olds et al, 1997^144^; Eckenrode et al, 2000^145^; Zielinski et al, 2009^146^; (The Elmira Trial) | Y | Y | PN | NA | NA | Y | NA | Some concerns | A few cases of mothers inadvertently revealing that they were visited by a nurse, but the staff gathering the data were told that the 15-year followup study was designed to assess the long-range effect of prenatal and early childhood services, including home visitations by nurses. The principal investigators and statisticians had access to the families’ treatment assignments.
Quinlivan et al, 2003^128^ | Y | Y | PN | NA | NA | Y | NA | Low | None
Robling et al, 2016^131^; Robling et al, 2021^149^; Robling et al, 2022^150^; (Nurse Family Partnership) | Y | Y | PY | PN | PY | Y | NA | Some concerns | Usual care received more frequent home visiting services than intervention arm, likely washing out the intervention effect. Only CATI outcomes were collected by blinded assessors. Field assessors were not blinded. This is less of an issue for ED visits/hospitalizations than it would be for some of the behavioral outcomes
Sadler et al, 2013^125^; (Minding the Baby) | Y | Y | PN | NA | NA | Y | NA | Low | None
Sege et al, 2015^152^; (Project DULCE) | Y | Y | PN | PN | PN | Y | NA | Low | None
Siegel et al, 1980^122^ | Y | Y | PN | NA | NA | Y | NA | Low | None
Silovsky et al, 2011^124^; (SafeCare+) | Y | Y | PN | NA | NA | Y | NA | Low | None
Wiggins et al, 2005^148^; Wiggins et al, 2004^130^; (The Social Support and Family Health Study) | Y | Y | PN | NA | NA | Y | NA | Some concerns | Because of the nature of the interventions, it was not possible for either the trial participants or the researchers to be blinded to group allocation. Authors noted that potential confounders were balanced in randomization. However, authors did note poor uptake of intervention

Abbreviations: CATI= Computer Assisted Telephone Interviewing; DULCE=Developmental Understanding and Legal Collaboration for Everyone; ED=emergency department; NA=not applicable; NI=no information; PN=probably no; PY=probably yes; ROB=risk of bias; Y=yes.

Appendix E Table 3 Quality Ratings, Domain 3: Risk of Bias Due to Missing Outcome Data

Author, Year, Program/Trial Name | 3.1 Data Randomized | 3.2 No Bias from Missing Data | 3.3 Missingness Dependency | 3.4 Missingness Likelihood | Domain 3 RoB | Domain 3 Comments
Barlow et al, 2007^112^; McIntosh et al, 2009^136^; (Family Partnership Model) | Y | NA | NA | NA | Low | None
Barlow et al, 2013^266^; (Family Spirit) | NI | PN | NI | NI | Some concerns | No information on the N for adverse events (the only eligible outcomes) and so cannot judge the risk of bias from attrition
Barnes et al, 2017^132^; Barnes et al, 2017^151^; (Group Family Nurse Partnership) | PN | PN | PN | NA | Some concerns | Some attrition (22%) but similar in both arms, no ITT analysis
Brayden et al, 1993^113^ | PN | PY | NA | NA | Low | None
Brooten et al, 1986^114^ | NI | NI | NI | NI | Some concerns | No information provided regarding attrition, but study notes that 57 of 136 eligible infants did not participate for various reasons including death, health or family complications, or refusal. Unclear whether these infants were randomized
Bugental and Schwartz, 2009^115^; (Healthy Start+) | Y | NA | NA | NA | Some concerns | Completers of the program were significantly more likely to be immigrants compared with noncompleters. ITT analysis was not used. The unavailability of all participants who initially accepted the program served to prevent an “intent to treat” analysis.
Calheiros et al, 2018^267^; (Family Support Program) | PN | PY | NA | NA | Low | None
Demeusy et al, 2021^268^; (Building Healthy Children) | PY | NA | NA | NA | Some concerns | Authors do not provide a CONSORT diagram but writeup suggests that all 232 participants randomized were retained
Dodge et al, 2019^269^; (Family Connects) | N | N | NI | NI | High | High overall attrition, differential engagement in the intervention/usual care arms
Duggan et al, 2007^116^; Caldera et al, 2007^137^; (Healthy Families Alaska) | PN | N | PY | NI | Some concerns | Families with versus those without a baseline interview were comparable on the Family Stress Checklist. However, in families followed up vs. those who withdrew, mothers were more likely to have worked before study enrollment (76% vs. 57%, p=0.01), more likely to be married or living with the child’s partner (56% vs. 34%, p<0.01), and less likely to have enrolled prenatally (44% vs. 66%, p=0.01). These mothers may have been less likely to need the problem or experience benefits and their inclusion would likely have moved the outcome to the null; even without their inclusion, program effects were not observed. Whether reasons for attrition was differential between arms is unclear
DuMont et al, 2008^117^; DuMont et al, 2010^138^; Kirkland et al, 2020^139^; (Healthy Families New York) | PN | N | PY | NI | Some concerns | The study used intention-to-treat analysis, but details are not reported, and sensitivity analyses are not provided. Participants who remained in the study (regardless of whether they continued to participate in the program) were more likely than those who dropped out of the study to be first-time mothers (Year 1: 55.5% versus 41.8%, p0.006; Year 2: 56.1% versus 43.9%, p=0.003), but less likely to have been randomly assigned at a gestational age of 30 weeks or less (Year 1: 47.4% versus 84%, p < .001; Year 2: 47.4% versus 80%, p < .001). Whether reasons for attrition were different by arm was unclear
Easterbrooks et al, 2013^110^; Jacobs et al, 2016^134^; Easterbrooks, 2019^135^; (Healthy Families Massachusetts) | NI | NI | NI | NI | Some concerns | No information regarding attrition or missing data was reported
Fergusson et al, 2005^118^; Fergusson et al, 2013^140^; (Early Start Program) | PN | PY | NA | NA | Low | None
Finello et al, 1998^126^ | PN | NI | NI | NI | Some concerns | G2 and G3 are missing >20% data for most 12-month outcomes
Goodman et al, 2021^270^; (Family Connects) | N | N | NI | NI | High | A random subsample selected from those randomized, outcomes from most participants missing (only includes 531/4777 participants)
Green et al, 2017^133^; (Healthy Families Oregon) | PY | PN | PN | NA | Low | None
Guyer et al, 2003^129^; Minkovitz et al, 2007^147^; (Healthy Steps) | N | PY | NA | NA | Some concerns | Missing data were purposefully not statistically adjusted for in the interest of an ITT analytic approach. High attrition. No information provided were missing data in control group vs. intervention group.
Kitzman et al, 1997^119^; Olds et al, 2007^141^; Olds et al, 2004^142^; (The Memphis Trial) | PN^*^ | NI | NI | NI | Some concerns | Low attrition at 6-month followup. Attrition increased over time (9 years) but similar across groups. Lack of information on how missing data were handled.
Lam et al, 2009^123^ | PN | NI | NI | NI | Some concerns | Small sample size, some missing data, use of multiple imputation stated in methods, but N for analysis not clearly specified.
Larson, 1980^127^ | N | PN | NI | NI | Some concerns | Control group with lower attrition than either intervention group.
Lowell et al, 2011^111^; (Child FIRST) | N | PY | NA | NA | Low | None
Marcenko and Spence, 1994^120^ | N | N | PY | NI | Some concerns | Intent-to-treat analysis was not used. Greater attrition in control group because participants not followed by the intervention team.
Olds et al, 1986^121^; Olds et al, 1994^143^; Olds et al, 1997^144^; Eckenrode et al, 2000^145^; Zielinski et al, 2009^146^; (The Elmira Trial) | N | N | PY | NI | Some concerns | Unclear how total N reduced from 314 to 237.
Quinlivan et al, 2003^128^ | Y | NA | NA | NA | Low | None
Robling et al, 2016^131^; Robling et al, 2021^149^; Robling et al, 2022^150^; (Nurse Family Partnership) | N | PN | PY | NI | Some concerns | ED/admission data did not use ITT, nor did they provide sensitivity analyses, but given negative results and similarity of dropout, not clear if failure to do ITT had an impact
Sadler et al, 2013^125^; (Minding the Baby) | N | PN | NI | NI | Some concerns | High attrition; analyses do not appear to account for missing data. Those lost to followup are similar to those retained with the exception of race/ethnicity and cesarean section, no differential attrition.
Sege et al, 2015^152^; (Project DULCE) | N | PN | PN | PN | Some concerns | High but non differential attrition. Unclear whether some families were lost to followup before or after randomization, Text suggests that randomization occurred prior to drop out and exclusion from the sample, the flowchart suggests that the families were not randomized.
Siegel et al, 1980^122^ | N | PN | NI | NI | Some concerns | For the health outcomes, all 321 participants were used, so there is less bias for those than the attachment measures. Unclear whether N analyzed is N randomized
Silovsky et al, 2011^124^; (SafeCare+) | N | PY | NA | NA | Some concerns | High differential attrition at 17 months
Wiggins et al, 2005^148^; Wiggins et al, 2004^130^; (The Social Support and Family Health Study) | N | PN | NI | NI | Some concerns | Overall attrition for both followup time points was at or lower than 20%, no sensitivity analysis but there was no differential attribution between groups.

* Probably no for long-term outcomes

Abbreviations: DULCE=Developmental Understanding and Legal Collaboration for Everyone; G2=group 2; G3=group 3; ITT=intention-to-treat; N=no; NA=not applicable; NI=no information; PN=probably no; PY=probably yes; RoB=risk of bias; Y=yes.

Appendix E Table 4 Quality Ratings, Domain 4: Risk of Bias In Measurement of the Outcome

Author, Year, Program/Trial Name | 4.1 Inappropriate Method | 4.2 Outcome Difference | 4.3 Assessor Awareness | 4.4 Assessment Influence | 4.5 Influence Likelihood | Domain 4 RoB | Domain 4 Comments
Barlow et al, 2007^112^; McIntosh et al, 2009^136^; (Family Partnership Model) | N | PY | N | NA | NA | Some concerns | For abuse outcomes, the methods only state that “participating health visitors provided data relating to case conferences, children on the protection register, children removed from the home and child deaths.” Because health visitors had far more contact with the intervention group, it is unclear how this method is equally valid for each group. It is unclear where health visitors got the information about these outcomes (e.g., via health records or purely self-report). Behavioral outcomes appear to have low concern for bias.
Barlow et al, 2013^266^; (Family Spirit) | NI | NI | N | PN | NA | High | Adverse events not described
Barnes et al, 2017^132^; Barnes et al, 2017^151^; (Group Family Nurse Partnership) | PN | PN | PN | NA | NA | Low | None
Brayden et al, 1993^113^ | N | PN | N | NA | NA | Low | None
Brooten et al, 1986^114^ | N | PN | NI | PN | NA | Some concerns | No information about how the 2 reports of child abuse were described or assessed.
Bugental and Schwartz, 2009^115^; (Healthy Start+) | N | PN | NI | PN | NA | Low | None
Calheiros et al, 2018^267^; (Family Support Program) | PY | PN | PY | PN | NA | Some concerns | Assessment not blinded
Demeusy et al, 2021^268^; (Building Healthy Children) | PY | PN | PN | NA | NA | Low | None
Dodge et al, 2019^269^; (Family Connects) | PN | PN | PN | PN | PN | Low | None
Duggan et al, 2007^116^; Caldera et al, 2007^137^; (Healthy Families Alaska) | N | PN | N | NA | NA | Low | None
DuMont et al, 2008^117^; DuMont et al, 2010^138^; Kirkland et al, 2020^139^; (Healthy Families New York) | N | PN | N | NA | NA | Low | None
Easterbrooks et al, 2013^110^; Jacobs et al, 2016^134^; Easterbrooks, 2019^135^; (Healthy Families Massachusetts) | N | PN | NI | PN | NA | Low | None
Fergusson et al, 2005^118^; Fergusson et al, 2013^140^; (Early Start Program) | N | PN | PY | PY | PN | Some concerns | Authors reported that “no blinding to assignment was undertaken,” which suggests that study personnel, assessors, and participants were not blinded. Child abuse and neglect outcomes only assessed via parent report using severe/very severe assault subscale of the Parent-Child Tactics Scale and parent report of involvement with CPS. The latter is subject to bias without confirmatory data from child welfare records. Authors provide additional child abuse and neglect data: 7 children were admitted to the hospital for child abuse and neglect (5 from control group and 2 from Early Start group).
Finello et al, 1998^126^ | N | PN | NI | NI | NA | Low | None
Goodman et al, 2021^270^; (Family Connects) | PN | PN | PY | NA | NA | Low | None
Green et al, 2017^133^; (Healthy Families Oregon) | PN | PN | PN | NA | NA | Some concerns | Potential for ascertainment bias and bias from process of ascertaining outcomes using administrative data. Because the authors did not have access to unique identifiers, they used probabilistic matching to assign outcomes to participants; potential for error
Guyer et al, 2003^129^; Minkovitz et al, 2007^147^; (Healthy Steps) | N | PN | N | NA | NA | Low | None
Kitzman et al, 1997^119^; Olds et al, 2007^141^; Olds et al, 2004^142^; (The Memphis Trial) | N | PN | N | NA | NA | Low | None
Lam et al, 2009^123^ | N | PN | PY | NI | PN | Low | None
Larson, 1980^127^ | N | PN | Y | NI | PN | Low | None
Lowell et al, 2011^111^; (Child FIRST) | N | PN | Y | PY | PN | Low | None
Marcenko and Spence, 1994^120^ | N | PN | NI | NI | NA | Low | None
Olds et al, 1986^121^; Olds et al, 1994^143^; Olds et al, 1997^144^; Eckenrode et al, 2000^145^; Zielinski et al, 2009^146^; (The Elmira Trial) | N | PN | Y | PY | PN | Low | None
Quinlivan et al, 2003^128^ | N | PN | Y | PY | PN | Low | None
Robling et al, 2016^131^; Robling et al, 2021^149^; Robling et al, 2022^150^; (Nurse Family Partnership) | N | PN | N | NA | NA | Low | None
Sadler et al, 2013^125^; (Minding the Baby) | N | PN | N | NA | NA | Some concerns | No information on how CPS outcomes were measured: unclear whether record-based or self-report.
Sege et al, 2015^152^; (Project DULCE) | PN | PN | PN | PN | NA | Low | None
Siegel et al, 1980^122^ | N | PN | N | NA | NA | Low | None
Silovsky et al, 2011^124^; (SafeCare+) | N | PN | PY | PY | PN | Low | None
Wiggins et al, 2005^148^; Wiggins et al, 2004^130^; (The Social Support and Family Health Study) | N | PN | Y | PY | PN | Some concerns | All outcomes are based on parent self-report and not verified against medical records.

Abbreviations: CPS=child protective services; DULCE=Developmental Understanding and Legal Collaboration for Everyone; N=no; NA=not applicable; NI=no information; PN=probably no; PY=probably yes; RoB=risk of bias; Y=yes.

Appendix E Table 5 Quality Ratings, Domain 5: Risk of Bias In Selection of the Reported Result

Author, Year, Program/Trial Name | 5.1 Appropriate Analysis | 5.2 Multiple Outcomes | 5.3 Multiple Analyses | Domain 5 RoB | Domain 5 Comments
Barlow et al, 2007^112^ McIntosh et al, 2009^136^; (Family Partnership Model) | PY | PN | PN | Low | None
Barlow et al, 2013^266^; (Family Spirit) | PY | PN | PN | Low | None
Barnes et al, 2017^132^; Barnes et al, 2017^151^; (Group Family Nurse Partnership) | PY | PN | PN | Low | None
Brayden et al, 1993^113^ | PY | PN | PN | Low | None
Brooten et al, 1986^114^ | PY | PN | PN | Low | None
Bugental and Schwartz, 2009^115^; (Healthy Start+) | PY | PN | PN | Low | None
Calheiros et al, 2018^267^; (Family Support Program) | PY | PN | PN | Low | None
Demeusy et al, 2021^268^; (Building Healthy Children) | PY | PN | PN | Low | None
Dodge et al, 2019^269^; (Family Connects) | PY | PN | PN | Low | None
Duggan et al, 2007^116^; Caldera et al, 2007^137^; (Healthy Families Alaska) | PY | PN | PN | Low | None
DuMont et al, 2008^117^; DuMont et al, 2010^138^; Kirkland et al, 2020^139^; (Healthy Families New York) | PY | PN | PN | Low | None
Easterbrooks et al, 2013^110^; Jacobs et al, 2016^134^; Easterbrooks, 2019^135^; (Healthy Families Massachusetts) | PY | PN | PN | Low | None
Fergusson et al, 2005^118^; Fergusson et al, 2013^140^; (Early Start Program) | PY | PN | PN | Low | None
Finello et al, 1998^126^ | PY | PN | PN | Low | None
Goodman et al, 2021^270^; (Family Connects) | PY | PN | PN | Low | None
Green et al, 2017^133^; (Healthy Families Oregon) | PY | PN | PN | Low | None
Guyer et al, 2003^129^; Minkovitz et al, 2007^147^; (Healthy Steps) | PY | PN | PN | Low | None
Kitzman et al, 1997^119^; Olds et al, 2007^141^; Olds et al, 2004^142^; (The Memphis Trial) | PY | PN | PN | Low | None
Lam et al, 2009^123^ | PY | PN | PN | Low | None
Larson, 1980^127^ | PY | PN | PN | Low | None
Lowell et al, 2011^111^; (Child FIRST) | PY | PN | PN | Low | None
Marcenko and Spence, 1994^120^ | PY | PN | PN | Low | None
Olds et al, 1986^121^; Olds et al, 1994^143^; Olds et al, 1997^144^; Eckenrode et al, 2000^145^; Zielinski et al, 2009^146^; (The Elmira Trial) | PY | PN | PN | Low | None
Quinlivan et al, 2003^128^ | PY | PN | PN | Low | None
Robling et al, 2016^131^; Robling et al, 2021^149^; Robling et al, 2022^150^; (Nurse Family Partnership) | PY | PN | PN | Low | None
Sadler et al, 2013^125^; (Minding the Baby) | PY | PN | PN | Low | None
Sege et al, 2015^152^; Project DULCE | PY | PN | PN | Low | None
Siegel et al, 1980^122^ | PY | PN | PN | Low | None
Silovsky et al, 2011^124^; (SafeCare+) | PY | PN | PN | Low | None
Wiggins et al, 2005^148^; Wiggins et al, 2004^130^; (The Social Support and Family Health Study) | PY | PN | PN | Low | None

Abbreviations: DULCE=Developmental Understanding and Legal Collaboration for Everyone; PN=probably no; PY=probably yes; RoB=risk of bias.