# Appendix D Evidence Tables

Appendix D Table 1 Characteristic of Randomized Controlled Trials: Program Name, Funding Source, and Design

Appendix D Table 2 Characteristic of Randomized Controlled Trials: Study Arm 1 and Study Arm 2

Appendix D Table 3 Characteristic of Randomized Controlled Trials: Study Arm 3 and Study Arm 4

Appendix D Table 4 Characteristic of Randomized Controlled Trials: Population, Inclusion and Exclusion, and Risk Factors

Appendix D Table 5 Characteristics of Randomized Controlled Trials: Demographics

Appendix D Table 6 Benefits of Primary Care Interventions for Child Maltreatment (KQ 1): Child Protective Services Reports, Categorical Outcomes

Appendix D Table 7 Benefits of Primary Care Interventions for Child Maltreatment (KQ 1): Child Protective Services Reports, Continuous Outcomes

Appendix D Table 8 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Child Protective Services Reports, Categorical Outcomes, Populations of Interest

Appendix D Table 9 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Child Protective Services Reports, Categorical Outcomes, Populations of Interest

Appendix D Table 10 Benefits of Primary Care Interventions for Child Maltreatment (KQ 1): Removal of Child From the Home, Categorical Outcomes

Appendix D Table 11 Benefits of Primary Care Interventions for Child Maltreatment (KQ 1): Removal of Child From the Home, Continuous Outcomes

Appendix D Table 12 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Other Measures of Abuse or Neglect, Categorical Outcomes

Appendix D Table 13 Benefits of Primary Care Interventions for Child Maltreatment (KQ 1): Other Measures of Abuse or Neglect, Continuous Outcomes

Appendix D Table 14 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Injuries With a High Specificity for Abuse, Categorical Outcomes

Appendix D Table 15 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Emergency Department Visits, Categorical Outcomes

Appendix D Table 16 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Emergency Department Visits, Continuous Outcomes

Appendix D Table 17 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Emergency Department Visits, Categorical Outcomes, Populations of Interest

Appendix D Table 18 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Emergency Department Visits, Continuous Outcomes, Populations of Interest

Appendix D Table 19 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Hospitalization, Categorical Outcomes

Appendix D Table 20 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Hospitalization, Continuous Outcomes

Appendix D Table 21 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Hospitalization, Categorical Outcomes, Populations of Interest

Appendix D Table 22 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Hospitalization, Continuous Outcomes, Populations of Interest

Appendix D Table 23 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Failure to Thrive, Categorical Outcomes

Appendix D Table 24 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Failure to Immunize, Categorical Outcomes

Appendix D Table 25 Benefits of Primary Care Interventions for Child Maltreatment (KQ 1): Decreased Internalizing, Externalizing, or Internalizing and Externalizing Behaviors, Categorical Outcome

Appendix D Table 26 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Decreased Internalizing, Externalizing, or Internalizing and Externalizing Behaviors, Continuous Outcome

Appendix D Table 27 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Decreased Internalizing, Externalizing, or Internalizing and Externalizing Behaviors, Continuous Outcomes, Populations of Interest

Appendix D Table 28 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Other Social, Emotional, and Developmental Problems Not Otherwise Categorized, Categorical Outcome

Appendix D Table 29 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Other Social, Emotional, and Developmental Problems Not Otherwise Categorized, Continuous Outcomes

Appendix D Table 30 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Other Social, Emotional, and Developmental Problems Not Otherwise Categorized, Continuous Outcomes, Populations of Interest

Appendix D Table 31 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Healthy Social–Emotional Development Based on Bayley Scales of Infant Development, Categorical Outcome

Appendix D Table 32 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Healthy Social–Emotional Development Based on Bayley Scales of Infant Development, Continuous Outcome

Appendix D Table 33 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Healthy Social–Emotional Development Based on Bayley Scales of Infant Development, Populations of Interest

Appendix D Table 34 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Other Measures of Healthy Social–Emotional Development and Delayed Developmental Delays, Categorical Outcome

Appendix D Table 35 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Other Measures of Healthy Social–Emotional Development and Developmental Delays, Continuous Outcome

Appendix D Table 36 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Other Measures of Healthy Social–Emotional Development and Developmental Delays, Categorical Outcomes, Populations of Interest

Appendix D Table 37 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Other Measures of Healthy Social–-Emotional Development and Developmental Delays, Continuous Outcomes, Populations of Interest

Appendix D Table 38 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): School Performance, Categorical Outcome

Appendix D Table 39 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): School Performance, Continuous Outcomes

Appendix D Table 40 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): School Performance, Categorical Outcomes, Populations of Interest

Appendix D Table 41 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): School Performance, Continuous Outcomes, Populations of Interest

Appendix D Table 42 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): School Attendance, Categorical Outcome

Appendix D Table 43 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): School Attendance, Categorical Outcomes, Populations of Interest

Appendix D Table 44 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Mortality, Categorical Outcome

Appendix D Table 45 Benefits of Primary Care Interventions for Child Maltreatment Prevention (KQ 1): Combination Adverse Neonatal Outcomes

Appendix D Table 46 Harms of Primary Care Interventions for Child Maltreatment Prevention (KQ 2): Adverse Events