# Appendix C Excluded Studies

Exclusion Codes:

X1 Ineligible publication type
X2 Ineligible population
X3 Ineligible/no intervention
X4 Ineligible/no comparison
X5 Ineligible/no outcomes
X6 Ineligible/nonclinical setting
X7 Ineligible study design
X8 Ineligible country/region
X9 Not in English
X10 Relevant protocol or ongoing study
X11 Duplicate
X12 Poor quality

1 Brayden RM, Altemeier WA, Dietrich MS, . A prospective study of secondary prevention of child maltreatment. J Pediatr. 1993 Apr;122(4):511–6. PMID: 8463893. Exclusion Code: X11.8463893
2 Eckenrode J, Ganzel B, Henderson CR, Jr., . Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000 Sep 20;284(11):1385–91. PMID: 10989400. Exclusion Code: X11.10989400
3 Guterman NB, Bellamy JL, Banman A. Promoting father involvement in early home visiting services for vulnerable families: Findings from a pilot study of “Dads matter”. Child Abuse Negl. 2018 Feb;76:261–72. doi: 10.1016/j.chiabu.2017.10.017. PMID: 29169043. Exclusion Code: X5.29169043
4 Abrahamse ME, Tsang VMW, Lindauer RJL. Home-based parent-child interaction therapy to prevent child maltreatment: a randomized controlled trial. Int J Environ Res Public Health. 2021 Aug 4;18(16)doi: 10.3390/ijerph18168244. PMID: 34444004. Exclusion Code: X5.34444004
5 Akin BA, McDonald TP. Parenting intervention effects on reunification: a randomized trial of PMTO in foster care. Child Abuse Negl. 2018 Sep;83:94–105. doi: 10.1016/j.chiabu.2018.07.011. PMID: 30025308. Exclusion Code: X5.30025308
6 Baggett K, Davis B, Feil E, . A randomized controlled trial examination of a remote parenting intervention: engagement and effects on parenting behavior and child abuse potential. Child Maltreat. 2017 Nov;22(4):315–23. doi: 10.1177/1077559517712000. PMID: 28587520. Exclusion Code: X5.28587520
7 Barlow J, Sembi S, Parsons H, . A randomized controlled trial and economic evaluation of the Parents Under Pressure program for parents in substance abuse treatment. Drug Alcohol Depend. 2019 Jan 1;194:184–94. doi: 10.1016/j.drugalcdep.2018.08.044. PMID: 30447510. Exclusion Code: X5.30447510
8 Behrens B, Edler K, Cote K, . Child internalizing symptoms during the COVID-19 pandemic among maltreating and non-maltreating families: examining the effects of family resources and the reminiscing and emotion training intervention. Child Abuse Negl. 2021 Oct 25:105375. doi: 10.1016/j.chiabu.2021.105375. PMID: 34749997. Exclusion Code: X2.34749997
9 Cala Cala LF, Kelly CL, Ramos E, . Which mothers know that all babies cry? a randomized controlled trial of a child abuse prevention program for low-income new mothers. Clin Pediatr (Phila). 2020 Sep;59(9–10):865–73. doi: 10.1177/0009922820922532. PMID: 32432487. Exclusion Code: X5.32432487
10 Colegrove VM, Havighurst SS, Kehoe CE, . Pilot randomized controlled trial of Tuning Relationships with Music: intervention for parents with a trauma history and their adolescent. Child Abuse Negl. 2018 May;79:259–68. doi: 10.1016/j.chiabu.2018.02.017. PMID: 29486348. Exclusion Code: X5.29486348
11 Cox JE, Harris SK, Conroy K, . A parenting and life skills intervention for teen mothers: a randomized controlled trial. Pediatrics. 2019 Mar;143(3)doi: 10.1542/peds.2018-2303. PMID: 30755464. Exclusion Code: X5.30755464
12 Demeusy EM, Handley ED, Manly JT, . Building healthy children: a preventive intervention for high-risk young families. Dev Psychopathol. 2021 May;33(2):598–613. doi: 10.1017/s0954579420001625. PMID: 33757620. Exclusion Code: X12.33757620
13 Dijkstra S, Asscher JJ, Deković M, . A randomized controlled trial on the effectiveness of family group conferencing in child welfare: effectiveness, moderators, and level of FGC completion. Child Maltreat. 2019 May;24(2):137–51. doi: 10.1177/1077559518808221. PMID: 30463425. Exclusion Code: X2.30463425
14 Dodge KA, Goodman WB, Bai Y, . Effect of a community agency-administered nurse home visitation program on program use and maternal and infant health outcomes: a randomized clinical trial. JAMA Netw Open. 2019 Nov 1;2(11):e1914522. doi: 10.1001/jamanetworkopen.2019.14522. PMID: 31675088. Exclusion Code: X12.31675088
15 Eddy JM, Shortt JW, Martinez CR, Jr., . Outcomes from a randomized controlled trial of the relief nursery program. Prev Sci. 2020 Jan;21(1):36–46. doi: 10.1007/s11121-019-00992-9. PMID: 30729363. Exclusion Code: X5.30729363
16 Feinberg ME, Jones DE, Hostetler ML, . Couple-focused prevention at the transition to parenthood, a randomized trial: effects on coparenting, parenting, family violence, and parent and child adjustment. Prev Sci. 2016 Aug;17(6):751–64. doi: 10.1007/s11121-016-0674-z. PMID: 27334116. Exclusion Code: X5.27334116
17 Goodman WB, Dodge KA, Bai Y, . Effect of a universal postpartum nurse home visiting program on child maltreatment and emergency medical care at 5 years of age: a randomized clinical trial. JAMA Netw Open. 2021 Jul 1;4(7):e2116024. doi: 10.1001/jamanetworkopen.2021.16024. PMID: 34232300. Exclusion Code: X12.34232300
18 Guastaferro K, Felt JM, Font SA, . Parent-Focused Sexual Abuse Prevention: Results From a Cluster Randomized Trial. Child Maltreat. 2020 Oct 7:1077559520963870. doi: 10.1177/1077559520963870. PMID: 33025835. Exclusion Code: X5.33025835
19 Guastaferro K, Lai BS, Miller K, . Braiding two evidence-based programs for families at-risk: results of a cluster randomized trial. J Child Fam Stud. 2018 Feb;27(2):535–46. doi: 10.1007/s10826-017-0886-2. PMID: 29540976. Exclusion Code: X4.29540976
20 Gülırmak K, Orak OS. Effectiveness of web-based distance education for parents in the prevention of emotional neglect and abuse: A randomized controlled study. Perspect Psychiatr Care. 2021 Apr;57(2):573–82. doi: 10.1111/ppc.12580. PMID: 32668039. Exclusion Code: X5.32668039
21 Hefti S, Pérez T, Fürstenau U, . Multisystemic Therapy for child abuse and neglect: do parents show improvement in parental mental health problems and parental stress? J Marital Fam Ther. 2020 Jan;46(1):95–109. doi: 10.1111/jmft.12367. PMID: 30516844. Exclusion Code: X2.30516844
22 Jones D, Feinberg M, Hostetler M, . Family and Child Outcomes 2 Years After a Transition to Parenthood Intervention. Fam Relat. 2018 Apr;67(2):270–86. doi: 10.1111/fare.12309. PMID: 30140113. Exclusion Code: X5.30140113
23 Kızıltepe R, Eslek D, Irmak TY, . “I am Learning to Protect Myself with Mika:” a teacher-based child sexual abuse prevention program in turkey. J Interpers Violence. 2021 Jan 15:886260520986272. doi: 10.1177/0886260520986272. PMID: 33446045. Exclusion Code: X3.33446045
24 Kliem S, Sandner M. Prenatal and Infancy Home Visiting in Germany: 7-Year Outcomes of a Randomized Trial. Pediatrics. 2021 Aug;148(2)doi: 10.1542/peds.2020-049610. PMID: 34326178. Exclusion Code: X5.34326178
25 Labella MH, Lind T, Sellers T, . Emotion regulation among children in foster care versus birth parent care: differential effects of an early home-visiting intervention. J Abnorm Child Psychol. 2020 Aug;48(8):995–1006. doi: 10.1007/s10802-020-00653-4. PMID: 32419117. Exclusion Code: X2.32419117
26 Lane WG, Dubowitz H, Frick KD, . Cost effectiveness of SEEK: A primary care-based child maltreatment prevention model. Child Abuse Negl. 2021 Jan;111:104809. doi: 10.1016/j.chiabu.2020.104809. PMID: 33203542. Exclusion Code: X5.33203542
27 Lanier P, Dunnigan A, Kohl PL. Impact of pathways triple p on pediatric health-related quality of life in maltreated children. J Dev Behav Pediatr. 2018 Dec;39(9):701–8. doi: 10.1097/dbp.0000000000000608. PMID: 30074927. Exclusion Code: X2.30074927
28 LeCroy CW, Lopez D. A Randomized Controlled Trial of Healthy Families: 6-Month and 1-Year Follow-Up. Prev Sci. 2020 Jan;21(1):25–35. doi: 10.1007/s11121-018-0931-4. PMID: 30039328. Exclusion Code: X5.30039328
29 Liu S, Phu T, Dominguez A, . Improving Caregiver Self-Efficacy and Children’s Behavioral Outcomes via a Brief Strength-Based Video Coaching Intervention: Results from a Randomized Controlled Trial. Prev Sci. 2021 May 7doi: 10.1007/s11121-021-01251-6. PMID: 33961176. Exclusion Code: X5.33961176
30 Ondersma SJ, Martin J, Fortson B, . Technology to Augment Early Home Visitation for Child Maltreatment Prevention: A Pragmatic Randomized Trial. Child Maltreat. 2017 Nov;22(4):334–43. doi: 10.1177/1077559517729890. PMID: 28954530. Exclusion Code: X5.28954530
31 O’Neill KMG, Cluxton-Keller F, Burrell L, . Impact of a Child Abuse Primary Prevention Strategy for New Mothers. Prev Sci. 2020 Jan;21(1):4–14. doi: 10.1007/s11121-018-0925-2. PMID: 29987503. Exclusion Code: X5.29987503
32 Pfeiffer H, Cowley LE, Kemp AM, . Validation of the PredAHT-2 prediction tool for abusive head trauma. Emerg Med J. 2020 Mar;37(3):119–26. doi: 10.1136/emermed-2019-208893. PMID: 31932397. Exclusion Code: X3.31932397
33 Portnoy J, Raine A, Liu J, . Reductions of intimate partner violence resulting from supplementing children with omega-3 fatty acids: A randomized, double-blind, placebo-controlled, stratified, parallel-group trial. Aggress Behav. 2018 May 20doi: 10.1002/ab.21769. PMID: 29781086. Exclusion Code: X5.29781086
34 Prinz RJ. Assessing child maltreatment prevention via administrative data systems: a case example of reproducibility. Child Abuse Negl. 2017 Feb;64:13–8. doi: 10.1016/j.chiabu.2016.12.005. PMID: 27992829. Exclusion Code: X3.27992829
35 Riem MME, Lotz AM, Horstman LI, . A soft baby carrier intervention enhances amygdala responses to infant crying in fathers: a randomized controlled trial. Psychoneuroendocrinology. 2021 Oct;132:105380. doi: 10.1016/j.psyneuen.2021.105380. PMID: 34391194. Exclusion Code: X5.34391194
36 Self-Brown S, Osborne MC, Boyd C, Jr., . The impact of SafeCare® Dads to Kids program on father maltreatment risk and involvement: outcomes and lessons learned from an efficacy trial. Child Abuse Negl. 2018 Sep;83:31–41. doi: 10.1016/j.chiabu.2018.06.014. PMID: 30016743. Exclusion Code: X5.30016743
37 Self-Brown S, Osborne MC, Lai BS, . Initial findings from a feasibility trial examining the safecare dad to kids program with marginalized fathers. J Fam Violence. 2017 Nov;32(8):751–66. doi: 10.1007/s10896-017-9940-5. PMID: 29307956. Exclusion Code: X5.29307956
38 Slep AMS, Heyman RE, Lorber MF, . Evaluating the Effectiveness of NORTH STAR: a community-based framework to reduce adult substance misuse, intimate partner violence, child abuse, suicidality, and cumulative risk. Prev Sci. 2020 Oct;21(7):949–59. doi: 10.1007/s11121-020-01156-w. PMID: 32827290. Exclusion Code: X5.32827290
39 Slep AMS, Heyman RE, Lorber MF, . The impact of NORTH STAR on suicidality, substance problems, intimate partner violence, and child abuse. Mil Med. 2021 Feb 26;186(3–4):e351–e8. doi: 10.1093/milmed/usaa380. PMID: 33169138. Exclusion Code: X5.33169138
40 Steele H, Murphy A, Bonuck K, . Randomized control trial report on the effectiveness of Group Attachment-Based Intervention (GABI©): improvements in the parent-child relationship not seen in the control group. Dev Psychopathol. 2019 Feb;31(1):203–17. doi: 10.1017/s0954579418001621. PMID: 30757992. Exclusion Code: X5.30757992
41 Vanderzee KL, John SG, Edge N, . A preliminary evaluation of the managing youth trauma effectively program for substance-abusing women and their children. Infant Ment Health J. 2017 May;38(3):422–33. doi: 10.1002/imhj.21639. PMID: 28464299. Exclusion Code: X5.28464299
42 Villodas MT, Moses JO, Cromer KD, . Feasibility and promise of community providers implementing home-based parent-child interaction therapy for families investigated for child abuse: a pilot randomized controlled trial. Child Abuse Negl. 2021 Jul;117:105063. doi: 10.1016/j.chiabu.2021.105063. PMID: 33930663. Exclusion Code: X2.33930663
43 Whitaker DJ, Self-Brown S, Hayat MJ, . Effect of the SafeCare© intervention on parenting outcomes among parents in child welfare systems: a cluster randomized trial. Prev Med. 2020 Sep;138:106167. doi: 10.1016/j.ypmed.2020.106167. PMID: 32569643. Exclusion Code: X2.32569643
44 Yarger HA, Lind T, Raby KL, . Intervening with attachment and biobehavioral catch-up to reduce behavior problems among children adopted internationally: evidence from a randomized controlled trial. Child Maltreat. 2021 Apr 22:10775595211010975. doi: 10.1177/10775595211010975. PMID: 33882710. Exclusion Code: X5.33882710
45 Zief S, Deke J, Burkander P, . Impacts of a home visiting program enhanced with content on healthy birth spacing. Matern Child Health J. 2020 Sep;24(Suppl 2):105–18. doi: 10.1007/s10995-020-02968-6. PMID: 32638144. Exclusion Code: X5.32638144
46 Bailhache M, Bénard A, Salmi LR. Simulation of the impact of programs for prevention and screening of pediatric abusive head trauma. J Neurotrauma. 2016 Jul 15;33(14):1397–403. doi: 10.1089/neu.2015.4014. PMID: 26566679. Exclusion Code: X7.26566679
47 Beyazit U, Bütün Ayhan A. A study on the mother education program for the prevention of child neglect. Psychol Rep. 2019 Dec;122(6):2178–200. doi: 10.1177/0033294118825100. PMID: 30669953. Exclusion Code: X5.30669953
48 Chaiyachati BH, Gaither JR, Hughes M, . Preventing child maltreatment: examination of an established statewide home-visiting program. Child Abuse Negl. 2018 May;79:476–84. doi: 10.1016/j.chiabu.2018.02.019. PMID: 29558714. Exclusion Code: X7.29558714
49 Chartier M, Nickel NC, Chateau D, . Families first home visiting programme reduces population-level child health and social inequities. J Epidemiol Community Health. 2018 Jan;72(1):47–53. doi: 10.1136/jech-2017-209321. PMID: 29122995. Exclusion Code: X7.29122995
50 Chartier MJ, Brownell MD, Isaac MR, . Is the families first home visiting program effective in reducing child maltreatment and improving child development? Child Maltreat. 2017 May;22(2):121–31. doi: 10.1177/1077559517701230. PMID: 28413917. Exclusion Code: X7.28413917
51 Czerwinski F, Finne E, Alfes J, . Effectiveness of a school-based intervention to prevent child sexual abuse-evaluation of the German IGEL program. Child Abuse Negl. 2018 Dec;86:109–22. doi: 10.1016/j.chiabu.2018.08.023. PMID: 30278285. Exclusion Code: X3.30278285
52 Matone M, Kellom K, Griffis H, . A Mixed Methods Evaluation of Early Childhood Abuse Prevention Within Evidence-Based Home Visiting Programs. Matern Child Health J. 2018 Oct;22(Suppl 1):79–91. doi: 10.1007/s10995-018-2530-1. PMID: 29855837. Exclusion Code: X7.29855837
53 Segal L, Nguyen H, Gent D, . Child protection outcomes of the Australian Nurse Family Partnership Program for Aboriginal infants and their mothers in Central Australia. PLoS One. 2018;13(12):e0208764. doi: 10.1371/journal.pone.0208764. PMID: 30532276. Exclusion Code: X7.30532276
54 Spencer RA, Livingston MD, Komro KA, . Association between Temporary Assistance for Needy Families (TANF) and child maltreatment among a cohort of fragile families. Child Abuse Negl. 2021 Oct;120:105186. doi: 10.1016/j.chiabu.2021.105186. PMID: 34229993. Exclusion Code: X5.34229993
55 Hollen L, Bennett V, Nuttall D, . Evaluation of the efficacy and impact of a clinical prediction tool to identify maltreatment associated with children’s burns. BMJ Paediatr Open. 2021;5(1):e000796. doi: 10.1136/bmjpo-2020-000796. PMID: 33644416. Exclusion Code: X7.33644416
56 Barlow A, Mullany B, Neault N, . Effect of a paraprofessional home-visiting intervention on American Indian teen mothers’ and infants’ behavioral risks: a randomized controlled trial. Am J Psychiatry. 2013 Jan;170(1):83–93. doi: 10.1176/appi.ajp.2012.12010121. PMID: 23409290. Exclusion Code: X12.23409290
57 Bruzelius E, Levy NS, Okuda M, . Prescription drug monitoring and child maltreatment in the United States, 2004-2018. J Pediatr. 2021 Oct 20doi: 10.1016/j.jpeds.2021.10.014. PMID: 34678247. Exclusion Code: X3.34678247
58 Garcia AR, Gupta M, Greeson JKP, . Adverse childhood experiences among youth reported to child welfare: results from the national survey of child & adolescent wellbeing. Child Abuse Negl. 2017 Aug;70:292–302. doi: 10.1016/j.chiabu.2017.06.019. PMID: 28668759. Exclusion Code: X2.28668759
59 Putnam-Hornstein E, Needell B, King B, . Racial and ethnic disparities: a population-based examination of risk factors for involvement with child protective services. Child Abuse Negl. 2013 Jan;37(1):33–46. doi: 10.1016/j.chiabu.2012.08.005. PMID: 23317921. Exclusion Code: X3.23317921
60 Turner CW, Robbins MS, Rowlands S, . Summary of comparison between FFT-CW(®) and Usual Care sample from Administration for Children’s Services. Child Abuse Negl. 2017 Jul;69:85–95. doi: 10.1016/j.chiabu.2017.04.005. PMID: 28456068. Exclusion Code: X2.28456068
61 Heinrichs M, Kliem S, Hahlweg K. Addendum to “four-year follow-up of a randomized controlled trial of triple p group for parent and child outcomes”. Prev Sci. 2017;18(4):491–503. doi: 10.1007/s11121-017-0782-4. PMID: CN-01623103. Exclusion Code: X5.28389746
62 Kim T. Do child sexual abuse prevention programs work? results from an evaluation of the second step child protection unit. J Am Acad Child Adolesc Psychiatry. 2020;59(10):S334-. doi: 10.1016/j.jaac.2020.07.810. PMID: CN-02207617. Exclusion Code: X1.
63 Barone L, Carone N, Costantino A, . Effect of a parenting intervention on decreasing adolescents’ behavioral problems via reduction in attachment insecurity: a longitudinal, multicenter, randomized controlled trial. J Adolesc. 2021;91:82–96. doi: 10.1016/j.adolescence.2021.07.008. PMID: CN-02347451. Exclusion Code: X5.34352497
64 Brianda ME, Roskam I, Mikolajczak M. Treating parental burnout: comparative efficiency of two psychological interventions. Psychother Psychosom. 2019;88:18–9. doi: 10.1159/000502467. PMID: CN-02005703. Exclusion Code: X1.
65 Calheiros MM, Patrício JN, Graça J, . Evaluation of an intervention program for families with children at risk for maltreatment and developmental impairment: a preliminary study. J Child Fam Stud. 2018;27(5):1605–13. doi: 10.1007/s10826-017-0988-x. PMID: CN-02114314. Exclusion Code: X12.
66 Colditz PB, Boyd RN, Winter L, . A randomized trial of Baby Triple P for Preterm Infants: child outcomes at 2 years of corrected age. J Pediatr. 2019;210:48–54.e2. doi: 10.1016/j.jpeds.2019.01.024. PMID: CN-02090289. Exclusion Code: X5.30857773
67 Dale R, Shanley DC, Zimmer-Gembeck MJ, . Empowering and protecting children by enhancing knowledge, skills and well-being: a randomized trial of Learn to BE SAFE with Emmy. Child Abuse Negl. 2016;51:368–78. doi: 10.1016/j.chiabu.2015.07.016. PMID: CN-01215110. Exclusion Code: X6.26360708
68 Fleming GE, Kimonis ER, Furr JM, . Internet-delivered parent training for preschoolers with conduct problems: do callous-unemotional traits moderate efficacy and engagement? J Abnorm Child Psychol. 2020;48(9):1169–82. doi: 10.1007/s10802-020-00660-5. PMID: CN-02158937. Exclusion Code: X5.32533295
69 IRCT. Design and effectiveness of training the Upbringing sexual of children to mothersâ€™ on knowledge and attitude of mothers to preventing sexual abuse. Cochrane. 2020 PMID: CN-02171091. Exclusion Code: X4.
70 ISRTN. BarnSäkert“ a safe environment for every child. Cochrane. 2020 PMID: CN-02172050. Exclusion Code: X10.
71 Jprn U. Examination of effective practice method for mothers of parenting program CARE in community health field - randomized controlled trial. Cochrane. 2018 PMID: CN-01903875. Exclusion Code: X4.
72 University of Tokyo, Graduate School of Medicine, Department of Mental Health. Behavioral activation therapy program via smartphone for postnatal mothers and babies. Cochrane Library ICTRP JPRN-UMIN000036864: World Health Organization International Clinical Trials Registry Platform; 27 May 2019. Exclusion Code: X10.
73 Khosravan S, Sajjadi M, Moshari J, . The effect of education on the attitude and child abuse behaviors of mothers with 3-6 year old children: a randomized controlled trial study. J Community Based Nurs Midwifery. 2018;6(3):227–38. PMID: CN-02114856. Exclusion Code: X8.
74 Kitzman H, Olds DL, Knudtson MD, . Prenatal and Infancy Nurse Home Visiting and 18-Year Outcomes of a Randomized Trial. Pediatrics. 2019;144(6)doi: 10.1542/peds.2018-3876. PMID: CN-02007261. Exclusion Code: X5.
75 Kliem S, Sandner M, Lohmann A, . Follow-up study regarding the medium-term effectiveness of the home-visiting program “Pro Kind” at age 7 years: study protocol for a randomized controlled trial. Trials. 2018;19(1)doi: 10.1186/s13063-018-2707-3. PMID: CN-01611102. Exclusion Code: X5.
76 Longhi E, Murray L, Hunter R, . The NSPCC UK Minding the Baby® (MTB) home-visiting programme, supporting young mothers (aged 14-25) in the first 2 years of their baby’s life: study protocol for a randomised controlled trial. Trials. 2016;17(1):486. doi: 10.1186/s13063-016-1618-4. PMID: CN-01444256. Exclusion Code: X10.27717374
77 REBEC. Effects of a program that assists parents in their child’s education. 2019. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-02071112/full Exclusion Code: X8.
78 NCT. Be Good Parents (Parent Education). Cochrane. 2016 PMID: CN-01560469. Exclusion Code: X5.
79 NCT. SEEK: dissemination and Implementation. 2018. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01662509/full Exclusion Code: X10.
80 NCT. Promotion of Successful Parenting. Cochrane. 2019 PMID: CN-01918887. Exclusion Code: X5.
81 NCT. A randomized controlled study of safer kids: a manualized intervention to prevent child abuse. Cochrane. 2019 PMID: CN-02009838. Exclusion Code: X2.
82 NCT. The Effect of Education on Prevention of Shaken Baby Syndrome. Cochrane. 2020 PMID: CN-02174358. Exclusion Code: X5.
83 Prevention of childhood maltreatment in families with young children. Cochrane Central Register of Controlled Trials NCT04341376; 31 October 2020. Exclusion Code: X10.
84 Study to understand risk and resilience opportunity for newborns after delivery. Cochrane Central Register of Controlled Trials NCT04438161; 31 October 2020. Exclusion Code: X10.
85 NCT. MIO-CPP to improve the well-being, permanency, and safety outcomes for young children at risk of or in out-of-home placement in philadelphia and bucks counties, and affected by maternal substance use. Cochrane. 2020 PMID: CN-02088732. Exclusion Code: X4.
86 Substance Use Treatment and Access to Resources (STARS) project. Cochrane Central Register of Controlled Trials NCT04459000; 31 October 2020. Exclusion Code: X10.
87 NCT. Pilot Trial of Family Partner - a Child Maltreatment Prevention Intervention. Cochrane. 2021 PMID: CN-02279622. Exclusion Code: X5.
88 NCT. Promoting healthy families: a canadian evaluation. Cochrane. 2021 PMID: CN-02217430. Exclusion Code: X10.
89 NCT. The effectiveness and underlying mechanisms of parent management training and mindful parenting program. Cochrane. 2021 PMID: CN-02278530. Exclusion Code: X3.
90 Netherlands Trial Register. Including manualized components in home visitation to reduce risk for child maltreatment. Cochrane. 2019 PMID: CN-01972016. Exclusion Code: X7.
91 Nojiri J, Yanagawa T. Effects of the stepping stones triple p for mothers of pre-school children with suspected autistic spectrum disorder. Journal Public Health. 2019;66(5):237–45. doi: 10.11236/jph.66.5_237. PMID: CN-01951619. Exclusion Code: X9.
92 Netherlands Trial Register. Changing chaos. 2017. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01885497/full Exclusion Code: X10.
93 N’zi AM, Stevens ML, Eyberg SM. Child Directed Interaction Training for young children in kinship care: a pilot study. Child Abuse Negl. 2016;55:81–91. doi: 10.1016/j.chiabu.2016.03.001. PMID: CN-01153180. Exclusion Code: X5.27012997
94 Oxford ML, Spieker SJ, Lohr MJ, . Promoting First Relationships®. Child Maltreat. 2016;21(4):267–77. doi: 10.1177/1077559516668274. PMID: CN-02111214. Exclusion Code: X2.27646148
95 Parra-Cardona JR, Bybee D, Sullivan CM, . Examining the impact of differential cultural adaptation with Latina/o immigrants exposed to adapted parent training interventions. J Consult Clin Psychol. 2017;85(1):58–71. doi: 10.1037/ccp0000160. PMID: CN-01306713. Exclusion Code: X5.28045288
96 Sandler I, Gunn H, Mazza G, . Effects of a program to promote high quality parenting by divorced and separated fathers. Prev Sci. 2018;19(4):538–48. doi: 10.1007/s11121-017-0841-x. PMID: CN-01789523. Exclusion Code: X5.28913663
97 Scavenius C, Chacko A, Lindberg MR, . Parent management training oregon model and family-based services as usual for behavioral problems in youth: a national randomized controlled trial in denmark. Child Psychiatry Hum Dev. 2020;51(5):839–52. doi: 10.1007/s10578-020-01028-y. PMID: CN-02143331. Exclusion Code: X5.32705460
98 Serravalle L, Iacono V, Wilson AL, . Improved parent-child interactions predict reduced internalizing symptoms among the offspring of parents with bipolar disorder undergoing a prevention program: a proof-of-concept study. Research on child and adolescent psychopathology. 2021doi: 10.1007/s10802-020-00743-3. PMID: CN-02247796. Exclusion Code: X5.
99 Shinn M, Brown SR, Gubits D. Can housing and service interventions reduce family separations for families who experience homelessness? Am J Community Psychol. 2017;60(1–2):79–90. doi: 10.1002/ajcp.12111. PMID: CN-01604784. Exclusion Code: X5.28012168
100 Steen JA, Burg MA. Parental attitudes following exposure to child abuse prevention campaign materials: a randomized trial. J. Public Child Welf. 2019;13(1):18–34. doi: 10.1080/15548732.2018.1462751. PMID: CN-02115914. Exclusion Code: X3.
101 Tobon AL, Condon E, Holland M, . Lasting Effects of Minding the Baby® home visiting program for young families. J Am Acad Child Adolesc Psychiatry. 2018;57(10):S159-. doi: 10.1016/j.jaac.2018.09.090. PMID: CN-01654978. Exclusion Code: X5.
102 Tomfohr-Madsen LM, Giesbrecht G, Madsen JW, . Improved child mental health following brief relationship enhancement and co-parenting interventions during the transition to parenthood. Int J Environ Res Public Health. 2020;17(3)doi: 10.3390/ijerph17030766. PMID: CN-02084991. Exclusion Code: X5.
103 Verano De Oliveira J, Constantino Miguel E, Chiesa AM, . Maternal ADHD symptoms and infants temperament predict maternal stress and childhood maltreatment during the first year of life. SAGE. 2019;11(1):S85-. doi: 10.1007/s12402-019-00295-7. PMID: CN-01942917. Exclusion Code: X1.
104 Walsh KE, Bacic J, Phillips BD, . Misuse of pediatric medications and parent-physician communication: an interactive voice response intervention. J Patient Saf. 2021;17(3):e207. doi: 10.1097/PTS.0000000000000375. PMID: CN-02308378. Exclusion Code: X5.28333698
105 Williams CM, Cprek S, Asaolu I, . Kentucky Health Access Nurturing Development Services Home Visiting Program Improves Maternal and Child Health. Matern Child Health J. 2017 May;21(5):1166–74. doi: 10.1007/s10995-016-2215-6. PMID: 28093688. Exclusion Code: X7.28093688
106 Weisleder A, Cates CB, Dreyer BP, . Promotion of positive parenting and prevention of socioemotional disparities. Pediatrics. 2016 Feb;137(2):e20153239. doi: 10.1542/peds.2015-3239. PMID: 26817934. Exclusion Code: X5.26817934
107 Schilling S, French B, Berkowitz SJ, . Child-Adult Relationship Enhancement in Primary Care (PriCARE): a randomized trial of a parent training for child behavior problems. Acad Pediatr. 2017 Jan–Feb;17(1):53–60. doi: 10.1016/j.acap.2016.06.009. PMID: 27353449. Exclusion Code: X5.27353449
108 Pruett MK, Cowan PA, Cowan CP, . Supporting father involvement: an intervention with community and child welfare–referred couples. Fam Relat. 2019;68(1):51–67. doi: 10.1111/fare.12352. Exclusion Code: X5.
109 Özyurt G, Dinsever Ç, Çaliskan Z, . Can positive parenting program (Triple P) be useful to prevent child maltreatment? Indian J Psychiatry. 2018 Jul–Sep;60(3):286–91. doi: 10.4103/psychiatry.IndianJPsychiatry_92_17. PMID: 30405253. Exclusion Code: X7.30405253
110 López CM, Davidson TM, Moreland AD. Reaching Latino families through pediatric primary care: Outcomes of the CANNE parent training program. Child Fam Behav Ther. 2018;40(1):26–39. doi: 10.1080/07317107.2018.1428054. PMID: 31485097. Exclusion Code: X7.31485097
111 Haskett ME, Okoniewski KC, Armstrong JM, . Feasibility, acceptability, and effects of a peer support group to prevent child maltreatment among parents experiencing homelessness. Child Youth Serv. 2017 Feb;73:187–96. doi: 10.1016/j.childyouth.2016.12.012. Exclusion Code: X5.
112 Durrant J, Plateau DP, Ateah CA, . Parents’ views of the relevance of a violence prevention program in high, medium, and low human development contexts. Int J Behav Dev. 2017 2017/07/01;41(4):523–31. doi: 10.1177/0165025416687415. Exclusion Code: X7.
113 Chacko A, Fabiano GA, Doctoroff GL, . Engaging fathers in effective parenting for preschool children using shared book reading: a randomized controlled trial. J Clin Child Adolesc Psychol. 2018 Jan–Feb;47(1):79–93. doi: 10.1080/15374416.2016.1266648. PMID: 28103110. Exclusion Code: X5.28103110
114 Cates CB, Weisleder A, Dreyer BP, . Leveraging healthcare to promote responsive parenting: impacts of the video interaction project on parenting stress. J Child Fam Stud. 2016 Mar 1;25(3):827–35. doi: 10.1007/s10826-015-0267-7. PMID: 27134514. Exclusion Code: X5.27134514
115 Breitenstein SM, Fogg L, Ocampo EV, . Parent use and efficacy of a self-administered, tablet-based parent training intervention: a randomized controlled trial. JMIR Mhealth Uhealth. 2016 Apr 20;4(2):e36. doi: 10.2196/mhealth.5202. PMID: 27098111. Exclusion Code: X5.27098111
116 Álvarez M, Rodrigo MJ, Byrne S. What implementation components predict positive outcomes in a parenting program? SAGE. 2016 2018/02/01;28(2):173–87. doi: 10.1177/1049731516640903. Exclusion Code: X5.
117 Álvarez M, Padilla S, Máiquez ML. Home and group-based implementation of the “Growing Up Happily in the Family” program in at-risk psychosocial contexts. Psychosoc Interv. 2016 1 Aug;25(2):69–78. doi: 10.1016/j.psi.2016.03.006. Exclusion Code: X5.
118 Ivanova MY, Hall A, Weinberger S, . The Vermont Family Based Approach in Primary Care Pediatrics: effects on Children’s and Parents’ Emotional and Behavioral Problems and Parents’ Health-Related Quality of Life. Child Psychiatry Hum Dev. 2022doi: 10.1007/s10578-022-01329-4. PMID: CN-02393155. Exclusion Code: X5.
119 McConnell MA, Rokicki S, Ayers S, . Effect of an Intensive Nurse Home Visiting Program on Adverse Birth Outcomes in a Medicaid-Eligible Population: a Randomized Clinical Trial. JAMA. 2022;328(1):27–37. doi: 10.1001/jama.2022.9703. PMID: CN-02420789. Exclusion Code: X5.35788794
120 NCT. New Parent Support Program Evaluation. https://clinicaltrials.gov/show/NCT05236192. 2022 PMID: CN-02381488. Exclusion Code: X10.
121 NCT. Child-Adult Relationship Enhancement in Primary Care (PriCARE) / Criando Niños Con CARIÑO (CARIÑO). https://clinicaltrials.gov/show/NCT05233150. 2022 PMID: CN-02367600. Exclusion Code: X10.
122 Nct. RISE With Veteran Service Providers. https://clinicaltrials.gov/show/NCT05490004. 2022 PMID: CN-02471166. Exclusion Code: X10.
123 Nct. An Intervention to Enhance Well-Being in Trauma Exposed New Mothers. https://clinicaltrials.gov/show/NCT05474534. 2022 PMID: CN-02431267. Exclusion Code: X5.
124 NCT. The Oklahoma Parent-Child Assistance Program. https://clinicaltrials.gov/show/NCT05534568. 2022 PMID: CN-02458755. Exclusion Code: X10.
125 Nct. Prevent It 2.0/GPP -iCBT to Reduce the Risk of Committing Child Sexual Abuse. https://clinicaltrials.gov/show/NCT05663047. 2022 PMID: CN-02508664. Exclusion Code: X5.
126 Nct. Engaging Male Caregivers in Effective Prevention Programming to Reduce Risk of Violence and Violence-Related Injury. https://clinicaltrials.gov/show/NCT05285267. 2022 PMID: CN-02391397. Exclusion Code: X5.
127 Reis O, Hassler F, Daubmann A, . Knowledge hardly translates to reality—A randomized controlled trial on sexual abuse prevention for girls with intellectual disabilities. Frontiers in psychiatry. 2022;13doi: 10.3389/fpsyt.2022.886463. PMID: CN-02426013. Exclusion Code: X5.
128 Rheinheimer N, Beijers R, Bruinhof N, . Effects of daily full-term infant skin-to-skin contact on behavior and cognition at age three - secondary outcomes of a randomized controlled trial. J Child Psychol Psychiatry. 2023;64(1):136–44. doi: 10.1111/jcpp.13679. PMID: CN-02453819. Exclusion Code: X5.35942886
129 Slack KS, Berger LM, Reilly A, . Preventing child protective services system involvement by asking families what they need: findings from a multi-site RCT of the community response program (CRP). Child Youth Serv. 2022;141doi: 10.1016/j.childyouth.2022.106569. PMID: CN-02492872. Exclusion Code: X2.
130 Sourander A, Ristkari T, Kurki M, . Effectiveness of an Internet-Based and Telephone-Assisted Training for Parents of 4-Year-Old Children With Disruptive Behavior: implementation Research. J Med Internet Res. 2022;24(4):e27900. doi: 10.2196/27900. PMID: CN-02388653. Exclusion Code: X5.35377332
131 Uccellini O, Benlodi A, Caroppo E, . 1000 Days: the “WeCare Generation” Program—The Ultimate Model for Improving Human Mental Health and Economics: the Study Protocol. Int J Environ Res Public Health. 2022;19(24)doi: 10.3390/ijerph192416741. PMID: CN-02510652. Exclusion Code: X10.
132 Tandon M, Jonson-Reid M, Constantino JN. Documenting opportunity for systematic identification and mitigation of risk for child maltreatment. J Am Acad Child Adolesc Psychiatry. 2022 Nov;61(11):1313–6. doi: 10.1016/j.jaac.2022.05.008. PMID: 35690303. Exclusion Code: X10.35690303
133 Galano MM, Stein SF, Clark HM, . Eight-year trajectories of behavior problems and resilience in children exposed to early-life intimate partner violence: The overlapping and distinct effects of individual factors, maternal characteristics, and early intervention. Dev Psychopathol. 2022 Mar 14:1–13. doi: 10.1017/s0954579422000104. PMID: 35285428. Exclusion Code: X5.35285428
134 Kawahara T, Doi S, Isumi A, . Interventions to change parental parenting behaviour to reduce unintentional childhood injury: a randomised controlled trial. Inj Prev. 2022 Nov 11doi: 10.1136/ip-2022-044721. PMID: 36368911. Exclusion Code: X5.36368911
135 Londono Tobon A, Condon E, Sadler LS, . School age effects of Minding the Baby-An attachment-based home-visiting intervention-On parenting and child behaviors. Dev Psychopathol. 2022 Feb;34(1):55–67. doi: 10.1017/s0954579420000905. PMID: 32907642. Exclusion Code: X5.32907642
136 Ribaudo J, Lawler JM, Jester JM, . Maternal History of Adverse Experiences and Posttraumatic Stress Disorder Symptoms Impact Toddlers’ Early Socioemotional Wellbeing: The Benefits of Infant Mental Health-Home Visiting. Front Psychol. 2021;12:792989. doi: 10.3389/fpsyg.2021.792989. PMID: 35111107. Exclusion Code: X5.35111107
137 Silovsky J, Bard D, Owora AH, . Risk and Protective Factors Associated with Adverse Childhood Experiences in Vulnerable Families: Results of a Randomized Clinical Trial of SafeCare®. Child Maltreat. 2022 May 16:10775595221100723. doi: 10.1177/10775595221100723. PMID: 35576407. Exclusion Code: X5.35576407
138 Tobe H, Sakka M, Kita S, . The Efficacy of a Resilience-Enhancement Program for Mothers Based on Emotion Regulation: A Randomized Controlled Trial in Japan. Int J Environ Res Public Health. 2022 Nov 13;19(22)doi: 10.3390/ijerph192214953. PMID: 36429671. Exclusion Code: X5.36429671
139 NCT04294134. MIO-CPP to Improve the Well-being, Permanency, and Safety Outcomes for Young Children at Risk of or in Out-of-home Placement in Philadelphia and Bucks Counties, and Affected by Maternal Substance Use. 2020. Exclusion Code: X10.
140 Health N. Northwell Health Visits: A Family Connects Pilot Implementation at Northwell Health. https://ClinicalTrials.gov/show/NCT03887910; 2019. Exclusion Code: X10.
141 Zolotor AJ, Runyan DK, Dunne MP, . ISPCAN Child Abuse Screening Tool Children’s Version (ICAST-C): Instrument development and multi-national pilot testing. Child Abuse Negl. 2009 2009/11/01/;33(11):833–41. doi: 10.1016/j.chiabu.2009.09.004. Exclusion Code: X5.19857897
142 Fortson B, Klevens J, Merrick M, . Child Abuse and Neglect Prevention Resource for Action: A Compilation of the Best Available Evidence National Center for Injury Prevention and Control, Centers for Disease Control and Prevention. 2016. https://www.cdc.gov/violenceprevention/pdf/CAN-Prevention-Resource_508.pdf Exclusion Code: X5.
143 Harper Browne C. The Strengthening Families Approach and Protective Factors Framework: Branching Out and Reaching Deeper Center for the Study of Social Policy. 2014. https://www.cssp.org/reform/strengtheningfamilies/2014/The-Strengthening-Families-Approach-and-Protective-Factors-Framework_Branching-Out-and-Reaching-Deeper.pdf Exclusion Code: X5.
144 Garg A, Toy S, Tripodis Y, . Addressing social determinants of health at well child care visits: a cluster RCT. Pediatrics. 2015 Feb;135(2):e296–304. doi: 10.1542/peds.2014-2888. PMID: 25560448. Exclusion Code: X5.25560448
145 Arbour M, Fico P, Atwood S, . Benefits of a Universal Intervention in Pediatric Medical Homes to Identify and Address Health-Related Social Needs: An Observational Cohort Study. Acad Pediatr. 2022 Nov–Dec;22(8):1328–37. doi: 10.1016/j.acap.2022.06.013. PMID: 35863734. Exclusion Code: X7.35863734
146 Arbour MC, Floyd B, Morton S, . Cross-Sector Approach Expands Screening and Addresses Health-Related Social Needs in Primary Care. Pediatrics. 2021 Nov;148(5)doi: 10.1542/peds.2021-050152. PMID: 34706903. Exclusion Code: X7.34706903