# Appendix B Detailed Methods

## Appendix B1 Search Strategies

### PubMed KQs Search, 1/03/2022

SRs = 516; 516 imported

RCTs = 822; 822 imported

Cohort and Case-Control = 2,410; 2,294 imported

Search number | Query | Filters | Results
1 | “Adverse Childhood Experiences”[Mesh] OR “Child, Abandoned”[Mesh] OR “Child Abuse”[Mesh] OR (“Craniocerebral Trauma”[Mesh] AND (abus*[tw] OR neglect*[tw] OR maltreat*[tw])) OR “Domestic Violence”[Mesh] OR (“Fractures, Bone”[Mesh] AND (abus*[tw] OR neglect*[tw] OR maltreat*[tw])) OR “Shaken Baby Syndrome”[Mesh] OR “child abuse”[All Fields] OR “child maltreatment”[All Fields] OR “infant abuse”[Title/Abstract] | | 57,992
2 | ((infant*[tw] OR “child*”[tw]) AND “abus*”[tw]) OR ((infant*[tw] OR child*[tw]) AND maltreat*[tw]) OR (child*[tw] AND neglect*[tw]) OR (domestic[tw] AND violen*[tw]) OR “emotional abuse”[tw] OR internaliz*[tw] OR (“shaken baby”[tw] AND syndrome[tw]) NOT Medline[subset] | | 13,339
3 | #1 OR #2 | | 69,548
4 | #1 OR #2 | English | 65,447
5 | #4 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) | | 65,277
6 | #4 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) | Child: birth-18 years | 38,192
7 | (adolescen*[tw] OR boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR girls[tw] OR infant*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR teen[tw] OR teens[tw] OR teenage*[tw]) NOT Medline[subset] | | 250,414
8 | #5 AND #7 | | 7,373
9 | #6 OR #8 | | 45,549
10 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] | | 4,432,828
11 | #9 NOT #10 | | 38,989
12 | #11 AND (“2016/06/18”[Date - Publication] : “3000”[Date - Publication]) | | 12,656
13 | “randomized controlled trial”[pt] OR “controlled clinical trial”[pt] OR randomized[tiab] OR placebo[tiab] OR “drug therapy”[sh] OR randomly[tiab] OR trial[tiab] | | 3,553,160
14 | #12 AND #13 | | 822
15 | “Cohort Studies”[Mesh] OR “Prospective Studies”[Mesh] OR cohort OR “Case-Control Studies”[Mesh] OR “case control”[tiab] | | 2,846,324
16 | #12 AND #15 | | 2,410
17 | “Systematic Review”[pt] OR (“Review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“Review Literature as Topic”[MeSH] AND “systematic”[tiab]) OR “Meta-analysis”[Publication Type] OR “Meta-analysis As Topic”[MeSH Terms] OR “Systematic Reviews as Topic”[Mesh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Umbrella Review”[tiab] | | 409,517
18 | #12 AND #17 | | 620
19 | #18 NOT (#14 OR #16) | | 516

### PubMed CQ 1 Search, 1/03/2022

Systematic Reviews = 9; 6 imported

Trials = 31; 20 imported

Cohort studies = 80, 43 imported

Everything Else (recommend to also review) = 231, 231 imported

Search number | Query | Filters | Results
1 | “Adverse Childhood Experiences”[Mesh] OR “Child, Abandoned”[Mesh] OR “Child Abuse”[Mesh] OR (“Craniocerebral Trauma”[Mesh] AND (abus*[tw] OR neglect*[tw] OR maltreat*[tw])) OR “Domestic Violence”[Mesh] OR (“Fractures, Bone”[Mesh] AND (abus*[tw] OR neglect*[tw] OR maltreat*[tw])) OR “Shaken Baby Syndrome”[Mesh] OR “child abuse”[All Fields] OR “child maltreatment”[All Fields] OR “infant abuse”[Title/Abstract] | | 58,008
2 | ((infant*[tw] OR “child*”[tw]) AND “abus*”[tw) OR ((infant*[tw] OR child*[tw]) AND maltreat*[tw]) OR (child*[tw] AND neglect*[tw]) OR (domestic[tw] AND violen*[tw]) OR “emotional abuse”[tw] OR internaliz*[tw] OR (“shaken baby”[tw] AND syndrome[tw) NOT Medline[subset] | | 13,383
3 | #1 OR #2 | | 69,597
4 | #1 OR #2 | English | 65,494
5 | #4 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) | | 65,319
6 | #4 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) | Child: birth-18 years | 38,216
7 | (adolescen*[tw] OR boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR girls[tw] OR infant*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR teen[tw] OR teens[tw] OR teenage*[tw]) NOT Medline[subset] | | 251,294
8 | #5 AND #7 | | 7,396
9 | #6 OR #8 | | 45,572
10 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “dictionary”[pt] OR “festschrift”[pt] OR “periodical index”[pt] | | 235,172
11 | #9 NOT #10 | | 45,404
12 | (“epidemiology”[MeSH Subheading] OR “epidemiology”[All Fields] OR “surveillance”[All Fields] OR “epidemiology”[MeSH Terms] OR “surveilance”[All Fields] OR “surveillances”[All Fields] OR “surveilled”[All Fields] OR “surveillance”[All Fields]) AND (“effect”[All Fields] OR “effecting”[All Fields] OR “effective”[All Fields] OR “effectively”[All Fields] OR “effectiveness”[All Fields] OR “effectivenesses”[All Fields] OR “effectives”[All Fields] OR “effectivities”[All Fields] OR “effectivity”[All Fields] OR “effects”[All Fields]) | | 924,173
13 | #11 AND #12 | | 2,761
14 | Acculturation[Mesh:no exp] OR “Racial Groups”[Mesh] OR “Cross-Cultural Comparison”[Mesh:no exp] OR “Cultural Characteristics”[Mesh:no exp] OR “Cultural Diversity”[Mesh:no exp] OR “Emigrants and Immigrants”[Mesh] OR “Ethnic Groups”[Mesh] OR “Health Equity”[Mesh:no exp] OR “Health Status Disparities”[Mesh:no exp] OR “Minority groups”[Mesh:no exp] OR “Minority health”[Mesh:no exp] OR Prejudice[Mesh:no exp] OR “Psychosocial Deprivation”[Mesh:no exp] OR “Race Relations”[Mesh] OR Racism[Mesh:no exp] OR Refugees[Mesh:no exp] OR “Social determinants of Health”[Mesh:no exp] OR “Social Discrimination”[Mesh:no exp] OR “Transients and Migrants”[Mesh:no exp] OR Xenophobia[Mesh:no exp] | | 373,831
15 | aboriginal[tw] OR caucasian*[tw] OR deprivation[tw] OR disparit*[tw] OR “english as a second language”[tw] OR equity[tw] OR ethnic*[tw] OR ethnology[tw] OR “first nation*”[tw] OR “foreign language”[tw] OR “health*care disparit*”[tw] OR “health care disparit*”[tw] OR “health status disparit*”[tw] OR “health disparit*”[tw] OR “health inequalit*”[tw] OR “health inequit*”[tw] OR hispanic*[tw] OR indigenous[tw] OR inequalit*[tw] OR inequit*[tw] OR inuit[tw] OR “language other than”[tw] OR “migration background”[tw] OR latina*[tw] OR latino*[tw] OR latinx[tw] OR “medically underserved”[tw] OR minorit*[tw] OR “native american”[tw] OR non-English[tw] OR non-white[tw] OR race[tw] OR racial[tw] OR racism[tw] OR “social determinants”[tw] OR “Torres Strait Islander”[tw] OR whites[tw] | | 834,186
16 | #15 NOT Medline[subset] | | 90,017
17 | “disproportionalities”[All Fields] OR “disproportionality”[All Fields] OR ((disparate OR disparity OR disparities) AND (race OR racial OR racism OR ethnic*)) | | 39,691
18 | #14 OR #16 OR #17 | | 472,808
19 | #13 AND #18 | | 341
20 | “Systematic Review”[pt] OR systematic[subset] OR (“Review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“Review Literature as Topic”[MeSH] AND “systematic”[tiab]) OR “Meta-analysis”[Publication Type] OR “Meta-analysis As Topic”[MeSH Terms] OR “Systematic Reviews as Topic”[Mesh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Umbrella Review”[tiab] | | 410,347
21 | #19 AND #20 | | 9
22 | randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized [tiab] OR placebo [tiab] OR drug therapy [sh] OR randomly [tiab] OR trial [tiab] | | 3,554,571
23 | #19 AND #22 | | 31
24 | “Cohort Studies”[Mesh] OR “Prospective Studies”[Mesh] OR cohort | | 2,588,761
25 | #19 AND #24 | | 80
26 | #19 NOT (#21 OR #23 OR #25) | | 231

### PubMed CQ 2 Search, 1/03/2022

SRs + MAs = 9; 0 imported

Everything else = 145; 97 imported

Search number | Query | Filters | Results
1 | “Adverse Childhood Experiences”[Mesh] OR “Child, Abandoned”[Mesh] OR “Child Abuse”[Mesh] OR (“Craniocerebral Trauma”[Mesh] AND (abus*[tw] OR neglect*[tw] OR maltreat*[tw])) OR “Domestic Violence”[Mesh] OR (“Fractures, Bone”[Mesh] AND (abus*[tw] OR neglect*[tw] OR maltreat*[tw])) OR “Shaken Baby Syndrome”[Mesh] OR “child abuse”[All Fields] OR “child maltreatment”[All Fields] OR “infant abuse”[Title/Abstract] | | 58,008
2 | ((infant*[tw] OR “child*”[tw]) AND “abus*”[tw) OR ((infant*[tw] OR child*[tw]) AND maltreat*[tw]) OR (child*[tw] AND neglect*[tw]) OR (domestic[tw] AND violen*[tw]) OR “emotional abuse”[tw] OR internaliz*[tw] OR (“shaken baby”[tw] AND syndrome[tw) NOT Medline[subset] | | 13,383
3 | #1 OR #2 | | 69,597
4 | #1 OR #2 | English | 65,494
5 | #4 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) | | 65,319
6 | #4 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) | Child: birth-18 years | 38,216
7 | (adolescen*[tw] OR boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR girls[tw] OR infant*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR teen[tw] OR teens[tw] OR teenage*[tw]) NOT Medline[subset] | | 251,294
8 | #5 AND #7 | | 7,396
9 | #6 OR #8 | | 45,572
10 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “dictionary”[pt] OR “festschrift”[pt] OR “periodical index”[pt] | | 235,172
11 | #9 NOT #10 | | 45,404
12 | “BabyFirst Screen”[All Fields] OR “Brief Infant-Toddler Social and Emotional Assessment”[All Fields] OR BITSEA[All Fields] OR “Brisbane Evaluation of Needs Questionnaire”[All Fields] OR “Child Abuse Potential Inventory”[All Fields] OR “Kempe Family Stress Checklist”[All Fields] OR “Maternal History Interview”[All Fields] OR “MHI-2”[All Fields] OR “Parent Risk Questionnaire”[All Fields] OR “Parent Screening Questionnaire”[All Fields] | | 173
13 | “Child Abuse and Trauma Scale”[All Fields] OR “Child Dissociative Checklist”[All Fields] OR “Childhood Trauma Questionnaire”[All Fields] OR “Emotional Abuse Subscale”[All Fields] OR “Problem Oriented Screening Instrument for Teenagers”[All Fields] OR “Protective Factors Survey”[All Fields] OR “Trauma Symptoms Checklist for Children”[All Fields] | | 1,517
14 | “Actuarial Risk Assessment Instrument Youth”[All Fields] OR “Brief CAPI”[All Fields] OR “California Family Assessment Factor Analysis”[All Fields] OR “California Family Risk Assessment”[All Fields] OR “CANTS 17B” [All Fields] OR “CAPI shortened version” [All Fields] OR “CFRA Abuse Scale” [All Fields] OR “CFRA Neglect Scale” [All Fields] OR “CFRA with possibility to overrule”[All Fields] OR “Check List of Child Safety” [All Fields] OR “Child Abuse Potential Inventory”[All Fields] OR “Child Abuse Risk Evaluation” [All Fields] OR “Colorado Family Risk Assessment” [All Fields] OR “Connecticut Risk Assessment”[All Fields] OR “Detection of Unsafety in Families” [All Fields] OR “Family Psychosocial Risk Inventory” [All Fields] OR “Family Stress Checklist” [All Fields] OR (Flaherty[tw] AND “neural network model”[All Fields]) OR (Flaherty[tw] AND “regression model”[tiab]) OR Horikawa[tw] OR “Instrument for Early Identification of Parents At Risk for Child Abuse and Neglect”[All Fields] OR Lealman[tw] OR “Maternal History Interview”[All Fields] OR “Minnesota Family Risk Assessment”[All Fields] OR “NCCD Risk Assessment Tools”[All Fields] OR “Screening Checklist for Risk of Referral”[All Fields] OR “Structured Problem Analysis of Raising Kids”[All Fields] OR (Vaithianathan[tw] AND “Predictive Risk Model”[All Fields]) | | 113
15 | #12 OR #13 OR #14 | | 1,718
16 | (“Risk Assessment”[Mesh] OR “risk assessment” OR “risk tool” OR “risk measure” OR “risk evaluat*” OR “risk analys*” OR “screen*”) AND (“AUC” OR “ROC” OR “sensitivity” OR “specificity” OR “predictive validity” OR “predictive accuracy”) | | 177,923
17 | (“Sensitivity and Specificity”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Reproducibility of Results”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “predictive value”[tw] OR sensitivity[tw] OR specificity[tw] OR accuracy[tw] OR ROC[tw] OR reproducib*[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw] OR reliability[tw] OR validity[tw]) | | 2,941,908
18 | #16 OR #17 | | 2,945,797
19 | #11 AND #15 AND #18 | | 177
20 | #11 AND #16 | | 237
21 | #19 OR #20 | | 403
22 | #21 AND (“2016/06/18”[Date - Publication] : “3000”[Date - Publication]) | | 154
23 | “Systematic Review”[pt] OR systematic[subset] OR (“Review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“Review Literature as Topic”[MeSH] AND “systematic”[tiab]) OR “Meta-analysis”[Publication Type] OR “Meta-analysis As Topic”[MeSH Terms] OR “Systematic Reviews as Topic”[Mesh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Umbrella Review”[tiab] | | 410,374
24 | #22 AND #23 | | 9
25 | #22 NOT #24 | | 145

### Health and Psychosocial Instruments (HaPI), EBSCOhost, 12/17/2022

Used to identify potentially relevant/new risk assessment tools and saved in EndNote for team to review:

33 results, 33 imported

Friday, December 17, 2021

# | Query | Limiters/Expanders | Results
S1 | “Child, Abandoned” OR “Child Abuse” OR “Domestic Violence” OR “Shaken Baby Syndrome” OR “emotional abuse” OR (“child*” AND “abuse”) OR “child abuse” OR (child* AND (maltreat* OR maltreatment)) OR “child maltreatment” OR (child* AND neglect*) OR (domestic AND violen*) OR (“shaken baby” AND syndrome) | Expanders - Apply equivalent subjects; Limiters - Publication Date: 2016-2020 | 4975
S2 | “Child, Abandoned” OR “Child Abuse” OR “Domestic Violence” OR “Shaken Baby Syndrome” OR “emotional abuse” OR (“child*” AND “abuse”) OR “child abuse” OR (child* AND (maltreat* OR maltreatment)) OR “child maltreatment” OR (child* AND neglect*) OR (domestic AND violen*) OR (“shaken baby” AND syndrome) | Limiters - Publication Date: 2016-2020 | 250
S3 | “Child, Abandoned” OR “Child Abuse” OR “Domestic Violence” OR “Shaken Baby Syndrome” OR “emotional abuse” OR (“child*” AND “abuse”) OR “child abuse” OR (child* AND (maltreat* OR maltreatment)) OR “child maltreatment” OR (child* AND neglect*) OR (domestic AND violen*) OR (“shaken baby” AND syndrome) | Limiters - Publication Date: 2016-2020; Expanders - Apply equivalent subjects; Narrow by Language: - English | 157
S4 | validity OR reliability | Expanders - Apply equivalent subjects | 19,852
S5 | S3 AND S4 | | 33

### Cochrane Library KQs Search, 1/6/2022

All results were trials. (1 editorial and 1 clinical answer not saved)

Used SR-Accelerator Polyglot Search module to translate PubMed search to Cochrane Library syntax and reviewed translation for correctness.

Limited the 3,865 trial results by Custom date range (when added to Cochrane Library) of 6/18/2016 – 1/6/2022; and further limited to Custom year range, published between 2016–2022:

Trials = 1695; 1,367 imported

ID | Search | Hits
#1 | [mh “Adverse Childhood Experiences”] OR [mh “Child, Abandoned”] OR [mh “Child Abuse”] OR ([mh “Craniocerebral Trauma”] AND (abus*:ti,ab,kw OR neglect*:ti,ab,kw OR maltreat*:ti,ab,kw)) OR [mh “Domestic Violence”] OR ([mh “Fractures, Bone”] AND (abus*:ti,ab,kw OR neglect*:ti,ab,kw OR maltreat*:ti,ab,kw)) OR [mh “Shaken Baby Syndrome”] OR “child abuse” OR “child maltreatment” OR “infant abuse”:ti,ab | 1644
#2 | ((infant*:ti,ab,kw OR child*:ti,ab,kw) AND; abus*:ti,ab,kw) OR ((infant*:ti,ab,kw OR child*:ti,ab,kw) AND maltreat*:ti,ab,kw) OR (child*:ti,ab,kw AND neglect*:ti,ab,kw) OR (domestic:ti,ab,kw AND violen*:ti,ab,kw) OR “emotional abuse”:ti,ab,kw OR internaliz*:ti,ab,kw OR (“shaken baby”:ti,ab,kw AND syndrome:ti,ab,kw) | 5027
#3 | #1 OR #2 | 5318
#4 | [mh Adolescent] OR [mh Child] OR [mh Infant] | 156845
#5 | #3 AND #4 | 1818
#6 | (adolescen*:ti,ab,kw OR boys:ti,ab,kw OR child:ti,ab,kw OR children:ti,ab,kw OR paediatric*:ti,ab,kw OR pediatric*:ti,ab,kw OR teen:ti,ab,kw OR teenage*:ti,ab,kw OR teens:ti,ab,kw) | 263544
#7 | #3 AND #6 | 3989
#8 | #5 OR #7 | 4012
#9 | address:pt OR autobiography:pt OR bibliography:pt OR biography:pt OR “case report”:ti,ab,kw OR “case reports”:ti,ab,kw OR “case series”:ti,ab,kw OR comment:pt OR “comment on” OR congress:pt OR dictionary:pt OR directory:pt OR editorial:pt OR festschrift:pt OR “historical article”:pt OR interview:pt OR lecture:pt OR “legal case”:pt OR legislation:pt OR news:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt | 31971
#10 | #8 NOT #9 | 3867
#11 | #10 Limited to Custom date range (added to Cochrane Library) between June 18, 2016 - January 6, 2022; Also further limited to Custom year range (publication year) between 2016 - 2022 | 1695

### Cochrane Library CQ 1 Search, 1/7/2022

Used SR-Accelerator Polyglot Search module to translate PubMed search to Cochrane Library syntax and reviewed translation for correctness.

Limited the results by Custom date range (when added to Cochrane Library) of 6/18/2016 – 1/6/2022; and further limited to Custom year range, published between 2016–2022

All results after date limit are trials.

Trials = 247; 3 imported

ID | Search | Hits
#1 | [mh “Adverse Childhood Experiences”] OR [mh “Child, Abandoned”] OR [mh “Child Abuse”] OR ([mh “Craniocerebral Trauma”] AND (abus*:ti,ab,kw OR neglect*:ti,ab,kw OR maltreat*:ti,ab,kw)) OR [mh “Domestic Violence”] OR ([mh “Fractures, Bone”] AND (abus*:ti,ab,kw OR neglect*:ti,ab,kw OR maltreat*:ti,ab,kw)) OR [mh “Shaken Baby Syndrome”] OR “child abuse” OR “child maltreatment” OR “infant abuse”:ti,ab | 1644
#2 | ((infant*:ti,ab,kw OR child*:ti,ab,kw) AND abus*:ti,ab,kw) OR ((infant*:ti,ab,kw OR child*:ti,ab,kw) AND maltreat*:ti,ab,kw) OR (child*:ti,ab,kw AND neglect*:ti,ab,kw) OR (domestic:ti,ab,kw AND violen*:ti,ab,kw) OR “emotional abuse”:ti,ab,kw OR internaliz*:ti,ab,kw OR (“shaken baby”:ti,ab,kw AND syndrome:ti,ab,kw) | 5027
#3 | #1 OR #2 | 5318
#4 | [mh Adolescent] OR [mh Child] OR [mh Infant] | 156845
#5 | #3 AND #4 | 1818
#6 | (adolescen*:ti,ab,kw OR boys:ti,ab,kw OR child:ti,ab,kw OR children:ti,ab,kw OR paediatric*:ti,ab,kw OR pediatric*:ti,ab,kw OR teen:ti,ab,kw OR teenage*:ti,ab,kw OR teens:ti,ab,kw) | 263544
#7 | #3 AND #6 | 3989
#8 | #5 OR #7 | 4012
#9 | address:pt OR autobiography:pt OR bibliography:pt OR biography:pt OR dictionary:pt OR festschrift:pt OR “periodical index”:pt | 37
#10 | #8 NOT #9 | 4012
#11 | (epidemiology OR surveillance OR [mh epidemiology] OR surveilance OR surveillances OR surveilled OR surveillance) AND (effect OR effecting OR effective OR effectively OR effectiveness OR effectivenesses OR effectives OR effectivities OR effectivity OR effects) | 48298
#12 | #10 AND #11 | 290
#13 | [mh ^Acculturation] OR [mh “Racial Groups”] OR [mh ^“Cross-Cultural Comparison”] OR [mh ^“Cultural Characteristics”] OR [mh ^“Cultural Diversity”] OR [mh “Emigrants and Immigrants”] OR [mh “Ethnic Groups”] OR [mh ^“Health Equity”] OR [mh ^“Health Status Disparities”] OR [mh ^“Minority groups”] OR [mh ^“Minority health”] OR [mh ^Prejudice] OR [mh ^“Psychosocial Deprivation”] OR [mh “Race Relations”] OR [mh ^Racism] OR [mh ^Refugees] OR [mh ^“Social determinants of Health”] OR [mh ^“Social Discrimination”] OR [mh ^“Transients and Migrants”] OR [mh ^Xenophobia] | 5972
#14 | (aboriginal:ti,ab,kw OR caucasian*:ti,ab,kw OR deprivation:ti,ab,kw OR disparit*:ti,ab,kw OR “english as a second language”:ti,ab,kw OR equity:ti,ab,kw OR ethnic*:ti,ab,kw OR ethnology:ti,ab,kw OR (“first” NEXT nation*):ti,ab,kw OR “foreign language”:ti,ab,kw OR (health*care NEXT disparit*):ti,ab,kw OR (“health care” NEXT disparit*):ti,ab,kw OR (“health status” NEXT disparit*):ti,ab,kw OR (“health” NEXT disparit*):ti,ab,kw OR (“health” NEXT inequalit*):ti,ab,kw OR (“health” NEXT inequit*):ti,ab,kw OR hispanic*:ti,ab,kw OR indigenous:ti,ab,kw OR inequalit*:ti,ab,kw OR inequit*:ti,ab,kw OR inuit:ti,ab,kw OR “language other than”:ti,ab,kw OR “migration background”:ti,ab,kw OR latina*:ti,ab,kw OR latino*:ti,ab,kw OR latinx:ti,ab,kw OR “medically underserved”:ti,ab,kw OR minorit*:ti,ab,kw OR “native american”:ti,ab,kw OR non-English:ti,ab,kw OR non-white:ti,ab,kw OR race:ti,ab,kw OR racial:ti,ab,kw OR racism:ti,ab,kw OR “social determinants”:ti,ab,kw OR “Torres Strait Islander”:ti,ab,kw OR whites:ti,ab,kw) | 47202
#15 | disproportionalities OR disproportionality OR ((disparate OR disparity OR disparities ) AND (race OR racial OR racism OR ethnic* )) | 1755
#16 | #13 OR #14 OR #15 | 48864
#17 | #10 AND #16 | 528
#18 | #17 Limited to Custom date range (added to Cochrane Library) between June 18, 2016 - January 6, 2022; Also further limited to Custom year range (publication year) between 2016 - 2022 | 247

### Cochrane Library CQ 2 Search, 1/7/2022

Used SR-Accelerator Polyglot Search module to translate PubMed search to Cochrane Library syntax and reviewed translation for correctness.

19 results before date limits. Limited the results by Custom date range (when added to Cochrane Library) of 6/18/2016 – 1/6/2022; and further limited to Custom year range, published between 2016–2022:

SRs = 2; 2 imported

Trials = 4; 0 imported

ID | Search | Hits
#1 | [mh “Adverse Childhood Experiences”] OR [mh “Child, Abandoned”] OR [mh “Child Abuse”] OR ([mh “Craniocerebral Trauma”] AND (abus*:ti,ab,kw OR neglect*:ti,ab,kw OR maltreat*:ti,ab,kw)) OR [mh “Domestic Violence”] OR ([mh “Fractures, Bone”] AND (abus*:ti,ab,kw OR neglect*:ti,ab,kw OR maltreat*:ti,ab,kw)) OR [mh “Shaken Baby Syndrome”] OR “child abuse” OR “child maltreatment” OR “infant abuse”:ti,ab | 1644
#2 | ((infant*:ti,ab,kw OR child*:ti,ab,kw) AND abus*:ti,ab,kw) OR ((infant*:ti,ab,kw OR child*:ti,ab,kw) AND maltreat*:ti,ab,kw) OR (child*:ti,ab,kw AND neglect*:ti,ab,kw) OR (domestic:ti,ab,kw AND violen*:ti,ab,kw) OR “emotional abuse”:ti,ab,kw OR internaliz*:ti,ab,kw OR (“shaken baby”:ti,ab,kw AND syndrome:ti,ab,kw) | 5027
#3 | #1 OR #2 | 5318
#4 | [mh Adolescent] OR [mh Child] OR [mh Infant] | 156845
#5 | #3 AND #4 | 1818
#6 | (adolescen*:ti,ab,kw OR boys:ti,ab,kw OR child:ti,ab,kw OR children:ti,ab,kw OR paediatric*:ti,ab,kw OR pediatric*:ti,ab,kw OR teen:ti,ab,kw OR teenage*:ti,ab,kw OR teens:ti,ab,kw) | 263544
#7 | #3 AND #6 | 3989
#8 | #5 OR #7 | 4012
#9 | address:pt OR autobiography:pt OR bibliography:pt OR biography:pt OR dictionary:pt OR festschrift:pt OR “periodical index”:pt | 37
#10 | #8 NOT #9 | 4012
#11 | “BabyFirst Screen” OR “Brief Infant-Toddler Social and Emotional Assessment” OR BITSEA OR “Brisbane Evaluation of Needs Questionnaire” OR “Child Abuse Potential Inventory” OR “Kempe Family Stress Checklist” OR “Maternal History Interview” OR MHI-2 OR “Parent Risk Questionnaire” OR “Parent Screening Questionnaire” | 38
#12 | “Child Abuse and Trauma Scale” OR “Child Dissociative Checklist” OR “Childhood Trauma Questionnaire” OR “Emotional Abuse Subscale” OR “Problem Oriented Screening Instrument for Teenagers” OR “Protective Factors Survey” OR “Trauma Symptoms Checklist for Children” | 92
#13 | “Actuarial Risk Assessment Instrument Youth” OR “Brief CAPI” OR “California Family Assessment Factor Analysis” OR “California Family Risk Assessment” OR “CANTS 17B” OR “CAPI shortened version” OR “CFRA Abuse Scale” OR “CFRA Neglect Scale” OR “CFRA with possibility to overrule” OR “Check List of Child Safety” OR “Child Abuse Potential Inventory” OR “Child Abuse Risk Evaluation” OR “Colorado Family Risk Assessment” OR “Connecticut Risk Assessment” OR “Detection of Unsafety in Families” OR “Family Psychosocial Risk Inventory” OR “Family Stress Checklist” OR (Flaherty:ti,ab,kw AND “neural network model”) OR (Flaherty:ti,ab,kw AND “regression model”:ti,ab) OR Horikawa:ti,ab,kw OR “Instrument for Early Identification of Parents At Risk for Child Abuse and Neglect” OR Lealman:ti,ab,kw OR “Maternal History Interview” OR “Minnesota Family Risk Assessment” OR “NCCD Risk Assessment Tools” OR “Screening Checklist for Risk of Referral” OR “Structured Problem Analysis of Raising Kids” OR (Vaithianathan:ti,ab,kw AND “Predictive Risk Model”) | 18
#14 | #11 OR #12 OR #13 | 133
#15 | ([mh “Risk Assessment”] OR “risk assessment” OR “risk tool” OR “risk measure” OR (“risk” NEXT evaluat*) OR (“risk” NEXT analys*) OR screen* ) AND (AUC OR ROC OR sensitivity OR specificity OR “predictive validity” OR “predictive accuracy” ) | 16442
#16 | ([mh “Sensitivity and Specificity”] OR [mh “Predictive Value of Tests”] OR [mh “ROC Curve”] OR [mh “Reproducibility of Results”] OR [mh “False Negative Reactions”] OR [mh “False Positive Reactions”] OR “predictive value”:ti,ab,kw OR sensitivity:ti,ab,kw OR specificity:ti,ab,kw OR accuracy:ti,ab,kw OR ROC:ti,ab,kw OR reproducib*:ti,ab,kw OR “false positive”:ti,ab,kw OR “false negative”:ti,ab,kw OR “likelihood ratio”:ti,ab,kw OR reliability:ti,ab,kw OR validity:ti,ab,kw) | 118783
#17 | #15 OR #16 | 125980
#18 | #10 AND #14 AND #17 | 19
#19 | #18 Limited to Custom date range (added to Cochrane Library) between June 18, 2016 - January 6, 2022; Also further limited to Custom year range (publication year) between 2016 - 2022 | 6

### Grey Literature Searches, 1/11/2022

ClinicalTrials.gov Advanced Search (https://clinicaltrials.gov/ct/screen/AdvancedSearch), Searched in Condition box (306 results, all 306 saved in EndNote):

AREA[ConditionSearch] ( Abandoned Child OR Adverse Childhood Experiences OR Bone fracture* AND ( abus* OR neglect* OR maltreat* ) OR Child Abuse OR child maltreatment OR EXPAND[Concept] “Craniocerebral Trauma” AND ( abus* OR neglect* OR maltreat* ) OR Domestic Violence OR EXPAND[Concept] “emotional abuse” OR infant abuse OR internaliz* OR “Shaken Baby Syndrome” OR (skull fracture* AND (abus* OR neglect* OR maltreat*)))

WHO International Clinical Trials Registry Platform (https://trialsearch.who.int/AdvSearch.aspx) (WHO ICTRP) Advanced search:

Searched in [underlined: Condition box] (2 searches to accommodate character limit)

For both searches:

Recruitment status: ALL / Search for clinical trials in children

Date of registration: 18/06/2016 – 31/01/2022

[underlined: Search 1]

Abandoned Child OR Adverse Childhood Experiences OR (Bone fracture* AND (abus* OR neglect* OR maltreat*)) OR Child Abuse OR child maltreatment

(65 trials found, 65 imported to EndNote)

[underlined: Search 2]

(Craniocerebral Trauma AND (abus* OR neglect* OR maltreat*)) OR Domestic Violence OR emotional abuse OR infant abuse OR internaliz* OR Shaken Baby Syndrome OR (skull fracture* AND (abus* OR neglect* OR maltreat*))

(30 trials found, 23 imported)

## Appendix B2 Inclusion and Exclusion Criteria

Category | Included | Excluded
Population | Children or adolescents (younger than age 18 years) with no known exposure to maltreatment or specific signs or symptoms of current or past maltreatment | Symptomatic children and adolescents undergoing diagnostic evaluations for conditions related to abuse or neglect (e.g., those presenting with a broken bone or other signs of physical abuse or neglect, or trauma symptoms associated with domestic violence exposure), children with known exposure to child maltreatment and perpetrators of maltreatment, and children of caregivers who perpetrated maltreatment toward them
Interventions | Primary care–based programs or services; services that could result from a referral by a primary care provider; Services may include home-visiting programs, respite care, parent education programs, and family support and family strengthening programs; Services may be implemented by nonclinicians; (Interventions may be directed at the caregiver and may or may not include components directed at the child) | Communitywide interventions such as public awareness campaigns or public service announcements only, without specific interventions linked to clinical settings
Comparisons | Usual care, delayed intervention, active interventions that allow for the assessment of the independent contribution of primary care–relevant preventive intervention (e.g., clinical interventions plus media campaigns vs. media campaigns) | Comparators that do not allow for the assessment of the independent contribution of the effect of primary care–feasible or referable preventive interventions (e.g., clinical interventions plus media campaigns vs. usual care)
Outcomes | KQ 1: Direct or proxy measures of abuse or neglect (required):; - Child protective services reports; - Removal of the child from the home; - Physical abuse, sexual abuse, or emotional abuse perpetrated by a parent or caretaker against a child (not parent-reported); - Physical (e.g., failure to thrive), emotional, dental/medical (for needed dental, medical, or mental health treatment), or educational neglect; - Injuries such as broken bones, bruises, burns, and other injuries with a high specificity for abuse; - Emergency department visits; - Hospitalizations; Mortality^*^; Behavioral, developmental, emotional, mental, or physical health and well-being:^*^; - Quality of life or functional status measures (using validated instruments); - Internalizing behaviors: depression, anxiety; - Externalizing behaviors: disruptive, aggressive, delinquent behavior; - Child development (including school readiness and academic performance): social–emotional (e.g., attachment problems, peer relationships, community involvement), developmental delays (language, cognitive); - Incidence of reactive attachment disorder; - Incidence of disinhibited social engagement disorder; - Incidence of acute stress disorder; - Incidence of posttraumatic stress disorder; - Incidence of traumatic stress symptoms: attachment, self-regulation, under- or overcontrolling behaviors (e.g., irritable/angry outbursts, self-destructive behavior, food hoarding), executive functioning, self-concept, hypervigilance, exaggerated startle response, dissociation, concentration problems, somatic problems (e.g., headaches, gastrointestinal problems), sleep disturbance, nightmares; - Unintended pregnancy, sexually transmitted infections, or termination of pregnancy; - Suicidality and self-injurious behaviors; KQ 2: Any harms that result as an effect of interventions (e.g., stigma, labeling, legal risks, risks of further harm to the child, or dissolution of families, worsening of inequities), or worsening of outcomes^**^ listed in KQ 1 | KQ 1: Outcomes not otherwise specified, studies without direct or proxy measures of abuse of neglect, and parent-reported measures of exposure to abuse or neglect; KQ 2: None specified
Clinical settings | Pediatrics, primary care, family medicine, school-based clinics, or other settings where primary care services are offered; services that could result from an assessment by a clinician (including delivery hospitals, in-home settings, and nonspecialist settings) | Not a primary care–feasible or referable setting, populations, or services/interventions not applicable to U.S. practice
Geographic setting | Research conducted in the United States or in populations similar to U.S. populations with services and interventions applicable to U.S. practice (countries categorized as “very high” on the United Nations Human Development Index, as defined by the United Nations Development Programme) | Research not relevant to the United States in countries categorized as less than “very high” on the Human Development Index
Study designs | KQ 1: RCTs; KQ 2: RCTs, controlled clinical trials, cohorts with controls, and case-control studies; Systematic reviews will be hand searched for additional eligible studies | KQ 1: Systematic reviews, nonrandomized cohort trials, case-control, case series, and case studies; KQ 2: Systematic reviews, case series, and case studies
Timing | Any timing | No exclusion based on timing
Languages | Full-text published in English | Non-English language
Publication type | Original research and systematic reviews | Editorials, commentaries, and narrative reviews

* These outcomes were evaluated in studies that also report at least one child maltreatment outcome. Studies that do not report at least one child maltreatment outcome were ineligible for this review.

** Will be restricted to RCTs

Abbreviations: KQ=key question; RCT=randomized, controlled trial.

## Appendix B3 USPSTF Quality Rating Criteria

### RCTs and Cohort Studies

- Initial assembly of comparable groups:
  ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs

### Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: U.S. Preventive Services Task Force Procedure Manual. Appendix VI. Criteria for Assessing Internal Validity of Individual Studies. Available at: https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual