# Appendix A Contextual Questions and Additional Background

## Contextual Questions

### CQ 1 What are current practices for a) identifying children at risk of maltreatment, b) referring children or families to prevention programs, c) reporting children or families to child protective services, and d) diagnosing child maltreatment outcomes? Do current practices in identification, referral, reporting, and diagnosis of outcomes of child maltreatment differ by race or ethnicity of the child or caregiver? If evidence exists of practice differences, what factors might explain these differences?

#### Key Points

- Evidence suggests that disparities arise frequently prior to intake into the child welfare system, potentially due to bias.
- Identification and diagnosis overlap considerably; we summarize studies on these findings together below along with a synthesis of studies on reporting.

##### Identification/Diagnosis

- The American Academy of Pediatrics (AAP) guidelines detail the recommended steps for the diagnosis of physical abuse.
- These guidelines were developed in part as a response to wide variations in practice for making a diagnosis of physical abuse.
- Data on practice variations primarily address the pediatric emergency department (ED) setting and young children (typically younger than age 2 years).
- Evidence on practice variations suggests:
  ○ Variations in approach to the diagnosis of physical abuse probably led to higher rates of missed diagnoses of physical abuse for White children (37%) than children overall (31%).
  ○ Differences in insurance may be contributing to discrepancies in diagnosis by race.
  ○ Clinician bias may be contributing to discrepancies in diagnosis by race.
  ○ Clinicians’ initial impressions when distinguishing between accidental and abusive trauma is poor.
  ○ Use of guidelines seems be to reducing variations in care.

##### Referral to Prevention Programs

- One study offered supportive interventions that had been shown to reduce child maltreatment to a cohort of families at higher risk; the study found an association between higher risk and active pursuit of home visitation services suggesting receptiveness to interventions.

##### Reporting

- States vary considerably regarding standards for reporting, burden of proof, and protection of the identity of the reporter.
- Certain professions, including healthcare workers, are required to report suspected abuse (mandatory reporters), but these can vary by State and even include professions without routine contact with children such as film or photograph processers, computer technicians, and animal control officers.
- Much of the data are from the 1990s and mid- to late 2000s.
- In addition to State variations in standards for reporting, reporting discrepancies by individual characteristics, such as informant type and Medicaid-eligibility or lack of insurance; household composition; and structural factors such as occupancy rate and proportion of Medicaid patients in hospitals exist.
- Clear and consistent patterns of racial and ethnic disparities exist with reporting. One study evaluating the accuracy of reporting to child protective services (CPS) against substantiation of maltreatment found that the ratio of false-positives to false-negatives was 1.71 in Black children when compared with 1.54 in White children.^74^
- Evidence to explain these differences is not, however, as clear or consistent. Maternal risk factors (such as prenatal care, maternal education, and number of children), socioeconomic status (SES), insurance status, clinician judgment, and community-level factors may play a role.

#### Main Findings

As noted in the main report, the potential for disparities in the child welfare system exists at every stage but particularly at the front-end, prior to intake into the child welfare systems. These disparities require a better contextual understanding of current practice standards and variations in practice. Specifically, this contextual question (CQ) focuses on understanding standards and practices in identifying children at risk of maltreatment, referring children or families to prevention programs, reporting children or families to CPS, and diagnosing outcomes following child maltreatment.

In reviewing the evidence, we encountered significant overlap of the literature in the domains of identification and diagnosis and opted to address those two domains together rather than separately. We found no studies that reported on current practices in making referrals to prevention programs.

We first present evidence on identification and diagnosis and then on reporting. Within each section, we present (1) guidelines or standards, (2) variations in practice, and (3) variations in practice by race and ethnicity. We then summarize evidence gaps for the CQ.

##### Identification and Diagnosis

###### Guidelines or Standards for Identification/Diagnosis of Child Maltreatment

Identification and diagnosis of maltreatment are critical steps toward referring families to appropriate preventive and intervention services that decrease children’s immediate and short-term risk of further maltreatment as well as the likelihood of experiencing long-term negative outcomes. However, identification and diagnosis of maltreatment is complex because maltreatment is often not witnessed by anyone other than the perpetrator and the child, perpetrators rarely report their actions, and children may be too young or too frightened to disclose their abuse.^166^ Additionally, certain injuries, such as rib fractures, are highly concerning for abuse, but not diagnostic. So, diagnosis of maltreatment requires the synthesis of data from a number of sources rather than simply relying on a single test.^167^ Identification and diagnosis of maltreatment are further complicated by variation in legal definitions of maltreatment, specifically neglect and emotional abuse, across States.^168^ So, even when a physician or other clinician has concerns about neglect or abusive injury, the clinical findings may not meet the legal definition of maltreatment in a particular jurisdiction.

The AAP has published guidelines regarding child physical abuse,^166,169,170^ sexual abuse,^171^ and caregiver-fabricated illness.^166,169,170,^ ^172^ In “The Evaluation of Suspected Child Physical Abuse,” the AAP reviews the recommended course of care. The clinical approach to the diagnosis of maltreatment typically involves a comprehensive nonaccidental trauma evaluation, which includes (1) a medical and event history, (2) a physical examination, and (3) additional laboratory and imaging studies (if indicated). A comprehensive medical history includes information about the child’s temperament and medical, developmental, and social history; family health history (e.g., bleeding, bone, metabolic genetic disorders); mothers’ pregnancy history; familial patterns of discipline; history of abuse to the child or siblings or parents’ and family involvement with CPS; parental or caregiver experiences with substance abuse, mental health problems, domestic violence, and arrests and incarcerations; and social and financial stressors and resources. In addition to explicit disclosure of abuse or neglect, medical and event histories that include explicit denial of recent trauma in a child with obvious injury; vague, inconsistent, or no explanation for a serious injury; or notable delay in seeking medical care may raise concern for maltreatment.

A physical examination includes inspection of the head, eyes, ears, nose, and throat for traumatic wounds; an oral examination for dental trauma or dental caries; an evaluation of skin injuries such as bruises, lacerations, burns, and bites, as well as assessment of skeletal and thoracoabdominal injuries; and a complete neurological and motor assessment (including assessment of the fontanelle in infants). Injuries that raise suspicion of maltreatment include any injury to a nonmobile infant; injuries that are patterned, affect multiple organ systems, or occur in unusual locations such as the torso, ears, or neck; multiple injuries in different stages of healing; unusual fractures including rib, midshaft humerus or femur, scapula, classic metaphyseal lesions of the long bones, vertebras, and sternum; and other significant injuries that are unexplained. In addition to physical injuries, symptoms such as unexplained vomiting, lethargy, irritability, apnea, or seizures may also be indicative of abuse.

Based on the findings of the history and physical, the clinician then determines if further diagnostic work-up is needed. In certain cases, the indications for further work-up are quite specific and clear. For example, any injury in an infant before they are cruising raises concern for abuse and likely merits a detailed history and physical examination. Others require significant clinical judgment on the part of the practitioner seeing the patient. For example, a clinician should be concerned for abuse when the explanation for the injury is inconsistent with the child’s physical and/or developmental capabilities, which requires them to exercise their judgment regarding the child’s physical and/or developmental capabilities.

If the clinician determines that further work-up is needed, laboratory and radiologic testing is conducted. Appendix A Table 1 summarizes the types of tests clinicians may conduct during a medical assessment based on the type of injury observed during the physical exam.

###### Variations in Practice in Identification/Diagnosis of Child Maltreatment

The AAP guidelines were developed in part as a response to the variation in the approach to possible cases of physical abuse.

A 2018 systematic review included a total of 22 studies reporting on skeletal survey utilization among 62,226 children age 0 to 59 months.^174^ The review revealed variations in practice by whether abuse was suspected or not, age of the child, type of clinical setting, and type of injury. Eleven studies reported on skeletal survey use among children suspected of abuse. Of these, four studies conducted in pediatric hospitals reported that 85 to 99 percent of infants (<12 months old) and 77 to 90 percent of children (12 to 23 months old) with any type of injury from suspected or diagnosed abuse received a skeletal survey. Two studies conducted in pediatric hospitals reported that 36 to 45 percent of children older than 24 months with suspected or diagnosed abuse received a skeletal survey. Notably, the one study conducted in non-pediatric centers reported much lower use of skeletal surveys among infants (58%) and 1-year-olds (32%) suspected of abuse. Seven studies reported skeletal survey utilization rates among children with specific injuries. Rates were high in studies of infants referred to a child protection team with retinal hemorrhage (100%), skull fracture (94%), bruising (91% to 94%), and burns (89%). Greater variation was observed in children younger than 48 months old diagnosed with abusive head trauma (65% to 92%) and abusive fractures (79%).

In the review, twelve studies reported on skeletal survey utilization among infants younger than 12 months old with injuries concerning for abuse (i.e., bruising or fracture), regardless of whether abuse was suspected.^174^ Skeletal survey utilization was most frequent (59% to 82%) among infants treated at pediatric centers for significant head injuries. Greater variability and inconsistency was observed across other injury types. Skeletal survey performance ranged from 12 to 21 percent among infants with bruising, burns, and minor head injuries, 11 to 60 percent for infants with any type of fracture, 0 to 77 percent for infants with long-bone fractures, and 41 to 86 percent for infants with skull fractures without associated intracranial hemorrhage. Among children older than 12 months, a single study reported that skeletal surveys were used in 66 percent of children 12 to 23 months old and 48 percent of children 24 to 35 months old presenting with severe head injury. More recent studies published after the review continue to find persistent and wide disparities in the use of skeletal surveys^175^ and neuroimaging.^176^

The level of variation described in the systematic review^174^ is concerning because many children are seen by healthcare practitioners prior to the diagnosis of abuse being made, meaning that the failure to obtain recommended testing constitutes a missed opportunity to diagnose child maltreatment. These kinds of missed opportunities appear to be common. In one study, the authors found that 54 of 173 children (31 percent) under 3 years old who were ultimately diagnosed with abusive head trauma were initially misdiagnosed when they were brought to medical attention.^77^ That study also found that White children and children from “intact” families in which both the mother and the father lived in the home had even higher rates of missed diagnoses at 43 of 115 cases (37 percent) and 37 of 92 cases (40 percent), respectively; children from “minority” families had lower rates of missed diagnoses (11 of 58 or 19%). Another study of 653 children younger than age 3 who were presented to either the ED or orthopedic clinic with a fracture found that 151 of those cases (23%) were consistent with possible missed abuse.^177^ Pediatric centers appear to be less likely to miss a diagnosis of abuse than primary care or the adult EDs.^178,179^

Missed diagnoses have significant consequences for children. When the initial presentation of suspected abuse is unrecognized, 39 to 50 percent of patients experience additional abusive injuries within 1 year. Moreover, missing the initial presentation of suspected abuse is also associated with a 10 to 25 percent increased risk of death.^180^

##### Clinician Judgment as a Contributor to Variation

Studies that aim to understand the logic behind a physician’s or other clinician’s thought process when a child presents with symptoms or signs concerning for abuse are limited because of the difficulty in obtaining these data. Surveys of how clinicians would handle hypothetical patient scenarios have been done,^181,182^ but it is unclear how well these surveys correlate with actual practice, and so these are not described here.

Other studies have taken different approaches to try to understand clinicians’ assessment of childhood injuries. One study sought to assess a clinician’s concern for abuse at the time of presentation for young infants presenting with bruising; clinicians reported their level of concern for abuse, with 1 being “definite abuse” and 5 being “abuse very unlikely.”^183^ This rating was done prior to ordering any additional testing, thus isolating the concern for abuse prior to seeing imaging or other laboratory results. The clinician participants worked in primary care offices, EDs, and child abuse programs and clinics. Overall, clinician judgment regarding the likelihood of abuse was poor. For level of concern ratings from 1 to 4, at least 30 percent of the children were determined to have been abused based on the clinical judgment of the study site’s primary investigator after a more thorough evaluation. So, even when providers had a lower suspicion of abuse based on the initial presentation, a substantial proportion of children have been abused. This study was conducted from 2010 to 2017, both before and after the publication of AAP guidelines regarding diagnosis of abuse. The authors recommended routine and protocol-based evaluations for infants with bruising.

Another study assessed physician documentation and orders in a pediatric ED for evidence that abuse was considered as a possible cause of fracture in infants younger than 1 year-old who had not been in a motor vehicle accident.^184^ For study purposes, physicians were classified as considering child abuse as a cause of fracture if they (1) mentioned child abuse as a possible cause of the injury in their note, (2) ordered a skeletal survey, or (3) ordered a consult from the child abuse team. Overall, 66 percent of the cases met criteria for considering abuse, and more than 80 percent of the cases in children younger than 6 months old met criteria for considering abuse. Significant predictors for considering abuse included presenting to the ED between midnight and 6AM, an unwitnessed injury, a male attending physician, rib fractures, and the presence of bruises or lacerations in addition to the fracture.

##### Variation in the Legal Response to a Diagnosis of Child Maltreatment

As mentioned earlier, a clinical diagnosis of maltreatment may or may not translate into legal action. One study reviewed 1,698 evaluations by a child abuse pediatrician over a 2-year period and found that out of the 1,698 cases, a diagnosis of child maltreatment was made in 477 (28%).^185^ Of those, only 151 cases were reported as going to court; the study is unclear on the disposition of the other cases. This highlights one of the difficult points for many clinicians with respect to addressing child maltreatment. Even when physicians state confidently that child has been maltreated, their judgment may not always translate into identification of or consequences for the perpetrator.

###### Variations by Race/Ethnicity of the Child or Caregiver in Identification/Diagnosis of Child Maltreatment

In one systematic review, seven studies examined associations between race and ethnicity and skeletal survey utilization.^174^ Three studies compared skeletal survey use among Black and White children and found that Black children were significantly more like than their White counterparts to receive skeletal surveys when presenting with unwitnessed head injuries, isolated skull fractures, and intracranial hemorrhage. Three studies compared skeletal survey use among “minority” and White children; two of the three reported that skeletal surveys were more common among minority children than White children when children presented with skull or long-bone fractures and when siblings or other household contacts had been diagnosed with physical abuse. One study reported no significant differences in rates of skeletal surveys between Hispanic and non-Hispanic children with minor head injuries.

In addition to the review, one study of 414 cases of children 3 years old and younger who were admitted to the hospital with a primary diagnosis of skull or long-bone fracture found that “minority children” had greater odds of getting skeletal survey than White children (odds ratio [OR], 2.01 [95% CI, 1.00 to 4.04 for children <12 months]; OR, 8.75 [95% CI 3.48 to 22.03 for children ≥12 months]).^78^ More recent studies have continued find higher rates of skeletal surveys among Black infants than among infants of other races.^186^ In another study, Black newborns (7.3%) were significantly more likely than White newborns (1.9%) and other racial and ethnic groups to receive a drug test when no obstetric urine drug test performed during the pregnancy, after controlling for insurance type.^187^

##### Insurance Status

Although one study suggested that insurance status was not significantly associated with receipt of a skeletal survey,^78^ others found differences by insurance status.

One study found differences in likelihood of a skeletal survey by insurance status (81% of children with public insurance received skeletal surveys vs. 59% of those with private insurance after adjusting for age and severity of the injury).^188^ The effect of insurance varied significantly by race. Eighty-two percent of White children with public insurance received a skeletal survey compared with 53 percent of children with private insurance. However, among Black children, 85 percent with public insurance received skeletal surveys vs. 75 percent of those with private insurance, and 72 percent of Hispanic children with public insurance vs. 55 percent of those with private insurance received surveys (p=0.2).

A second study found that in ED, primary care, or urgent clinic settings, infants 6 months old or younger with at least one injury with public insurance were more likely to receive a skeletal survey that those with non-public insurance.^175^

A third study reported differences in rates of neuroimaging among infants with humerus and femur factures by insurance status after adjusting for age, sex, race/ethnicity, fracture type, and hospital.^176^ Publicly insured infants underwent neuroimaging more frequently (62.0%) than privately insured infants (55.1%) (p=0.001). However, detection of an intracranial injury was no more likely among publicly insured infants (3.7%) than privately insured infants (1.7%) (p=0.10). Among infants less than 6 months of age, there was no significant difference in rates of neuroimaging between publicly (81.6%) and privately (76.3%) (p=0.08) insured infants. However, among infants between 6 and 12 months of age, publicly insured infants (42.7%) were significantly more likely to undergo neuroimaging than privately insured infants (33.5%) (p=0.003).

##### Physician Perceptions

Physician perceptions may also be a contributor to the variations in diagnosis by race. A study of children referred for physical abuse evaluation by child abuse pediatricians from 23 institutions across the United States found that physicians’ perceptions of social risk for abuse was highest for non-minority families and minority families with low SES. More specifically, the study found that the two lowest SES tertiles were associated with higher perceived social risk for abuse for both minority and non-minority families, indicating that SES plays a role in pediatricians’ perception of abuse risk.^189^

A retrospective, secondary analysis of young children hospitalized acutely for the treatment of head trauma in 1 of 18 participating pediatric intensive care units (PICUs) found that race/ethnicity-based disparities in abusive head trauma (AHT) evaluation and reporting were observed. However, evidence of racial disparities at 2 of the 18 sites seemed to be the primary contributors to the evidence of bias across the whole study. When the other 16 sites were analyzed separately, the evidence of bias by race was no longer statistically significant. In the absence of local confounders, these disparities likely represent the impact of local physicians’ implicit bias at the 2 sites where bias was noted.^76^

##### Role of Guidelines in Addressing Provider Bias

In areas for which recommendations are clear regarding the need for evaluation of maltreatment, implementation of guidelines appears to reduce disparities. In one study, the implementation of a protocol recommending a skeletal survey for all children younger than 1 year with unwitnessed head trauma, disparities by race in obtaining a skeletal survey were reduced.^190^ Prior to the protocol, Black infants underwent a skeletal survey 90 percent of the time vs. 69 percent for White infants. After the implementation of the protocol, Black children received skeletal surveys 92.3 percent of the time vs. 84.6 percent of the time for White children. Another study found that disparities in skeletal survey testing by insurance type and ED settings were reduced after the implementation of a child abuse guideline.^191^ Prior to guideline implementation, among infants who met AAP criteria for evaluation of abuse those who did not have private insurance were significantly more likely to receive a skeletal survey than those with private insurance across community and pediatric EDs. Prior to guideline implementation, 29.6 percent of infants with a single type of medically minor injury (i.e., oral injury or high-risk bruising) received a skeletal survey in pediatric EDs compared to 4.0 percent of infants in community EDs. After guideline implementation, variation in skeletal survey testing for infants with a single type of medically minor injury was nearly eliminated (26.7% vs. 25.05%).Calls have been made to develop clearer guidelines for more nuanced patient presentations, such as infants who present with brief, resolved, unexplained events, which include symptoms such as pauses in breathing or alterations in consciousness that are less straight-forward with respect to appropriate testing.^186^

##### Referral to Prevention Programs

One study offered supportive interventions that had been shown to reduce child maltreatment to a cohort of families at higher risk.^192^ Birth records were used to identify factors interpreted as risks for child maltreatment: (1) “abnormal” condition of the newborn, (2) low birth weight, (3) absence of private insurance, (4) inadequate prenatal care, (5) single parenthood, (6) parenting multiple children, (7) maternal age <25 years, (8) maternal education less than high school, and (9) prior abortion. The study found an association between higher risk and active pursuit of home visitation services (p < .047) suggesting receptiveness to interventions.

##### Reporting

###### Guidelines or Standards for Reporting Child Maltreatment

Our review of guidelines for reporting suspected abuse or neglect reveal significant State-based variations in specifying mandatory reporters, reporting by other persons institutional reporters, standards for making a report, and confidentiality of the reporter’s identity. Mandatory reporters belong to professions whose members were required to report suspected maltreatment. Forty-seven States specify mandatory reporters. While mandatory reporters generally included professions with frequent contact with children (such as social workers, teachers, healthcare workers [including mental health professionals], childcare providers, medical examiners, and law enforcement officers), they may also include—depending on the State—professions without routine contact with children such as film or photograph processers, computer technicians, and animal control officers. Regarding reporting by other persons, 18 States require all persons who suspect abuse or neglect to report it regardless of professions. All remaining 32 States permit all persons who suspect maltreatment to report it; these persons are considered “permissive reporters.” Institutions that employ mandatory reporters also have specified roles, responsibilities, and requirements that vary by State (“institutional reporters”). For instance, laws vary about whether the mandated reporter or the institutional head is required to report the suspected maltreatment. Some States have laws that prohibit discouraging or retaliating against employees who report suspected maltreatment.

Recent investigative reporting suggests that expansion of reporting (as in case of the State of Pennsylvania, which expanded the list of mandatory reporters, broadened the definition of abuse, and increased penalties for failing to report abuse) may have resulted in overwhelmed systems dealing with a 42 percent increase in reported cases (29,766 from 2010 to 2014 vs. 42,399 from 2015 to 2019) without a concomitant increase in substantiated cases (10,410 from 2010 to 2014 vs. 10,399 from 2015 to 2019).^193^ The burden of this increase in investigation is more likely to fall on Black families who are reported at greater rates than their proportionate share of the population (in Philadelphia, Black children comprise 42% of the child population but were the focus of 66% of the reports to the Department of Human Services).

As with standards for who is required to report suspected maltreatment, standards for making reports also vary by State. These can include suspicion or reason to believe that a child has been abused or neglected or knowledge or observation of a child being subjected to conditions that would reasonably result in harm to the child. In Maine, for example, having reasonable cause to suspect that a child is not living with their family requires mandatory reporting. While mandatory and permissive reporters are required to explain the circumstances that led to the report, neither are required to provide proof of maltreatment. Although most States (44 as of 2019) protect the identity of reporters from alleged perpetrators of maltreatment, State requirements on the inclusion of the reporter’s name on the report is more variable. Toll-free telephone lines for reporting suspected maltreatment generally permit anonymous reporting. Nineteen States (as of 2019) require the name of mandatory reporters to be included in the report.

###### Variations in Practice for Reporting Child Maltreatment

In addition to State variations in standards for reporting, reporting discrepancies persist by individual characteristics such as informant type and insurance status; household composition; and structural factors such as hospital characteristics (occupancy rate and proportion of Medicaid patients). A 2020 systematic review reported on informant discrepancies between case files, youth self-report, and parent report. To explore level of agreement between informants, the systematic review included studies with at least two types of informants of at least one form of child maltreatment.^194^ The authors found that discrepancies in reporting were common, with generally poor agreement between informants across all maltreatment types (k=−0.02 to 0.37 [poor to fair agreement]). Across studies, youth tended to endorse physical abuse, sexual abuse, and emotional abuse more often than recorded in their case files but reported less neglect relative to their case files. Fewer studies included comparisons of other types of informants including caregivers and residential treatment staff; however, the directionality between youth and those informants was often inconsistent across studies.^194^

Some evidence suggests an association between insurance status and risk of being reported. When controlling for race and age, Medicaid-eligible/uninsured infants were more likely than privately insured infants to be reported to CPS in the presence of a complex skull fracture or clinical findings that raised suspicion for abuse.^195^

Household composition also appears to play a role. A national, longitudinal study of household composition and maltreatment allegations for children from ages 4 to 10 years explored familial risk factors and found substantial variability in the rate of maltreatment allegations across different types of single-mother household compositions. In particular, the presence of non-relatives, especially unrelated males, demonstrated an increased risk for maltreatment allegations in the home. However, single-mother homes with two or more adult relatives, especially grandmothers, had a reduced risk for child maltreatment allegations. The study demonstrated that maltreatment allegations in single-mother homes were linked to the composition of types of other adults in the home rather than correlated with the number of adults in the home.^196^

Hospital-level factors may affect reporting. A study of hospital-level risk factors using a merged dataset of birth, hospital discharge and CPS records for all children born in Washington State between 2006 and 2013 reported associations between hospital-level factors and variations in CPS reporting. The study found significantly higher likelihood of being reported to CPS among substance-exposed infants born at hospitals that served larger populations of patients with Medicaid (OR, 1.25 [95% CI, 1.08 to 1.45]) and children in hospitals with higher occupancy rates (OR, 1.43 [95% CI, 1.15 to 1.77]) than substance-exposed children born in hospitals serving smaller populations of patients with Medicaid and with low occupancy rates to be reported to CPS.^197^

###### Variations by Race/Ethnicity of the Child or Caregiver in Reporting of Child Maltreatment

The National Incidence Study of Child Abuse and Neglect (NIS), a congressionally mandated effort to provide estimates of the incidence of child abuse and neglect, was last conducted from 2005 to 2006. This study (which included 29,488 children) represents the most recent geographically representative data source for the United States.^75^ The study used two definitions: the harms standard and the endangerment standard. The harm standard requires that “an act or omission result in demonstrable harm in order to be classified as abuse or neglect,” whereas the more inclusive endangerment standard also counts children who had the potential to be harmed because of maltreatment.^75^ A further analysis of these data, coupled with California’s child welfare agency data, sought to understand the rates of disproportional reporting at the front-end of the system.^74^ The study assumed that substantiation of maltreatment (using the endangerment standard) was the true positive and sought to identify the accuracy of referral when compared with substantiated cases. The study showed that specificity and sensitivity were both lower among Black participants when compared with White participants (sensitivity, 0.399 vs. 0.374 and specificity, 0.944 vs 0.972, respectively). The ratio of false-positives to false-negatives was 1.71 in Black children when compared with 1.54 in White children. The study suggested that these differences may be attributable to more random errors or “honest mistakes”^74,^ ^pp. 390^ for minority groups. The study did not, however, explore factors such as interpersonal or structural racism as reasons why supposedly random errors may occur more frequently among Black children than among White children.

Other population-based studies also report large disparities in reporting by race both within and across States. A study of a 2002 cohort in California reported the number of Black children referred for maltreatment before age 5 was 300.0 per 1,000 vs. 133.5 per 1,000 for White children (risk ratio [RR], 2.24 [95% CI, 2.20 to 2.29]).^198^ A comparison of reports to CPS in Alaska and California found that disparities across two States (26% in Alaska for 2009 to 2011 vs. 19% in California) in rates of reporting could be explained by population race structure.^199^ Furthermore, within each State, rates of reporting vary by race: (cumulative incidence rates in Alaska for American Indian/Alaska Native children: 0.487, Black: 0.305, White: 0.167; cumulative incidence rates in California for American Indian/Alaska Native children: 0.432, Black: 0.379, White: 0.159).^199^ These clear and consistent patterns of differences in reporting of maltreatment by race have led to numerous investigations of individual and familial factors, provider factors, and larger community factors to explain these differences.

###### Individual, Maternal, and Familial Risk Factors

One population-based study of children born in 2008 in Tennessee addressing the child-specific risk factor of a diagnosis of autism spectrum disorder did not reveal differences in reporting of maltreatment when comparing White children to all other races. Notably, however, pooling all races other than White as the comparator may have conflated varying rates of reporting.^200^ Studies of maternal risk factors—specifically, prenatal substance abuse exposure—failed to demonstrate bias. A study using 2006 linked birth, hospital discharge, and CPS record data in California did not find evidence that racial disparities in CPS reports arise from bias in response to prenatal substance exposure.^201^ The study found that substance-exposed Black and Hispanic infants were reported at significantly lower or statistically comparable rates to substance-exposed White infants. A merged dataset of birth, hospital discharge, and CPS records for all children born in Washington State between 2006 and 2013 also failed to demonstrate statistically significant differences in the odds of reporting by race (Black, Hispanic, Native American, White) and type of prenatal substance use exposure (amphetamine, cannabis, alcohol, cocaine, opioids), with the exception of Black women with prenatal alcohol exposure—these women had higher odds (2.43 [95% CI, 1.18 to 5.03]) of having their children reported for maltreatment than White women with prenatal opioid exposure.^197^ An Illinois-based study of neonatal toxicology reports and child welfare agency data in 2012 did not find data to support differential reporting by race; rather the study found that White infants were more likely to be reported than Black infants. The study notes, however, that the type of prenatal substance use exposure may influence the decision to report, and the type of prenatal substance use varied by race in this study (Black infants were reported more frequently for prenatal cannabinoid exposure and White infants were reported more frequently for prenatal opioids exposure).^202^

A study exploring other maternal risk factors (SES, prenatal care, maternal education, number of children) found that controlling for these risk factors reduced the risk of CPS referral among Black children. A study using 2002 linked birth and CPS record data in California found that Black children were more than twice as likely as White children to be referred for maltreatment before age 5, but when stratifying for public health insurance as a marker of SES, race no longer showed a significant association with referral for maltreatment; low-SES Black children had a lower risk of referral to CPS than their socioeconomically similar White counterparts. Further, the study found that the relative risk of CPS referral decreased when maternal risk factors including prenatal care, maternal education, and number of children were included in the model as covariates. For instance, prenatal care during the first trimester of pregnancy, presence of some college education, and having fewer children were protective factors associated with reduced risk of a child’s report for maltreatment. More specifically, those with prenatal care that began during the third trimester or not at all were 2.04 and 3.92 times as likely to have been referred than those whose care began during the first trimester, respectively.^198^

Insurance status may also influence disparities in reporting by race. One study found that among privately insured patients, Black children were more likely to be reported to CPS than White children; however, among children without private health insurance, the reporting rate for Black patients did not differ significantly from the reporting rate for children of all other races.^203^ These findings suggest that private health insurance can protect White children from being reported to CPS.^203^

###### Clinician Factors

Studies reporting clinician factors demonstrate racial disparities in healthcare providers’ reporting decisions, with a tendency to over-report Black and other “minority” children in comparison to White children. A retrospective chart review of 388 children hospitalized for skull or long-bone fracture between 1994 and 2000 at an urban academic children’s hospital in Philadelphia found that minority toddlers were significantly more likely (AOR, 4.32 [95% CI, 1.63 to 11.43]; p=0.003) to be reported to CPS by hospital clinicians compared with White toddlers, even after controlling for insurance status and likelihood of abuse.^78^ This finding demonstrates differential reporting by race and suggests provider implicit bias plays a role when reporting pediatric fractures for child abuse. Similarly, a retrospective study of children diagnosed with rib fractures at an urban tertiary care children’s hospital in Philadelphia between 2007 and 2018 found that Black children were more likely to have a CPS report than White children (89% vs. 59%; p=0.035).^204^ Similarly, a secondary analysis of CPS reports for pediatric patients at a regional, academic center in New York found racial/ethnic disparities in CPS reporting.^81^ Specifically, the study reported that medical personnel made significantly disparate reporting decisions for “minority” pediatric patients compared with decisions for White pediatric patients, with the odds of Black and Hispanic pediatric patients being reported to CPS being approximately four times greater than the odds of White pediatric patients. In addition to racial disparity findings, the study found SES to be significant in reporting decisions: pediatric patients from high poverty neighborhoods were reported to CPS at approximately five times the rates of pediatric patients from low poverty neighborhoods.^81^

###### Community-Level Risk Factors

Studies of community-level risk factors—specifically, neighborhood composition—demonstrated disparities in families’ contact with CPS authorities but did not demonstrate reasons for these disparities. In a study investigating the cumulative risk of CPS reports before age five by neighborhood poverty rate and neighborhood racial composition using 1997 to 2015 administrative record data of CPS reports in Connecticut, the investigators found that CPS reports occurred at disproportionately rates among children in poor neighborhoods and children in non-White neighborhoods. For example, while only 28 percent of children in the State live in neighborhoods with greater than 10 percent poverty, these areas account for more than half of CPS reports. Similarly, nearly half of reports involve families in majority-non-White neighborhoods, which is disproportionate to the 26 percent of Connecticut children who live in these neighborhoods. The study does not shed light on whether unequal CPS involvement results from greater risks faced by groups disproportionately involved or from bias on the part of child maltreatment reporters and the CPS system.^205^

Further analysis of community-level risk factors suggests that disparities in reporting do not entirely disappear in analyses that stratify by poverty, with Black children still reported more than White children at the highest level of poverty.^206^ A study of school employees in 2016 to 2017 in a metropolitan California county demonstrated that Black to White disparity in CPS referral by school employees remained even when data was stratified by different poverty levels. This study found that Black children were still reported slightly more often than White children at the highest level of poverty (as measured by the percentage of students eligible for free meals); the Black/White disparity index was 1.10, indicating disproportionate reporting in the first group compared with the second. More specifically, the highest level of poverty was associated with a reduction of the Black/White disparity index by an average of 8 percent per each 1 percent of student population eligibility, but the Black to White disparity ratios did not completely disappear.^206^

##### Evidence Gaps in Identification/Diagnosis of Child Maltreatment

We identified multiple gaps in the literature in seeking to answer this CQ. Much of the data on the diagnosis and identification of maltreatment comes from EDs, mostly pediatric EDs. Data regarding the approach to identification and diagnosis of maltreatment in primary care settings, both pediatrics and family medicine, are needed, especially since the little available data suggest high rates of missed diagnoses in those settings.^179^ Much of these data were collected before the publication of the 2015 AAP guidelines. New studies to assess practice since the release of those guidelines would be helpful, particularly since studies suggest that the implementation of guidelines seems to be reducing bias in practice.

Additionally, the data on variations in practice have been extracted primarily in the context of physical abuse toward small children, a context in which guidelines have clear recommendations about evaluation and diagnosis. Studies assessing variations in practice for the diagnosis and evaluation of sexual abuse and neglect are needed, as well as studies assessing variations in the approach to diagnosis of physical abuse in older children, areas for clear recommendations, are lacking.

##### Evidence Gaps in Referral to Prevention Programs

With the exception of the very limited evidence on higher uptake of home visitation among those identified to be at higher risk of child maltreatment,^192^ we found no information on the rates and variations in referrals and uptake, including by race or ethnicity.

##### Evidence Gaps in Reporting of Child Maltreatment

As with the evidence on identification/diagnosis, much of the evidence on reporting is older, collected in late 1990s and mid- to late 2000s. More recent studies will help to identify current patterns in reporting. As noted above, although evidence of disparities was clear, evidence on the reasons for disparities were lacking clarity or consistency. Studies addressing multifactorial and structural causes, including social determinants of health (SDOH) may offer greater clarity. Vast State-to-State variations in reporting also highlight the importance of continuing to study whether specific State systems are associated with better outcomes or worse outcomes.

### CQ 2 What are the validity and reliability of risk assessment tools to identify children and adolescents who are at risk of child maltreatment? Does the reported validity and reliability (of risk assessment tools) differ by race and ethnicity? If yes, what might explain these differences? Is there evidence that these tools alter or increase inequity?

#### Key Points

- We identified two systematic reviews, one meta-analysis, and 33 studies describing evidence on 25 instruments. Of these studies, 10 describe reliability and 23 describe validity.
- No gold standard exists for identifying child maltreatment: both parent-reported abuse and neglect measures and child welfare measures, such as reporting to CPS or substantiated reports of abuse, may reflect over- or underreporting of true child maltreatment occurrence.
- Risk assessment instruments may rely on referrals to CPS, substantiated reports, or consensus judgment for validation.
- Typical settings of use include screening for physical abuse in the context of the ED or hospital setting. Eleven of the 23 instruments were evaluated in an outpatient or home setting; of these two were set in primary care and one in a prenatal care setting.
- Instruments can be classified as actuarial, based solely on empirically established relationships of risk factors and child maltreatment, or clinical, based on the judgment of a professional or a group of experts.^207^
- The distinction between actuarial and clinical can be imprecise as there are instruments and questions that could be considered actuarial or clinical based on how the information is collected. For example, if a question or domain in a tool is evaluating harsh parenting practices, then a yes or no question that is self-reported by the caregiver could be used in an actuarial tool; but if a nurse is answering based on perception or clinical judgment of the parenting practices, then it would be categorized as clinical.
- Of the 25 risk assessment tools, 11 instruments can be used to predict future maltreatment: four actuarial and seven clinical.
- Instruments have poor to good accuracy overall (areas under AUCs range from 0.31 to 0.89), but instruments in settings that are not applicable to primary care (emergency departments and hospitals) have consistently higher accuracy (AUCs range from 0.78 to 0.89) than instruments in settings applicable to primary care (AUCs range from 0.31 to 0.85).
- Sensitivities range from 14.8 to 97.0 percent, and specificities range from 16.6 to 98.5 percent.
- Actuarial instruments are better at predicting the onset of maltreatment than clinical instruments, but actuarial sensitivity ranges from 61.1 to 96.8 percent, specificity ranges from 16.6 to 98.5 percent, and AUCs range from 31.3 to 89 percent. Clinical sensitivity ranges from 14.8 to 97.0 percent, specificity ranges from 21.0 to 98.2 percent, and AUCs range from 50.0 to 87.0 percent.
- Of the 24 studies included in the review of the key questions, six identified participants using a risk assessment instrument. The six studies used one of five screening instruments: Kempe Family Stress Checklist (KFSI), the Maternal History Interview (MHI-2), the Parent Screening Questionnaire (PSQ) within the Safe Environment for Every Kid (SEEK) Model, the Brief Infant-Toddler Social and Emotional Assessment (BITSEA), and the Parent Risk Questionnaire (PRQ). Studies reporting on the validity of the tools were found for only two of these instruments (KFSI and MHI-2), and those reporting on reliability were found for three of the instruments (FKSI, MHI-2, and BITSEA). Four of the five instruments are risk assessment tools for child maltreatment (KFSI, MHI-2, PSQ, and PRQ) and one instrument screens for social or emotional behavioral problems (BITSEA).
- No studies reported the reliability or validity of risk assessment tools by race or ethnicity. No information is available on whether risk assessment tools alter inequities.

#### Main Findings

One meta-analysis^207^ examined the predictive accuracy of 27 instruments from 30 studies using the AUC value for effect size. The study classified the instruments as either clinical or actuarial and found that the mean effect size was higher for actuarial instruments than for consensus-based instruments or structured clinical judgments, which were both considered clinical instruments (AUC, 0.704 vs. 0.644 vs. 0.592, respectively).^207^ Of the 30 studies, nine examined the onset of maltreatment, 16 examined the recurrence of maltreatment, and five studies included both onset and recurrence of maltreatment or did not specify. The meta-analysis found that instruments predicting the onset of maltreatment had a higher mean effect size than instruments predicting the recurrence of maltreatment (AUC, 0.744 vs. 0.659; p<0.01).^207^ The meta-analysis did not report on the reliability of predictive validity estimates but noted that very few instruments have been validated in multiple independent samples.

One study,^208^ published after the meta-analysis,^207^ found the opposite when it compared the validity of actuarial vs. clinical factors for identifying child maltreatment and found that the clinical factors better predicted CPS investigations for child maltreatment and emergency medical care (EMC) outcomes. The four demographic factors were health insurance of the infant, first-time birth, teen parenthood, and no high school diploma. Four clinical domains, together the Enhanced Eligibility Screening for Family Connects, with three factors each (healthcare, parenting/childcare, home safety, and parent mental health) were evaluated by a nurse during a home visit. The demographic and clinical factors were compared as risk assessments tools to both CPS reports and EMC for injury or illness. CPS reports had a significant coefficient for the clinical risk variable (hazard ratio [HR], 4.01 [95% CI, 1.97 to 8.15]) and a non-significant coefficient for the demographic risk variable (HR, 2.45 [95% CI, 0.58 to 10.26]).^208^ For predicting EMC, the clinical risk variable significantly predicted higher and earlier-onset of use (HR, 2.14 [95% CI, 1.03 to 2.14]), while the demographic risk variable did not significantly predict use (HR, 1.54 [95% CI, 0.88 to 2.87]).^208^ The study had a smaller sample size (n=201) and only represented one geographic community but had substantial interrater reliability (K=0.69). Another consideration is that the nurses who found families to be at higher risk based on the clinical domains were responsible for the higher rates of CPS reports and ED visits as they may have made reports to CPS or recommended seeking medical care as a result of their home visits and interactions with the family. One study^209^ of the actuarial risk assessment tool, the Instrument for early identification of Parents At Risk for child Abuse and Neglect (IPARAN), compared results from the instrument to nurses only using clinical judgment to nurses using the instrument and clinical judgment. The nurses using the IPARAN with clinical judgment had the best validity (sensitivity, 66.7 percent; specificity, 77.4 percent; AUC, 72.0 percent).^209^ Using the IPARAN alone had greater sensitivity and AUC effect size than clinical judgment alone, which was more specific. The difference between IPARAN alone and IPARAN combined with clinical judgment was not statistically significant.^209^

One systematic review^210^ evaluated screening tools for child abuse and included 23 articles with 15 screening tools divided into three categories: objective assessments including interviews and physical exams (five tools), biochemical tests and precision imaging (six tools), and self-report (four tools). Of the 15 tools the study identified, validity was evaluated for 11 tools (AUC, sensitivity, and/or specificity) and reliability was evaluated for two tools (internal consistency Cronbach’s alpha).^211^ The systematic review did not evaluate the tools by category and notes that the studies were validated in a variety of settings (two during home visits, two in hospital settings, three at outpatient clinics, five in Eds, and three in PICUs). and for three studies, no gold standard for confirming child abuse was used.^212^ The review recommends using the Escape tool (a clinic judgement tool for which they calculated an AUC of 99.2%), or if the child is being evaluated for a brain injury or fracture, they recommend the PIBIS (Pittsburgh Infant Brain Injury Score), DIPCA (Diagnostic Index for Physical Child Abuse), and SIPCA (Screening Index for Physical Child Abuse) tools (actuarial tools with reported AUC values of 83%, 86%, and 89%, respectively).^212^

One study of medical students and orthopedic residents identifying child abuse in children presenting with fractures found that participants who used predominantly objective data were correct in 56 percent of cases while participants who used predominantly social data were correct in 33 percent of cases.^213^ Participants who used a combination of objective and social data had the best accuracy and were correct in 72 percent of the cases. Their sensitivity increased with training ranging from 0.71 to 0.73, while their specificity decreased with additional training ranging from 0.30 to 0.47.^213^ This finding is consistent with the finding that actuarial instruments have better validity than tools that require clinical judgement.

One study examined skull fractures to determine if complex fractures are more indicative of child abuse than simple skull fractures and found that it was not possible to determine abuse versus accident from skull fracture type alone.^214^ The positive predictive value of a complex skull fracture for abuse was 7 percent, illustrating that even something as specific for abuse as a complex skull fracture does not have a high enough positive predictive value to determine abuse by itself.^214^

Of the 25 risk assessment tools for which we identified evidence; 11 instruments can be used to predict future maltreatment. Four are actuarial tools: Child Abuse Potential Inventory (CAPI), Enhanced Eligibility Screening for Family Connects, IPARAN, and Predictive Risk Modeling. Seven are clinical tools: BabyFirst Screen, Early Risks of Physical Abuse and Neglect Scale (ERPANS), INTOVIAN, KFSI, MHI-2, Ontario Risk Assessment Tool, and Symptoms Associated with Sexual Abuse (SASA).

##### Actuarial Tools

Twelve instruments were identified as actuarial risk assessment tools that are based on empirically established relationships of risk factors and child maltreatment. Table 2 presents information on the reliability and validity of these instruments. For the 12 actuarial instruments, sensitivity ranges from 61.1 to 96.8 percent, and specificity ranges from 16.6 to 98.5 percent. A wide variety of reference standards were used to evaluate these tools including CPS reports, abnormal radiologic findings, and consensus or clinical judgment. Five of the 11 instruments were studied in an outpatient setting while the others evaluated children already in the emergency room (ER) or hospital. Four were designed to screen for future maltreatment: CAPI, IPARAN, Predictive Risk Modeling, and Enhanced Eligibility Screening for Family Connects.

The CAPI has been validated in several studies, and the meta-analysis^207^ calculated AUCs ranging from 0.5565 to 0.6895, showing poor discrimination for this instrument. The validity and reliability information for the Enhanced Eligibility Screening for Family Connects^208^ and the IPARAN^209^ were described above. The Predictive Risk Modeling^215^ was validated in children enrolled in New Zealand’s public benefit system using substantiated CPS reports as the reference. The study found an AUC of 0.76 (95% CI, 0.757 to 0.771) indicating acceptable discrimination for the tool.^215^

The New South Wales Child Development Study^216^ was validated in children born in New South Wales from 2002 to 2005. The children were followed until age 13 using substantiated CPS reports or out-of-home care placement. The study found AUCs of 0.82 to 0.84 (95% CI, 0.82 to 0.85) depending on use of the full 14 indicators or the final 10 indicator model.^216^ The mean sensitivities ranged from 0.72 to 0.74, and specificities ranged from 0.80 to 0.82.^216^ This tool was not developed to predict child maltreatment at the individual level, and the author notes that if this tool were implemented at the population level it would result in high false positive rates resulting in individuals not likely to develop the adverse outcome being targeted for intervention.^216^

##### Clinical Tools

Thirteen instruments were identified as clinical risk assessment tools or based on the judgment of a professional or a group of experts. Table 3 presents information on the reliability and validity of these instruments. For these clinical instruments, the sensitivity ranges from 14.8 to 97.0 percent, and specificity ranges from 21.0 to 98.2 percent. There was a wide variety of reference standards used to evaluate these tools including CPS reports, record reviews including trauma registries, and consensus or clinical judgment. Six of the 12 instruments were studied in an outpatient setting while the others evaluated children already in the emergency room or hospital. Two were set in primary care and one in a prenatal care setting. Seven were designed to screen for future maltreatment: BabyFirst Screen, ERPAN, INTOVIAN, KFSI, MHI-2, Ontario Risk Assessment Tool, and SASA.

BabyFirst Screen^217^ was validated in infants born in Manitoba, Canada, using reports of out-of-home placement from provincial ministry of family services records as the reference standard. The tool was found to have a sensitivity of 0.776 and a specificity of 0.833.^217^

The reliability of ERPANS^218^ was evaluated in a study of home visits in the Netherlands. The tool was found to have high internal consistency (Cronbach’s α, 0.94) and interrater reliability (across all items: r=0.97). No testing of validity was performed. The reliability of the INTOVIAN^219^ tool was also evaluated among children seen in public health centers in Cyprus, Greece, and Spain, and the tool had acceptable internal consistency (Cronbach’s α, 0.79).

Three studies evaluated the validity of the KFSI and had varied results.^39,220,221^ The results from one screening test accuracy study indicate high sensitivity and specificity (80% and 89.4%, respectively), but the method of validation has serious flaws because it appears to exclude participants with intermediate risk.^221^ A meta-analysis calculated the mean effect size for the instrument from this data and found an AUC of 0.8470.^207^ A second study reported reliability data from two trials and found relatively lower rates of specificity.^220^ One trial reported sensitivities of 84 to 89 percent and specificities of 28 to 35 percent, depending on if followup was at 6 or 12 months.^220^ The other trial reported sensitivities of 69 to 96 percent and specificities of 21 to 42 percent, depending on the cutoff used for the KFSI.^220^ This trial also reported on the reliability of the KFSI and found high reliability on individual characteristics in terms of levels of risk (r=0.93), but it did not provide answers to whether families would receive the same score by independent evaluations.^220^

Two studies reported on the validity of the MHI-2. One of the studies found low rates of sensitivity and specificity (65% and 81.3%, respectively) with a low positive predictive value (5.5%), high false-positive rate (34.8%), and high false-negative rate (18.7%).^113^ The study did find an internal consistency alpha of 0.08 and both studies were able to achieve 90 percent or greater interobserver agreement among four trained interviewers.^113,222^ Two studies of the MHI-2 were used in the meta-analysis to calculate the mean effect size for the instrument, and the AUC ranged from 0.5385 to 0.7620.^207^

One study evaluated the reliability and validity of the Ontario Risk Assessment Tool^223^ based on children in the Children’s Aid Society database. The tool had an acceptable internal consistency (Cronbach’s α, 0.73) for caregiver category but with lower internal consistency (Cronbach’s α, under 0.7) for the four other categories. The interrater reliability was poor with Cohen’s Kappa scores greater than would be expected by chance alone in eight of the 22 risk items. The meta-analysis^207^ calculated an AUC of 0.5000, indicating the tool does not discriminate any better than expected by chance.

One study evaluated the reliability and validity of the SASA,^224^ a tool designed to screen for sexual abuse. The tool had good internal reliability (Cronbach’s α, 0.83). The study found that the tool had a sensitivity of 90.9 percent and a specificity of 88.5 percent compared with the reference of CPS reports.^224^

##### Tools Used in Review Studies

Of the 24 studies included in the review of key questions, six identified participants using a risk assessment instrument. Four were screening instruments for child maltreatment: KFSI, the MHI-2, the PSQ within the SEEK Model, and the PRQ. Two of these four instruments were clinical instruments and had studies evaluating their reliability and validity (KFSI and MHI-2) as detailed above.

##### Race and Ethnicity

No studies reported the reliability or validity of risk assessment tools by race or ethnicity. One meta-analysis^207^ examined the effect of the percentage of cultural minority participants in each study and found no significant moderating effect on predicting child maltreatment. One scoping systematic review^225^ synthesized the evidence of validity and reliability of specific risk assessments tools designed for CPS agencies. Eleven tool families were identified and divided into four consensus-based, six actuarial, and one automated algorithmic tool.^225^ The study found a lack of evidence that the assessments tools are equally predictive or reliable across subgroups with less than one-third of the studies even describing the racial and ethnic makeup of the study population.^225^ One of the included studies found that the California Structured Decision Making Risk Assessment disproportionately classified Native American families at higher risk despite having similar outcome rates.^225^ The authors recommend that these CPS tools are explicitly tested among various subpopulations.^225^

One study^226^ found that Torso, Ear, and Neck Bruising Clinical Decision Rule (TEN-4-FACESp), a clinical tool used to identify physical abuse using bruising, found that the tool’s validity did not vary significantly by skin tone. Skin tone was assessed by the research staff and defined as fair, light, mid, brown, or dark compared with five photographs that served as the reference standard. The categorizations were verified by the principal investigator. No information is available on whether risk assessment tools alter inequities.

#### Potential Interventions to Address Child Maltreatment

Interventions to prevent child maltreatment may include:

- [underlined: Home-visitation programs]: Prevention programs often involve home visitation programs aimed at improving parenting and parent–child relationships and strengthening the family. The focus of the intervention is typically on building positive parent–child or family relationships and attachment, reducing harsh parenting, increasing nurturing parenting, and creating a safe home environment.^244,245^ These interventions sometimes include components designed to support parents in meeting basic needs (e.g., employment) and helping them gain access to social support and community services.
- [underlined: Pediatric primary care programs]: Programs implemented in the pediatric primary care setting train health professionals to identify factors placing children at high risk for maltreatment or neglect. AAP recommends that pediatricians assess parenting strengths and weaknesses and make referrals to community resources that may help prevent maltreatment.^101^
- [underlined: Psychotherapy interventions]: Psychotherapy interventions may target high-risk groups such as children of families exposed to substance use, marital discord, inadequate housing, poverty, or lack of social supports. Counseling and cognitive behavioral therapy strategies may be incorporated into prevention efforts with a focus on improving parental mood and coping skills. Art therapy or other psychological approaches may target child or parent mental health or behaviors.^246^ Early childhood mental health services typically focus on strengthening the parent–child relationship and addressing attachment between caregiver and child; infant mental health services focus specifically on children from birth to age 3 years^247^ and their caregivers. Psychotherapy interventions may be offered in the home as a home-visiting service or component of a home-visitation program or be clinic based.
- [underlined: Respite care]: Interventions may also include respite care, which offers short-term, temporary relief to families caring for children with developmental disabilities or serious emotional disturbances or families that lack reliable support systems. These factors may place children at risk for maltreatment or neglect. Respite care provides a safe environment for children and a break for families. Respite care can be provided on an emergent basis for several hours, overnight, or for a few weeks at a time. Care may be provided in the home, a foster home, or a facility in the community such as a crisis nursery or emergency shelter.
- [underlined: Parent education programs]: These prevention programs are commonly didactic and may be delivered via parent groups. Programs typically seek to promote parents’ understanding of children’s developmental needs and typical developmental behaviors, model positive parenting behaviors, improve parents’ capacity to provide nurturing care and problem solve, and increase the use of positive discipline strategies.^248,249^
- [underlined: Community-based prevention programs]: More recently, prevention programs have expanded from a focus on individuals and families to a broader community focus.^97^ Community-based prevention programs attempt to reduce barriers created by a lack of community support and systemic factors that may affect communities. The focus of community-based prevention programs is both to reduce risks and enhance protective factors. Goals may include fostering partnerships among local programs serving young children; mitigating child maltreatment risks across the family, community, organization, and societal levels; and working to create more supportive relationships among community residents. Goals of these programs may also include achieving policy-level changes that increase resources available at the level of clinical care. These programs are most often not primary care–feasible or referable.

#### Recommendations From Other Groups on Interventions to Prevent Child Maltreatment

Appendix A Table 4 summarizes current screening recommendations from other groups.

### CQ 3 What are the effects of primary care–feasible or referable preventive interventions that report on child maltreatment outcomes on social determinants of health? Do primary care–feasible or referable preventive interventions that report on child maltreatment outcomes examine the association between social determinants of health and child maltreatment outcomes?

#### Key Points

- Eighteen of the 25 studies included for this review addressed an SDOH-related outcome; almost all of these 18 studies addressed interventions including a home-visiting component.
- Studies evaluated multiple, diverse SDOH-related outcomes, measured using disparate methods and at multiple time points. The heterogeneity of outcomes and contextual nature of this analysis precluded quantitative synthesis, but the analysis below focuses on signals of benefits, regardless of volume of evidence.
- Overall, at least some interventions reported positive changes in some SDOH outcomes for intervention versus control groups (e.g., well-childcare outcomes, social support). For other outcomes, the studies reported no group differences (e.g., maternal employment, maternal access to care).
- Four studies reported SDOH-related outcomes in subpopulations defined by factors including SES and intensity of intervention. Although subgroup definitions varied, some evidence suggests that groups characterized by higher socioeconomic need experienced greater improvements in SDOH outcomes after receiving child maltreatment interventions than overall study populations.
- One study evaluating a home-visiting intervention addressed associations between SDOH outcomes and child maltreatment outcomes and reported that children of mothers who used more services between baseline and the end of followup (including Head Start and parenting classes) had a higher probability of being reported (substantiated or unsubstantiated reports) as experiencing child maltreatment; the odds of a maltreatment report increased by 1.55 with every additional service used (95% CI, 1.24 to 1.93);^110^ surveillance bias cannot be ruled out.
- The link between improving SDOH and reducing child maltreatment remains unclear.

#### Main Findings

SDOH, the “conditions in the environments where people are born, live, learn, work, play, worship, and age that affect a wide range of health, functioning, and quality-of-life outcomes and risks”^251^ have been linked to poor health outcomes including adverse neonatal effects, cardiovascular disease, poor glycemic control, diabetes and diabetes complications, lower receipt of medication, and poor pediatric cancer survival.^252–260^ Earlier research estimated that approximately 245,000 deaths in the United States were attributable to low education; 176,000 to racial segregation; 162,000 to lack of social support; 133,000 to individual-level poverty; 119,000 to income inequality; and 39,000 to area-level poverty in the year 2000.^261^ More recently, increases in social vulnerability were associated with increased COVID-19 incidence and mortality.^262^

Improving SDOH may ameliorate poor health outcomes; recent systematic reviews have reported mixed effects depending on the social need targeted and type of intervention employed.^263^ SDOH (poverty, housing insecurity, education, uninsurance) have also been associated with child maltreatment specifically,^96^ and social programs that target SDOH such as supplemental nutrition assistance may prevent child maltreatment.^264^

In the context of the overlap between SDOH and risk factors for child maltreatment, uncertainty persists about whether interventions to address child maltreatment may mitigate the risk factors associated with child maltreatment. We sought to understand the effects of interventions that seek to prevent child maltreatment on SDOH and the extent to which studies of such preventive interventions examine associations between SDOH and child maltreatment outcomes.

Commonly cited frameworks addressing SDOH vary in how they conceptualize factors that comprise SDOH. Moreover, SDOH factors are multidimensional and measured in multiple ways. We prioritized the Centers for Disease Control and Prevention (CDC) SDOH domains (economic stability, education access and quality, healthcare access and quality, neighborhood and built environment, and social and community context) to guide the SDOH considered for this CQ. We considered an outcome to be positive/beneficial or negative as implied by the study (i.e., if a study suggested that the change in the outcome was a benefit for group A vs. group B, we reported the outcome as beneficial for group A). We did not consider vaccination as an SDOH outcome in the healthcare access and quality domain given the potential overlap of attitudes toward vaccines/vaccine hesitancy on uptake of vaccinations. We also note that other SDOH-related outcomes (e.g., ED visits, academic attainment) are addressed by key questions and not repeated here.

##### Effects of Child Maltreatment Prevention Interventions on Social Determinants of Health-Related Outcomes

SDOH-related outcomes were frequently addressed in studies of interventions to prevent child maltreatment: 18 of the 25 studies included for this review addressed an SDOH outcome.^110–112,116–121,124,127–133,152^ Interventions typically targeted individuals with risk factors for child maltreatment that overlap with SDOH: homelessness, incarceration, low educational attainment, low SES, lack of social support. Several specifically targeted young mothers or included a majority of teenaged mothers.^110,112,119,121,132^ All but one study^132^ addressed interventions including a home-visiting component; the study without a home-based component evaluated group-based implementation of nurse visiting with nursing support offered in a group setting.^132^ All interventions included some level of referral to social or community services such as food or employment assistance. In addition, comparison arms in eight of 17 studies included referral to services.^110,112,117,120,124,130–132^ Six studies included longer term (>24 months postpartum) followup.^117–119,121,129,131^

Appendix A Table 5 outlines key study findings. Studies addressed multiple SDOH-related outcomes, measured using disparate methods and at multiple time points; overall, studies addressed more than 100 SDOH-related outcomes. We grouped these outcomes into CDC SDOH domains (economic stability, education access and quality, healthcare access and quality, neighborhood and built environment, and social and community context) as applicable. No consistent direction of effects emerged across domains or studies.

Overall, effects of interventions were mixed, with positive changes in some outcomes reported for intervention vs. control groups (e.g., receipt of well-childcare and social support) and no group differences reported for other outcomes (e.g., maternal employment, child enrollment in early education). No study reported negative effects of child maltreatment interventions on SDOH-related outcomes, and direction of intended effect (i.e., whether an outcome is considered a positive or negative effect) could be ambiguous for some outcomes (e.g., length of time receiving government aid, number of community service contacts, receipt of remedial education for children).

###### Economic Stability

Twelve studies reported one or more diverse outcomes (e.g., use of community services or government aid programs, material supports, use of employment services, incarcerations) in this domain. Of these, five studies reported beneficial outcomes for groups receiving an intervention compared with control groups: home-visiting participants reported significantly greater help in accessing transportation (48% vs. 16%), clothing for self (17% vs. 5%) and baby (26% vs. 9%), baby furniture/toys (22% vs. 4%), vs. control participants (p≤0.05) in one study,^120^ while another reported fewer months using food stamps (p=0.004) and Aid to Families with Dependent Children (AFDC) (p=0.01) but no difference in Medicaid use (p=not significant) in home-visited participants (effect sizes ranging from −0.24 to −0.15).^119^ In another study, intervention participants had significantly more community service contacts (mean, 8.7 vs. 7.7: effect size, 0.31);^118^ in a fourth study, Healthy Steps participants had greater odds of receiving community resource information (AOR, 4.23 [95% CI: 3.56 to 5.02]) and greater odds of referral to services including early intervention, marital and family support, and other social or environmental agencies (AOR, 1.44 [95% CI, 1.21 to 1.73]) than control participants.^129^ The final study noted improvements in self-reported access to resources deemed by social workers to be attainable within 6 months (food pantry/program; Supplemental Nutrition Assistance Program; Special Supplemental Nutritional Program for Women, Infants, and Children; discounted telephone service; low-income utility assistance; Emergency Aid to the Elderly, Disabled, and Children; AFDC) in intervention families compared with control (p=0.007, proportions NR).^152^ This study also reported receipt of resources by category: at the 12-month followup, more intervention than control families had heard of, tried to obtain, or successfully obtained utility and phone assistance (12.7% vs. 10.6%, p=0.006) and had received a greater number of resources overall (mean 3.7 vs. 3.2, p=0.03).

Ten studies also reported outcomes in this domain that did not differ between groups: four studies reported no group differences in use of government aid programs such as AFDC;^118,121,131,133^ two reported no differences in use of community services or wanting or needing social services^116^ or accessing food or housing supports.^120^ In another study, hearing about, attempting to obtain, or obtaining food, income, or housing assistance did not significantly differ between intervention and control groups at the 12-month followup.^152^ Scores on the Family Resources Scale did not differ between groups in two studies,^124,131^ and homelessness did not differ in one study.^131^

The number of mothers employed at followup did not differ between intervention and comparison groups in four studies,^110,121,130,131^ and use of employment services did not differ in two studies.^131,133^ Similarly two studies reported that mothers’ assessment of their financial situation^130^ or observers’ assessment of study participants’ financial situations^127^ was not significantly different between groups. Finally, two studies, the Elmira, New York, nurse home-visiting trial and a replication of that trial with low-income women, both with long-term followup, reported no group differences in maternal arrests or incarcerations. The Elmira trial reported fewer, but not statistically significantly fewer, arrests, convictions, days in jail, New York State arrests or convictions among women receiving home visiting for children up to age 2 compared with transportation and screening and control groups (difference in incidence ranging from 0.24 to 9.00; all p=NS).^121^

###### Education Access and Quality

Seven studies reported one or more outcomes in this domain. Studies reporting significant group differences in education access and quality outcomes (n=5) included both child and parent measures. In one study, more home-visiting children were participating in a gifted program at age 7 (5.4% vs. 2.0%; AOR, 2.80; p≤0.01) compared with control group children,^117^ and in another, more home-visited children were attending Head Start, preschool, day care, or early intervention (82% vs. 74.9%; p=0.05).^119^ Another study reported that families receiving the Healthy Steps intervention had greater odds of receiving books to read to children compared with control families (AOR, 29.07 [95% CI, 23.52 to 35.94]), though the percentage of mothers reading to children daily did not differ between groups.^129^ Another study reported no differences in early childhood education attendance but higher scores on overall assessments of early learning and early learning goals in home-visited children compared with usual care (AORs of 1.26 and 1.24; p<0.05).^131,149,150^ One study reported that more mothers had completed at least 1 year of college in the home-visiting group vs. control (OR, 1.96 [95% CI, 1.17 to 3.30]; p<0.01), though the completion of high school did not differ between groups.^110^ Another study similarly reported no group differences in mothers not in education, employment, or training and also no differences in mothers in formal education.^131^ Four studies reported either no significant differences between intervention and control group in use of child learning or education services^116^ or children in remedial programs or special education.^117,119,131^

###### Healthcare Access and Quality

Ten studies reported one or more outcomes in this domain using between-group comparisons; these outcomes included receipt of well-childcare or health insurance, use of or knowledge of contraception, and having a healthcare provider. Four studies reported no significant group differences in receipt of well-childcare,^116,119,127,131^ but well-childcare outcomes improved significantly in intervention groups compared with control in two studies. One reported that more home-visiting participants were up to date with health visits compared with control participants, with small effect sizes (0.20 to 0.25).^120^ One study of the Healthy Steps intervention noted greater odds of receiving well-child visits up to age 24 months (AORs ranging from 1.49 to 2.61) and of referral to services including developmental assessment, allied health, early intervention, and marital or family issues assistance in the intervention vs. control arm (AOR, 1.44 [95% CI, 1.21 to 1.73]).^129^ One^116^ of two studies^116,130^ addressing use of public health nurses, social workers, or home visitors reported no group differences; the second reported that home-visited children had fewer general practitioner (GP) visits or use of health services and more social worker or health visitor contacts than children in the control arm at 12 months, but differences had attenuated by the 18 month followup; the study does not clarify if reduced use of GPs and health services was considered a benefit.^130^

Other healthcare access outcomes included maternal access to care, having a specific provider or practice, health insurance access, and contraception knowledge. The number of women accessing healthcare for themselves improved in the home-visited arm vs. control in one study (45% vs. 30%; p≤0.05),^120^ while another study reported no group differences in maternal use of health services.^130^ Another study reported no differences between intervention and control groups in the number of participants having a specific primary provider,^116^ while a second reported that more children in the Healthy Steps intervention group remained with their pediatric practice than in the control group.^129^ One study reported improvements in the number of children with health insurance in the home-visiting arm compared with control (95% vs. 90%; AOR, 2.05 [95% CI, 1.06 to 4.00]; p<0.05).^116^

Among three studies reporting contraception-related outcomes, one reported significant improvements in the intervention group vs. control in contraception knowledge and use of contraception (adjusted RR, 1.35 [95% CI, 1.09 to 1.68]; p=0.007) at 6 months.^128^ Another reported that intervention participants were more likely to report condom use (OR, 1.61 [95% CI, 1.10 to 2.37]; p<0.05) at 12 months, but at 24 months, differences between groups in use of condoms or hormonal birth control were not significant.^110,134^ Similarly, in the third study, differences in contraceptive use between groups were not significant.^131^

###### Social and Community Context

Six studies reported outcomes in this domain. Two reported more social support in intervention participants compared with those in control groups.^112,131^ One reported longer relationships with the current partner in home-visited women vs. control (effect size, 0.28; p=0.016) and more relationships with employed partners in home-visited women than in control participants (effect size, 0.25; p=0.002).^119^ In another, more home-visiting families used center-based parenting services compared with control participants (48% vs. 39%).^116^ In two other studies, level of partner support and overall social support as well as tangible support, emotional support, and affectionate support or positive social interaction did not differ between groups.^130,132^

##### Effects of Child Maltreatment Prevention Interventions on Social Determinants of Health-Related Outcomes in Populations of Interest

Four studies reported differences in effects on SDOH-related outcomes for specific populations defined by the level of intervention received, socioeconomic factors, or maternal age. Although subgroup definitions varied considerably, some evidence suggests that groups characterized by higher socioeconomic need experienced greater improvements in SDOH outcomes after receiving child maltreatment interventions than overall study populations.

In one study, women who received a medium or high level of home visiting had greater increases in use of health visitors for their own care compared with the control group; this outcome did not differ between groups in the whole sample.^130^ Women who received a medium or high level of home visiting also had greater increases in use of health visitors for the care of their child, greater use of social workers, and decreased use of a GP for childcare compared with the control group; these outcomes were also significantly increased in the home-visiting arm vs. the whole sample.^130^

This study also included analyses of “socially excluded” participants, characterized by measures of social or financial deprivation including receipt of housing or welfare benefits, limited education, and relationship status (lacking a partner). Socially excluded women in the intervention group used health visitors and social workers more frequently for their own care and care of their child compared with socially excluded women in the control group at the 12-month followup; they also had increased use of GPs and hospital doctors for their own care and higher risk of using any health services in the previous month (RR, 1.25 [95% CI, 1.00 to 1.55]) compared with control group at 18 months.^130^ These outcomes generally aligned with those reported for the overall sample.

Another home-visiting study reported outcomes for unmarried women from low-SES households. In contrast to no differences in these outcomes in the whole sample, home-visited, low-income women used fewer months of AFDC or food stamps compared with low-income women in the comparison groups (mean, 60.4 vs. 90.3).^144^ Low-income, home-visited women were employed for a greater number of months and received Medicaid for fewer months vs. low-income women in the comparison groups, though these differences were not statistically significant. Home-visited, low-income women also had significantly fewer arrests, convictions, or days in jail vs. low-income comparison group women at the 15-year followup in one study (difference in incidence ranging from 1.19 to 3.32; all p<0.01); these outcomes did not differ significantly between groups in the whole sample.^144^

In a United Kingdom–based study comparing home visiting with usual care, scores on the Early Years Foundation Stage profile did not differ between home-visited and usual-care children in subgroups defined by maternal employment or participation in education or training or lack of employment/participation in education or training at baseline or deprivation quintile (measured on the Index of Multiple Deprivation); however, in subgroups defined by maternal age (younger than or older than age 16) at recruitment, children of mothers younger than age 16 in the intervention group had higher scores compared with the control group (total point score of 32.4 vs. 28.9; AOR, 3.65 [95% CI, 0.76 to 6.55]; p=0.013). Scores did not differ for children of mothers older than age 16 (total point score of 32.2 in intervention arm vs. 31.8 in control), but the interaction between maternal age groups was significant (p=0.05).^149,150^

In the Healthy Steps study, significantly more high- or middle-income families in the intervention group received children’s books (89% to 93% in high-income group vs. 84% to 85% in middle-income, and 80% to 81% in low-income group) and information on community resources (48% to 54% in high income, 43% to 53% middle income, and 44% to 45% low income) compared with low-income families in the intervention group.^129^ These outcomes aligned with outcomes for the whole sample.

##### Association Between Social Determinants of Health Outcomes and Child Maltreatment Outcomes

Only one study evaluating a home-visiting intervention provided data addressing associations between SDOH outcomes and child maltreatment outcomes. One study reported a moderating effect of the use of community services on reports of child maltreatment.^110^ Children of mothers who used more services (including Head Start and parenting classes) had a higher probability of being reported (substantiated or unsubstantiated reports) as experiencing child maltreatment; the odds of a maltreatment report increased by 1.55 with every additional service used (95% CI, 1.24 to 1.93).

#### Discussion

The studies addressing child maltreatment prevention identified for this CQ reported mixed effects of child maltreatment interventions on SDOH-related outcomes. Some studies reported some moderate effects on SDOH in intervention compared with control groups, particularly on outcomes related to the domain of healthcare access and quality. In several studies, women receiving home-visiting interventions had greater access to care for themselves and their children completed more well-child visits, while other studies reported no differences in these outcomes. Interventions also positively affected access to or use of resources such as food or housing support or education services in some studies. Some studies also reported changes in the social and community context-related outcome of social support. However, many studies also reported no differences in SDOH-related outcomes between groups, and no clear pattern of effects emerges in the studies meeting criteria for this review, which makes drawing firm conclusions about effects of child maltreatment interventions on SDOH-related outcomes challenging. Nearly half of studies explicitly noted providing social services referrals to control participants, and usual community services would presumably have been available to control participants across studies; thus, between-group changes in SDOH outcomes may be muted. Of note, some studies reported that outcomes improved within groups from baseline to followup, but we focused on significant differences between intervention and comparison groups for the CQ. SDOH outcomes were also defined and measured variably, which limits comparability. We did not attempt to assess the reliability or validity of outcome measures. In addition, studies may be subject to a Hawthorne effect in home-visited participants. Studies also measured numerous outcomes, with variable correction for multiple testing.

Despite these limitations, some SDOH outcomes were improved for intervention participants, with some stronger effects in participants with greater socioeconomic needs, which may suggest effects for these interventions beyond prevention of child maltreatment. Moreover, child maltreatment is itself linked to poor SDOH (e.g., poverty, housing instability);^96^ thus, improving SDOH may have positive downstream effects on preventing child maltreatment.

The one study addressing links between improvements in SDOH associated with interventions and maltreatment outcomes specifically reported increased reports of child maltreatment with increasing use of social services, which may suggest surveillance bias with increasing service contacts. Other reviews of home visiting, not restricted to studies specifically addressing child maltreatment outcomes, have reported positive effects of home visiting on SDOH.^265^

Appendix A Table 1 Laboratory and Radiologic Tests Recommended in the AAP Guidelines by Injury Type^*^

Injury Type | Laboratory Testing | Radiologic Testing
Fracture | Bone health testing; 25-hydroxyvitamin D and PTH level; Serum copper, vitamin C, and ceruloplasmin levels; Skin biopsy for fibroblast culture or venous blood for genetic testing | Skeletal survey^†^
Bruise | Hematologic disorders testing | Skeletal survey; Brain imaging
Abdominal Trauma | Liver enzyme test; Pancreatic enzymes test | Skeletal survey; CT scan with contrast
Head Trauma | Complete blood count with platelets; Coagulation testing; D-dimer; Review newborn screening; Urine organic acids | Skeletal survey; CT scan; MRI
Cardiac Injury | Cardiac enzyme test | None

* Adapted from AAP guidelines.

† The skeletal survey consists of a series of x-rays of the arms, legs, head, neck, and trunk to assess for otherwise unknown or healing fractures. The x-rays needed for a complete skeletal survey are determined by the American College of Radiology guidelines.^173^

Abbreviations: AAP=American Academy of Pediatrics; CT=computerized tomography; MRI=magnetic resonance imaging; PTH=parathyroid hormone.

Appendix A Table 2 Reliability and Validity of Actuarial Risk Assessment Tools

Instrument | Study Using the Instrument | Description | Reliability | Validity | Reference Standard
Child Abuse Alert System^227^ | Berger et al (2018; United States)^227^ | Thirty age-specific triggers in the EMR to identify physical abuse | Not reported | Validated in a sample of 226 children <2 years old in a pediatric hospital; Sensitivity was 96.8% (95% CI, 92.4 to 100.0) and specificity was 98.5% (95% CI, 98.3.5 to 98.7); Positive predictive value 26.5% (95% CI, 21.2 to 32.8%) and negative predictive values 99.9% (95% CI, 99.9 to 100.0) | Children’s Hospital of Pittsburgh Child Protection team’s assessment of abuse
Child Abuse Potential Inventory (CAPI)^39,228^ | van der Put et al (2017; systematic review includes multiple locations)^39^ includes 4 studies looking at the validity of CAPI: Ayoub and Milner (1985); Chaffin and Valle (2003); Milner, et al (1984); and Ondersma (2005) | 160-item, self-report measure consisting of a primary clinical scale containing a 77-item Physical Abuse Scale with eight subscales: distress, rigidity, unhappiness, ego, loneliness, problem with child and self, problem with family, and problem with others | Split-half and Kuder-Richardson-20 reliability coefficients range from 0.92 to 0.98^229^; Milner & Wimberly (1986) | Calculated AUCs range from 0.5565 to 0.6895^39^ | Not reported
Diagnostic Index for Physical Child Abuse (DIPAC)^212,230^ | Chang et al (2004; United States)^230^ | 6-item, 15-point scale to identify physical abuse using External Injury Codes | Not reported | Validated in a sample of 11,919 children <3 years old in a pediatric trauma registry; Sensitivity, 72.5%; specificity, 89.1%; AUC, 86.3% | Abuse cases identified from the trauma registry
Instrument for early identification of Parents At Risk for child Abuse and Neglect (IPARAN)^209,212^ | van der Put et al (2017; Netherlands)^209^ | 16-item, 4-point actuarial instrument to identify child abuse and neglect in families with a newborn and answers are self-reported by parents | Not reported | Validated in a sample of 4,692 children <1 year-old during a home visit of families; IPARAN alone: Sensitivity, 61.1%; specificity, 78.6%; AUC, 70.0% (95% CI, 56.7 to 83.2); Nurse clinical judgment alone: Sensitivity, 21.4%; specificity, 96.7%; AUC, 59.1% (95% CI, 42.2 to 75.9); IPARAN combined with nurse clinical judgment: Sensitivity, 66.7%; specificity, 77.4%; AUC, 72.0% (95% CI, 59.3 to 84.7); Difference between IPARAN and IPARAN combined with clinical judgment was not statistically significant | Verified reports of child maltreatment in the family at the Dutch child protective services (CPS) during a 3-year followup period
New South Wales Child Development Study^216^ | Green at al (2022; Australia)^216^ | 14 dichotomous risk indicators, which was reduced to 10 indicators in the final model | Not reported | Validated in a sample of 72,059 children born in New South Wales, Australia between 2002 and 2005 and followed until the age of 13; Mean AUC for full 14 indicators: 0.84 (95% CI, 0.82 to 0.85); for 10 final indicators: 0.83 (95% CI 0.82 to 0.85).; Mean sensitivity for full: 0.72 (SD 0.06); and final: 0.74 (SD 0.05); Mean specificity for full: 0.82 (SD 0.06); and final: 0.80 (SD 0.04); Mean positive predictive value for full: 0.18 (SD 0.03); and final: 0.16 (SD 0.02) | Substantiated child protection reports (according to a “risk of significant harm” threshold) or an out-of-home care placement before age 13–14 years, as recorded in data obtained from the New South Wales Department of Communities and Justice Child Protection records
Pediatric Brain Injury Research Network (PediBIRN-4)^212,231,232^ | Pfeiffer et al (2018; Australia and New Zealand)^231^ | 4-item tool for use in the PICU to identify abusive head trauma (AHT) | Not reported | Validated in a sample of 141 children <3 years old admitted to the hospital with head trauma; In the PICU patients: Sensitivity, 100% (95% CI, 75.0 to 100.0) and specificity, 11% (95% CI, 0.0 to 48.0); In all admitted patients: sensitivity, 96% (95% CI, 82.0 to 100.0) and specificity, 43% (95% CI, 32.0 to 53.0) | Multidisciplinary child protection team consensus
Pediatric Brain Injury Research Network (PediBIRN-4)^212,231,232^ | Hymel et al (2014; United States)^212,232^ | | Not reported | Validated in a sample of 291 children <3 years old in intensive care for head injury; Sensitivity, 96.0% (95% CI, 90.0 to 99.0) and specificity, 43.0% (95% CI, 35.0 to 50.0); Positive predictive value, 0.55 (95% CI, 1.46 to 1.9) and negative predictive value, 0.09 ((5% CI, 0.04 to 0.23); AUC, 78.0% | Definitional criteria for AHT applied by PediBIRN investigators
Pittsburgh Infant Brain Injury Score (PIBIS)^212,233^ | Berger et al (2016; United States)^233^ | 4-item instrument with a 5-point scale to identify AHT | Not reported | Validated in a sample of 1,040 children <1 year-old in the ED; Sensitivity, 93.3% (95% CI, 89.0 to 96.3) and specificity, 53.0% (95% CI, 49.3 to 57.1); AUC, 83.0% (95% CI, 80.0 to 86.0) | Abnormal neuroimaging (head CT or MRI)
Predicting Abusive Head Trauma (PredAHT)^212,234^ | Cowley et al (2015; United Kingdom)^234^ | Instrument to identify AHT in children <3 years of age who have sustained an intracranial injury identified on neuroimaging based on 6 clinical features | Not reported | Validated in a sample of 198 children <3 years old with an intracranial injury in the PICU; Sensitivity, 72.3% (95% CI, 60.4 to 81.7) and specificity, 85.7% (95% CI, 78.8 to 90.7); AUC, 88.0% (95% CI 82.3 to 92.6) | Previously determined as abusive head trauma (AHT) or non-abusive head trauma (nAHT) based on multidisciplinary assessment or court proceedings, social and historical factors beyond the presenting injury, a perpetrator admission or independently witnessed abusive incident.
Predicting Abusive Head Trauma version 2 (PredAHT-2)^235^ | Pfeiffer et al (2019; Australia and New Zealand)^235^ | Instrument to identify abusive head trauma in children <3 years of age who have sustained an intracranial injury identified on neuroimaging based on 6 clinical features. Version 2 enables a probability calculation when information regarding any of the six features is absent | Not reported | Validated in a sample of 87 cases of children <3 years old admitted to the hospital with an intracranial injury; Sensitivity, 74% (95% CI 54 to 89) and specificity, 87% (95% CI 71 to 94); Positive predictive value, 77% (95% CI, 56 to 91) and negative predictive value, 85% (95% CI, 71 to 94); AUC, 0.80% (95% CI, 0.68 to 0.92) | Multidisciplinary child protection team case review
Predictive Risk Modeling^215^ | Vaithianathan et al (2013; New Zealand)^215^ | 132 predictor variables related to the demographics, SES, and histories of the primary caregiver, partner, and child | Not reported | Validated in a sample of 57,986 children enrolled in New Zealand’s public benefit system before age 2 years; AUC, 76% (95% CI, 75.7 to 77.1) | Substantiated report of maltreatment based on CPS data by age 5 years
Screening Index for Physical Child Abuse (SIPCA)^212,236^ | Chang et al (2005; United States)^236^ | 6-item, 15-point scale to identify physical abuse using ICD-9 codes | Not reported | Validated in a sample of 58,558 children <14-years-old discharged from a hospital with at least 1 injury code; Sensitivity, 86.6% and specificity, 80.5%; AUC, 89.0% | Prevalence of child abuse cases in this dataset was compared externally with the finding from the initial development dataset as well as internally across different types of pediatric trauma centers
Enhanced Eligibility Screening for Family Connects^208^ | Dodge et al (2021; United States)^208^ | Uses 4 demographic factors (i.e., health insurance of the infant, first-time birth, teen parent, no high school diploma) and 4 clinical factors (i.e., need in domains of healthcare, parenting/childcare, home safety, and parent mental health) with 3 domains each completed by nurse during home visit | Interrater independent agreement on scoring, K=0.69 | Validated in a sample of 201 families in the Family Connects RCT; Any demographic risk:; For CPS investigations: sensitivity, 0.947 and specificity, 0.166 and accuracy, 0.313.; For EMC: sensitivity 0.893; specificity, 0.203; accuracy, 0.622; Any clinical risk:; For CPS investigations: sensitivity, 0.703; specificity, 0.642; accuracy, 0.653.; For EMC: sensitivity 0.500; specificity, 0.692; accuracy, 0.577 | Child maltreatment investigations as recorded in the State CPS registry or emergency medical care for injury or illness

Abbreviations: AHT=abusive head trauma; AUC=area under the curve; CAPI=Child Abuse Potential Inventory; CI=confidence interval; CPS=child protective services; CT=computerized tomography; DIPAC=Diagnostic Index for Physical Child Abuse; ED=emergency department; EMC=emergency medical care; EMR=electronic medical record; ICD-9=International Classification of Diseases, Ninth Edition; IPARAN=Instrument for early identification of Parents At Risk for child Abuse and Neglect; MRI=magnetic resonance imaging; PediBIRN=Pediatric Brain Injury Research Network; PIBIS=Pittsburgh Infant Brain Injury Score; PICU=pediatric intensive care unit; PredAHT=Predictive Abusive Head Trauma; RCT=randomized controlled trial; SES=socioeconomic status; SIPCA=Screening Index for Physical Child Abuse

Appendix A Table 3 Reliability and Validity of Clinical Risk Assessment Tools Interventions

Instrument | Study Using the Instrument | Description | Reliability | Validity | Reference Standard
BabyFirst Screen^217^ | Brownell et al (2011, Canada)^217^ | 23-weighted-item questionnaire administered at birth to parents and completed by nurses relating to biological, psychological, and social risk factors for maltreatment. | Not reported | Validated in a sample of 30,486 infants born in Manitoba, Canada from 2000 to 2002; Sensitivity, 77.6% and specificity, 83.3%; Positive predictive value, 10.9% and negative predictive value, 99.3%; False-positive rate, 16.7% and false-negative rate, 22.4%; Accuracy, 83.2% | Reports of out-of-home placement from provincial ministry of family services records
Burns Risk assessment for Neglect or abuse Tool (BuRN-Tool)^212,237,238^ | Kemp et al (2018; United Kingdom)^237^ | 7-item instrument to identify physical abuse completed by nurses or doctors in a pediatric ED | Not reported | Validated in a sample of 1,327 children <16 years old with a burn in the pediatric ED; Sensitivity, 87.5% (95% CI, 61.7 to 98.4) and specificity, 81.5% (95% CI, 77.1 to 85.4); Positive likelihood ratio, 4.7 (95% CI, 3.6 to 6.3) and negative likelihood ratio, 0.2 (95% CI, 0.04 to 1.6); Positive predictive value, 17.5 (95% CI, 9.9 to 27.6) and negative predictive value, 99.3 (95% CI, 97.6 to 99.9); AUC, 0.87% (95% CI, 0.83 to 0.90) for scalds and 0.85% (95% CI, 0.81 to 0.88) for non-scalds | Rate of referrals to a children’s social care team
Burns Risk assessment for Neglect or abuse Tool (BuRN-Tool)^212,237,238^ | Hollen et al (2020; United Kingdom)^238^ | 7-item instrument to identify physical abuse completed by nurses or doctors in a pediatric ED | Interrater reliability Krippendorff’s alpha for 1,293 score was 0.85 | Validated in a sample of 2,443 children <16 years old with a burn in the pediatric ED; Sensitivity, 72.1% (95% CI, 62.8 to 80.2) and specificity, 82.7% (95% CI, 80.3 to 85.0); Positive likelihood ratio of 4.2 and negative likelihood ratio 0.3; AUC, 0.81% (95% CI, 0.79 to 0.83) | Proportion of cases referred to children’s social care or the hospital safeguarding team
Early Risks of Physical Abuse and Neglect Scale (ERPANS)^212,218^ | Schols et al (2019; Netherlands)^218^ | 31-item, 4-point, nurse-rated tool to identify physical abuse and neglect | Internal consistency (Cronbach’s α=0.94), interrater reliability (across all items: r=0.97) | Validated in a sample of 1,257 children <1 year-old during a home visit of families | Child abuse reports in the child’s electronic files which include referrals to service agencies and reports to the child protection agency
Escape Instrument^212,239^ | Louwers et al (2014; Netherlands)^239^ | 6-item instrument to identify physical abuse built to be completed by ED nurse during triage irrespective of patient’s reason for ED visit | Not reported | Validated in a sample of 18,275 children <18 years old who visited the ED; Sensitivity, 80.0% (95% CI, 67.0 to 89.0) and specificity, 98.0%; Positive predictive value, 0.10 (95% CI 0.08 to 0.14) and negative predictive value, 0.99 | Expert Child Abuse Team panel
INTOVIAN^212,219^ | Ezpeleta et al (2017; Cyprus, Greece, Spain)^219^ | 9-item questionnaire to identify physical abuse, emotional abuse, or neglect administered by medical personnel | Internal consistency, Cronbach’s alpha 0.79 | Validated in a sample of 219 children <3 years old in public health centers | Clinical judgment
Kempe Family Stress Inventory (KFSI) or Family Stress Checklist^*^,^39,220,221^ | Murphy et al (1985, United States)^221^ | 10-item rating scale including psychiatric and criminal history, childhood history of care, emotional functioning, attitudes toward and perception of children, discipline of children, and level of stress in parent’s life; Original checklist developed to evaluate parents with known abuse or neglect | Not reported | Validated in a sample, in 197 women 2 to 2.5 years after baseline measure; Validation of 38 with positive scores (possibly scores ≥40, not clearly specified) and 157 without positive scores (threshold not specified; possibly includes 100 women with scores 0–10 and 25–35); 80% sensitivity and 89.4% specificity, sample appears to exclude intermediate risk category; Reported 52.5% positive predictive value, 96.8% negative predictive value; Calculated AUC 0.8470^39^ | Identified abuse, neglect, or failure to thrive from chart review (specifics not defined)
Kempe Family Stress Inventory (KFSI) or Family Stress Checklist^*^,^39,220,221^ | Hawaii Healthy Start^220^ | | Not reported | Validated in a sample of 287 families (96 low risk with KFSI scores of 20 or below and 191 high risk with scores of 25 or above); Calculated 6-month followup: sensitivity, 89% and specificity, 28% with a positive predictive value, 37% and negative predictive value, 85%; Calculated 12-month followup: sensitivity, 84% and specificity, 35% with a positive predictive value, 25% and negative predictive value, 89% | CAPI scores
Kempe Family Stress Inventory (KFSI) or Family Stress Checklist^*^,^39,220,221^ | Oregon HFA^220^ | | High reliability reported in HFA sites in Oregon for classifying parents on individual characteristics in terms of levels of risk (r=0.93) but does not provide answer to whether families would receive the same score by independent evaluations^220^ | Validated in a sample of 2,870 families; 25 cutoff: sensitivity, 96% and specificity, 21% with a positive predictive value, 3% and negative predictive value, 99.7%; 40 cutoff: sensitivity, 69% and specificity, 42% with a positive predictive value, 4.5% and negative predictive value, 99.7% | Confirmed child maltreatment reports (about 50% of the reports were made by the HFA/study home visitors)
Maternal History Interview (MHI-2)^39,113,222^ | Brayden et al (1993, United States)^113^ | Series of open-ended questions that are designed to predict abuse, neglect, or nonorganic failure to thrive. Participant answers are scored by best fit into predetermined categories. Subscale scores are developed for knowledge of parenting skills and philosophy about discipline, personality (extroversion, aggressiveness, dependency, and self-image), positive and negative feelings about the pregnancy, the mother’s perception of her nurture as a child, a truncated version of the Life Stress Inventory for both mother and father, and a “lie” scale (to detect attempts to respond only with socially appropriate answers) | Four interviewers trained to administer the MHI-2 and score answers at 90% or greater interobserver agreement; Internal consistency alpha, 0.80 | Validated in a sample of 1,154 families seen for prenatal care at Metropolitan Nashville General Hospital; Sensitivity of 55.6% and positive predictive value of 6.6% for physical abuse; Increased risk of neglect or separation were not predicted by the MHI-2; Calculated AUCs 0.5385 to 0.6470^39^ | Target children and siblings followed through 36 months for reports of physical abuse, neglect, sexual abuse, or mother–child separation in public agency documents (excluding “unsubstantiated reports, grudge or crank reports, and those without evidence of trauma”). Siblings were included only if their first abuse report occurred after the interview
Maternal History Interview (MHI-2)^39,113,222^ | Altemeier et al^†^ (1984, United States)^222^ | | Four research assistants trained to maintain an interrater agreement of 90% or greater | Validation study on 1,400 expectant mothers screened at a prenatal clinic; Calculated AUCs, 0.5849 to 0.7620^207^ | Target children and siblings followed for reports of abuse in Juvenile Court and Department of Human Services computer records (excluding “unsubstantiated reports, grudge or crank reports, and those without evidence of trauma”)
Ontario Risk Assessment Tool^207,223^ | Barber et al (2008; Canada)^223^ | Consensus tool of 22 risk factors that are rated on a 5-point scale to predict future risk for multiple forms of maltreatment | Reliability tested in a sample of 132 cases in the Children’s Aid Society database; Internal consistency, Cronbach’s alpha 0.73 for caregiver category but under 0.7 for the 4 other categories; Interrater reliability evaluated using Cohen’s Kappa. Kappa scores greater than would be expected by chance alone in eight of the 22 risk items | Validated in a sample of 1,118 cases in the Children’s Aid Society database; Calculated AUC, 0.5000^207^ | Substantiated cases of maltreatment recurrence within 18 months of case closure
Torso, Ear, and Neck Bruising Clinical Decision Rule (TEN-4 BCDR or TEN-4-FACESp)^212,226,240^ | Pierce et al (2010; United States)^240^ | Instrument to identify physical abuse using bruising to torso, ear, or neck (TEN), frenulum, angle of jaw, cheeks (fleshy), eyelids, subconjunctivae (FACES), and patterned (p). The 4 represents any bruising anywhere to an infant 4.99 months or younger | Not reported | Validated in a sample of 95 children <4 years old with abusive or accidental trauma in the PICU; Sensitivity, 97.0% and specificity, 84.0% | Multiple criteria for abuse were used: (1) trauma registry categorized the trauma as abuse; (2) hospital medical team determined the injuries to be highly suggestive of abuse; (3) stated cause of injury did not account for the type, severity, and/or number of injuries; (4) history of trauma was absent, vague, or changing; or (5) State social services that determined the patient was abused
Torso, Ear, and Neck Bruising Clinical Decision Rule (TEN-4 BCDR or TEN-4-FACESp)^212,226,240^ | Pierce et al (2021; United States)^226^ | | Interrater reliability: Kendall coefficient, 0.89 (95% CI, 0.87 to 0.91) | Validated in a sample of 2,161 children <4 years old who presented to the ED with bruising; Sensitivity, 95.6 (95% CI, 93.0 to 97.3) and specificity, 87.1% (95% CI, 85.4 to 88.6); Positive predictive value, 63.9% (95% CI, 60.3 to 67.7) and negative predictive value, 98.8% (95% CI, 98.1 to 99.3) | Consensus judgment of a multidisciplinary expert panel composed of pediatric emergency medicine and child abuse pediatrics physicians and a biomechanical engineer, all with expertise in pediatric injury
Screening instrument for Child Abuse and Neglect (SCAN)^241^ | Hoedeman et al (2022; Netherlands)^241^ | 4-item questionnaire administered by ED nurses or physicians to identify child abuse and neglect | None reported | Validated in a sample of 24,963 children <18 years old presenting to eight EDs from the combination of 3 studies; Pooled AUC of 0.75 (95% CI, 0.63 to 0.87) in cross validation; AUCs range from 0.61 to 0.79 depending on imputation for unknown outcomes | Two studies used consensus diagnosis of (suspected) child maltreatment by the local multidisciplinary child abuse team. One study was defined as physical child abuse and/or neglect based on the decision of at least two out of three experts, blinded for their mutual decision
SPUTOVAMO-R^212,242^ | Sittig et al (2011; Netherlands)^242^ | 6-item questionnaire to identify physical abuse completed by emergency room providers | Not reported | Validated in a sample of 4,290 children <7 years old with a physical injury in the ED; Positive predictive value, 0.03 (95% CI, 0.006 to 0.085) and negative predictive value, 1.0 (95% CI, 0.094 to 1.0) | Expert panel consensus
SPUTOVAMO-R2^243^ | Schouten et al (2017; Netherlands)^243^ | 5-question checklist to identify child abuse completed by provider. A revised version of SPUTOVAMO-R for out-of-hours primary care locations (OPCs) instead of EDs | Not reported | Validated in a sample of 50,671 children <18 years old attending an OPC; Sensitivity, 14.8% (95% CI, 7.0 to 26.2) and specificity, 98.2% (95% CI, 97.8 to 98.5); Positive predictive value, 8.3 (95% CI, 3.9 to 15.2) and negative predictive value, 99.1 (95% CI, 98.8 to 99.3) | CPS report within 10 months of the encounter
Symptoms Associated with Sexual Abuse (SASA)^212,224^ | Wells et al (1997; United States)^224^ | 12-item structured parent interview questionnaire to identify sexual abuse | Internal reliability: Chronbach’s alpha, 0.83 | Validated in a sample of 121 children <15 years old with 3 subgroups: substantiated sexual abuse where perpetrator confessed; alleged abuse (evaluated in a sexual abuse clinic but perpetrator didn’t confess); non-abused; Sensitivity, 90.9% and specificity, 88.5%; Positive predictive value, 77% and negative predictive value, 96% | CPS referral

* KFSI was designated as an actuarial tool in the meta-analysis,^39^ but it’s a psychosocial interview and requires clinical judgment so we have included it with the clinical instruments.

† MHI-2 is designated as both actuarial and clinical in the meta-analysis.^39^

Abbreviations: AUC=area under the curve; BuRN-Tool=Burns Risk assessment for Neglect or abuse Tool; CI=confidence interval; CPS=child protective services; ED=emergency department; ERPANS=Early Risks of Physical Abuse and Neglect Scale; FACESp=frenulum, angle of jaw, cheeks (fleshy), eyelids, subconjunctivae, and patterned; HFA=Healthy Families America; KFSI=Kempe Family Stress Inventory; MHI=Maternal History Interview; OPC=out-of-hours primary care locations; PICU=pediatric intensive care unit; SASA=Symptoms Associated with Sexual Abuse; SCAN= Screening instrument for Child Abuse and Neglect; TEN-4 BCDR=Torso, Ear, and Neck Bruising Clinical Decision Rule

Appendix A Table 4 Current Recommendations From Other Organizations

Organization, Year | Recommendation
American Academy of Family Physicians 2013^98^ | Screening/Intervention; - Notes that evidence is insufficient that any specific screening strategy or behavioral intervention produces better health outcomes than clinician awareness and evaluation of potential signs of abuse.; - Provides a list of steps primary care physicians can take to prevent child abuse, which includes screening for risk factors or problems, with a link to the American Academy of Pediatrics’ recommendations.
American Academy of Pediatrics 2010, 2015, 2021 | Universal Prevention; - 2014 (published in October 2010, reaffirmed in January 2014).^101^; - Strongly recommends physician involvement in preventing child maltreatment in the context of the pediatrician’s unique role in identifying and protecting children and recommends offering anticipatory guidance and referring families to programs and resources to promote safe, stable, nurturing relationships with the aim of preventing maltreatment.^101^; - Notes that universal prevention of child maltreatment must begin with an approach that assesses the caregivers’ strengths and deficits and connects the family with community resources that will protect the dependent children before abuse or neglect occurs.; 2015 (published in April 2015)^166,^ ^p. e1348- e1349^; - Focuses on management of suspected physical abuse.; - Notes that, “Child abuse prevention is important but difficult and requires efforts that are broad and sustained. The pediatrician, as a trusted adviser to parents, caregivers, and families about health, development, and discipline, can play an important role in abuse prevention by assessing caregivers’ strengths and deficits, providing education to enhance parenting skills, connecting families with supportive community resources that address parent and family needs, and promoting evidence-based parenting practices that are nurturing and positive.” This statement cites the 2010 clinical statement.; 2021 (published in July 2021)^102,^ ^p. 1451^; - Pediatricians are uniquely situated to prevent child abuse and neglect because of their relationship with families across the lifespan. Pediatricians should learn the signs and symptoms of maltreatment, obtain a thorough history when they see signs and symptoms, and report suspected cases of abuse. It also recommends advocating for supports for families and referring to home visiting and other support programs as a prevention strategy.
Canadian Task Force on Preventive Health Care 2000^99^ | Screening; - Unacceptable rate of predictive value (e.g., positive predictive value of 6.6% and a sensitivity of 55.6% for physical abuse in one study).; - D recommendation for screening: “because of the high false-positive rates of screening tests for child maltreatment and the potential for mislabeling people as potential child abusers, the possible harms associated with these screening maneuvers outweigh the benefits.”; Interventions; - Good evidence to include referral in the periodic health examination for home visitation by nurses (A).; - Insufficient evidence to include referral in the periodic health examination for prevention of child maltreatment (C) for comprehensive healthcare; parent education and support; or home-based services, including case management, education, and psychotherapy.; - No additional evidence to alter recommendation (C) in 1993 update for programs for children aimed at preventing sexual abuse and abduction.
Community Preventive Services Task Force, 2013^250^ | Screening; - None; Interventions; - Noted strong evidence of effectiveness for early childhood home visitation to prevent violence against the child (maltreatment): Recommended.; - Also noted that “programs delivered by professional visitors (i.e., nurses or mental health workers) seem more effective than programs delivered by paraprofessionals, although programs delivered by paraprofessionals for 2 years also appear to be effective in reducing child maltreatment.”

Appendix A Table 5 Key Social Determinants of Health-Related Outcomes in Studies of Child Maltreatment Prevention Interventions

Author, Year, Country | Population | Group (N Randomized) | Key SDOH Findings
Barlow 2007^112^; U.S. | Pregnant individuals at risk for poor parenting | Intensive home visiting (68); Standard services for “vulnerable” families (63) | Social Support Questionnaire scores declined (worsened) more in control group vs. home visiting at 6 and 12 months (p<0.004)
Barnes 2017^132,151^; U.K. | Pregnant individuals (gestation 16–20 weeks), age <20 years with one or more previous live births or age 20–24 years plus low educational qualifications | Group-based Family Nurse Partnership (99); Usual care (67) | No significant differences in overall social support between groups (adjusted effect estimate, −0.45 [95% CI, −5.45 to 4.59]; p=0.85) or in tangible support, emotional support, affectionate support, or positive social interaction subscales
Duggan 2007^116,137^; U.S. | At-risk families (high risk on Kempe Family Stress Checklist) | Home visiting (162 families); Control (163 families) | More home-visited children had healthcare coverage at followup compared with control (95% vs. 90%; AOR, 2.05 [95% CI, 1.06 to 4.00]; p<0.05); No differences in receipt of well-childcare, having specific primary care provider (AORs ranging from 0.76 to 1.01); No difference in use of community services to address mental health or substance use (30% of home-visiting group vs. 26% of control; p=0.38) or partner violence (9% of home-visiting group vs. 6% control; p=0.28); No differences in wanting or needing social services in prior year (WIC, emergency food, food stamps, TANF, child support enforcement), AORs ranging from 0.62 to 1.53; More home-visiting families used center-based parenting services vs. control (48% vs. 39%; AOR, 1.45 [95% CI, 1.05 to 2.02]; p<0.05); No differences in use of infant learning program or home-based parenting services or receipt of public health nursing services (AORs, 0.61 to 1.98)
DuMont 2008^117,138^; U.S. | At-risk families (high risk on Kempe Family Stress Checklist) | Home visiting (621); Control (information + referral to appropriate community services) (633) | In both groups, 80% received referrals to community services. Percentage of families with at least 1 referral by service:; “Concrete” services (not defined): 52.5; Nutrition services: 35.4; Employment, training, education: 33.3; Family and social support: 32.6; Healthcare services: 29.5; Counseling and support services: 19.3; Department of Social Services/Human Resources Administration services: 16.7; Other services (not defined): 31.0; More home visiting than control children were participating in a gifted program at age 7 (5.4% vs. 2.0%; AOR; 2.80; p≤0.01); Fewer home-visited children were receiving remedial services (32.8% vs. 33.3%), special education (12.3% vs. 16.7%), or repeated a grade (12.3% vs. 12.6) at age 7, all p=NS; No differences in costs for government supported programs (food stamps, public assistance, preventive services [undefined]), Medicaid delivery and hospitalizations from random assignment to child’s 7^th^ birthday (all p=NS)
Easterbrooks 2013^110,134,135^ | First-time parents younger than age 21 | Home visiting (517); Control (referral to services and child development information) (320) | At 24-month followup, more intervention participants completed ≥1 year of college vs. control (OR, 1.96 [95% CI: 1.17 to 3.30], p<0.01); No group differences in completion of high school or full- or part-time employment (ORs, 0.92 and 0.81); At 24 months, no significant group differences in use of condoms or hormonal birth control, but at 12 months, intervention participants more likely to report condom use vs. control (OR, 1.61 [95% CI, 1.10 to 2.37]; p<0.05); In moderator analyses, higher probability of being reported as victim of child maltreatment (substantiated and unsubstantiated reports) for children whose mothers used more services from pregnancy to 12-month followup (e.g., Early Head Start, parenting classes): odds of maltreatment report increased by 1.55 with every additional service used (95% CI, 1.24 to 1.93)
Fergusson 2005^118,140^; New Zealand | At-risk families (≥2 risk factors) | Home visiting (220); Control (223) | Significantly higher (all p<0.05) percentage of home-visited participants vs. control were up to date with health visits at 36-month followup:; Mean # GP visits (23.4 vs. 20.7); Percentage up to date with well-child checks (41.9 vs. 30.1); Percentage enrolled with dental nurse/dentist (72.3 vs. 62.8); Effect sizes ranged from 0.20 to 0.25; Significantly greater use of community or education services in intervention arm vs. control (all p<0.05) at 36-month followup:; Mean duration early child education (16.4 vs. 13.6 mo, effect size=0.22); Mean number community service contacts (8.7 vs. 7.7, effect size=0.31); At 9-year followup, no significant group differences in hardship measures (intervention vs. control):; Mean number hardship factors (3.52 vs. 3.46); Mean adverse life events score (10.03 vs. 9.97); Percentage welfare dependent (59.5 vs. 56.8); Mean debt (NZ dollars) (5,248 vs. 4,492)
Green 2017^133^; U.S. | At-risk first-time parents (2 or more risk factors on New Baby questionnaire) | Home visiting (1,438); Control (1,289) | Receipt of services (home visiting vs. control, ITT analysis); Ever received TANF (41.7% vs. 40.8%; OR, 1.04; p=0.60); Received 1^st^ TANF post-randomization (45.2% vs. 39.1%; OR, 1.78; p=0.04); Mean days on TANF (176.1 vs. 169.6; p=0.08); Ever received SNAP (84.6% vs. 82.3%; OR, 1.20; p=0.08); Receiving SNAP 1^st^ time post-randomization (17.7% vs. 18.3%; OR, 1.12; p=0.32); Mean days on SNAP (475.1 vs. 461.2; p=0.17); Ever received childcare subsidy (10.7% vs. 11.3%; OR, 0.94; p=0.59); Received childcare subsidy 1^st^ time post-randomization (79.6% vs. 82.8%; OR, 1.20; p=0.53); Mean days with childcare subsidy (19.5 vs. 19.8; p=0.96); Ever received employment services (30.6% vs. 30.2%; OR, 1.03; p=0.72); Received employment services 1^st^ time post-randomization (53.9% vs. 54.7%; OR, 1.04; p=0.78); Mean days with employment services (98.9 vs. 94.4; p=0.42); Receipt of services (families receiving home visit vs. propensity score–matched controls); Ever received TANF (43.6% vs. 38.6%; OR, 1.22; p=0.09); Mean days on TANF (192.8 vs. 153.9; p<0.01); Received 1^st^ TANF post-randomization (45.9% vs. 42.5%; p=0.43); Mean days on SNAP (487.1 vs. 449.6; p=0.03)
Guyer 2003^129,147^; U.S. | Families of newborns (<4 weeks) | Intervention (randomized and quasi-experimental sites) (2,963 infants); Control (randomized and quasi-experimental sites) (2,602 infants) | 36-month followup; Greater odds of receiving community resource information in intervention vs. control arm (AOR, 4.23 [95% CI, 3.56 to 5.02]; Greater odds of receiving books to read to children in intervention vs. control arm (AOR, 29.07 [95% CI, 23.52 to 35.94]); More high- or middle-income families in intervention group received children’s books and information on community resources compared with low-income participants; No between-group difference in percent of mothers reading to children every day, though more higher income mothers read to children every day in both groups; Greater odds of referral to non-medical services including developmental assessment, allied health, early intervention, family issues in intervention vs. control arm (AOR, 1.44 [95% CI, 1.21 to 1.73]); Greater odds of receiving well-child visits at age 1–24 months in intervention vs. control arm (AORs ranging from 1.49 to 2.61); higher percentages of intervention vs. control children within low-, middle-, and high-income subgroups had age-appropriate well-child visits; 5.5-year followup; 65% of intervention children vs. 61% of control children remained at the pediatric practice (p=0.04)
Kitzman 1997^119,141,142^; U.S. | At risk individuals <29 weeks pregnant | Home visiting up to child age 24 months (228); Control (transportation and referral services) (515) | 24-month followup; No significant differences in well-child visits at (mean 4.6 in home visiting group vs. 4.8 in control); No significant differences in mean months worked or months on AFDC at 12 months or 24 months (mean differences ranging from −0.5 to 0.7); Age 6 followup; Significantly longer duration with current partner in home-visited arm vs. control (effect size, 0.24); Fewer months using food stamps (p=0.004), AFDC (p=0.01), Medicaid (p=NS) in home-visited arm vs. control (effect sizes ranging from −0.24 to −0.15); No significant differences in economic status of mother occupation or partner occupation among home-visited mothers vs. control (p=NS); More children in home-visited group vs. control attended Head Start, preschool, day care, early intervention (82% vs. 74.9%; p=0.05); Age 9 followup; No differences in special education placement between groups: 2.3% of comparison group and 2.2% of home-visited group had a special education placement in grades 1–3 (OR, 0.98 [95% CI, 0.36 to 2.65]; p=0.97); Home-visited mothers had longer relationships with current partner than control (effect size, 0.28; p=0.016); more home-visited participants had relationships with employed partners vs. control (effect size, 0.25; p=0.002); Home-visited participants had fewer months/year AFDC/TANF and food stamps from birth to child age 9 (effect sizes ranging from −0.17 to −0.14; p≤0.008); More maternal arrests and mothers jailed in home-visited group vs. control (p=NS), 6- to 9-year followup
Larson 1980^127^; Canada | Pregnant individuals age 18–35, low SES | Prenatal home visit, hospital visit, postpartum home visits up to age 15 months (NR); Home visits up to age 15 months (NR); Control (NR); 115 total at baseline | No differences among all groups in well-child visits at 6, 12, or 18 months; No differences in observed financial problems between groups receiving home visits at 12 months or 15 months of age
Lowell 2011^111^; U.S. | Families with children 6–36 months old with social–emotional or behavioral problems or parents with psychosocial risk factors on the Parent Risk Questionnaire | Child FIRST intervention (78); Usual care (79) | At the 6- and 12-month followups, significantly greater percentage of “wanted social services received” in the intervention group vs. control (91% vs. 33% at 12 months); significantly greater proportion needs met in each domain in intervention arm vs. control (early education 88% vs. 26%, family support 83% vs. 9%, adult mental health 92% vs. 7%, social services 93% vs. 56%, medical services 98% vs. 78%, adult education 62% vs. 9%, concrete needs 89% vs. 16%; p<0.001); Child FIRST families received mean of 14.7 (SD 5.4) wanted services vs. usual care (5.1, SD 2.4)
Marcenko 1994^120^; U.S. | Pregnant individuals with risk of out-of-home child placement based on history of one of the following substance abuse, homelessness, domestic violence, psychiatric illness, incarceration, HIV, lack of social support | Home visiting (125); Control (100) | Home-visited participants reported significantly greater help in accessing transportation (48% vs. 16%), clothing for self (17% vs. 5%) and baby (26% vs. 9%), baby furniture/toys (22% vs. 4%), and healthcare vs. control participants (45% vs. 30%); all p≤0.05; No significant differences between groups in assistance with food and housing; Significant increase in total social support home visiting participants received between baseline and followup (p<0.005); no change for control group
Olds 1986^121,143,144^; U.S. | Actively recruited pregnant individuals (<25 weeks gestation) with no previous live births and a sociodemographic risk factor (younger than age 19, unmarried, low SES) but any pregnant individual (<25 weeks gestation) requesting to enroll could do so | Nurse home visiting during pregnancy and up to child age 2 and transportation and screening (116); Nurse home visiting during pregnancy and transportation and screening (100); Transportation and screening (94); Control (infant developmental screening) (90) | 15-year followup; Fewer months of AFDC, food stamps, Medicaid in group visited up to age 2 vs. control and transportation and screening groups combined (p=NS); Greater number months employed in group visited up to age 2 vs. control and transportation and screening groups combined (p=NS); Fewer arrests, convictions, days in jail, New York State arrests or conviction among women receiving home visiting up to age 2 compared with transportation and screening and control groups (difference in incidence ranging from 0.24 to 9.00; all p=NS); In low-SES unmarried subsample significantly fewer months of AFDC, food stamps in group visited up to age 2 vs. low-SES unmarried women in the control and transportation and screening groups combined (p<0.01); nonsignificantly greater months employed and non-significantly fewer months receiving Medicaid in group visited up to age 2 vs. control and transportation and screening groups combined; In low-SES, unmarried sample, significantly fewer arrests, convictions, days in jail, New York State arrests or convictions among women receiving home visiting up to age 2 compared with low-SES unmarried women in transportation and screening and control groups (difference in incidence ranging from 1.19 to 3.32; all p<0.01)
Quinlivan 2003^128^; Australia | Pregnant individuals younger than age 18 | Home visiting (65); Usual care (71) | Greater contraception knowledge in intervention arm vs. usual care at 6-month assessment (p=NS); No differences in contraception use at hospital discharge but greater use in intervention arm vs. usual care at 6-month assessment (ARR, 1.35 [95% CI, 1.09 to 1.68]; p=0.007)
Robling 2016^131,149,150^; U.K. | Nulliparous individuals, <25 weeks gestation, age 19 or younger | Home visiting (823); Usual Care (822) | At 24 months, no significant differences between groups in use of childcare; use of day nursery, children’s center or toddler group; contraceptive use; primary care consultation; Family Resources score; use of social worker, contacts with employment adviser; mothers not in education, employment, or training; mothers in formal education; mothers in paid employment; mothers receiving State benefits or other financial support; mothers who were homeless from baseline to 24 months; referrals of child to social services; No significant group differences in antenatal care checkups or planned visits to day assessment units; More intervention participants vs. control reported high level of social support at 18 and 24 months (AOR, 1.50 [95% CI, 1.06 to 2.12]; p=0.02); No differences in Early Education attendance up to 4 years; more children in usual-care arm vs. intervention received special education (33% vs. 29%; absolute difference, −3.9%; AOR, 0.83 [95% CI,0.67 to 1.03]; p=0.097); More children in the home-visiting arm compared with control had “good level of development” overall scores on early learning assessments (AOR, 1.26 [95% CI, 1.03 to 1.55]; p=0.026) and in early learning goals (AOR, 1.24 [95% CI, 1.01 to 1.52]; p=0.043); Scores on the Early Years Foundation profile were improved in the intervention arm vs. control in subgroup of children whose mothers were younger than age 16 at baseline; total point score, 32.4 vs. 28.9; AOR, 3.65 (95% CI, 0.76 to 6.55); p=0.013; p value for interaction between mother <16 and mothers >16 subgroups, 0.046; Early Years Foundation scores did not differ between intervention and control arms for subgroups defined by maternal age >16; maternal employment, education, or training status at baseline; deprivation quintile measured on the Index of Multiple Deprivation
Sege 2015^152^; U.S. | Families of newborns <10 weeks old receiving care at one pediatric primary care clinic | Collaborative clinician+family specialist primary care visit, family specialist home visits, and other contacts (text, phone, email, in-person) (167); Usual care (163) | 6-month followup; More intervention vs. control participants had access to resources (food assistance, utility assistance, Emergency Aid to the Elderly, Disabled, and Children, Transitional Aid to Families With Dependent Children) deemed likely to be attainable within 6 months by social workers (% NR, p=0.007); no group differences in resources deemed “impossible to obtain” within 6 months (e.g., housing); 12-month followup; At 12-month followup, more intervention vs. control participants had heard about, tried to obtain, or obtained utility and telephone assistance 12.7% vs. 10.6%, p=0.006) or had accessed more resources overall (mean 3.7 vs. 3.2, p=0.03); No significant group differences in hearing about, attempting to obtain, or obtaining other resources (food, housing, income assistance); Legal consultations arranged for 75 intervention families; data not available for usual care participants
Silovsky 2011^124^; U.S. | Rural families with children age 0–5 and at least 1 risk factor | Home visiting adapted for rural environment (48); Services as usual (57) | No significant group differences on Family Resources Scale (measures adequacy of resources in households with children) at 17-month followup but significant improvement from baseline in home-visiting arm
Wiggins 2004^130^; U.K. | Individuals with young infants residing in economically deprived districts | Home visiting (183); Community services referral (184); Control (364) | 12-month followup; Home-visiting group more likely than control to have seen or spoken to health visitor or social worker (RR, 3.31 [95% CI, 1.23 to 8.96]); similar proportion of home-visiting group and control group used health services for own needs in past month; No significant differences in use of healthcare between control and community services group; Fewer home-visited children had seen GP vs. control children (RR, 0.77 [95% CI, 0.62 to 0.97]) and home-visited children had less use of any health service than control children (RR, 0.89 [95% CI, 0.77to 1.03]); Fewer women in intervention groups vs. control group considered their financial situation to be worse than prior year but differences were not significant; Slightly fewer women in both intervention groups than in the control group were currently employed, with similar time to return to employment among all 3 groups; Similar proportions among all groups had low partner support (11% to 14%); Women who received medium or high level of home visiting had greater increases in use of health visitors for self and child and use of social workers vs control group and decreased use of GP for child vs. control group; Home-visiting participants considered “socially excluded” had greater increases in use of health visitors for self and child and greater use of social worker vs. socially excluded control group participants; 18-month followup; Increased use of health services for self in home-visiting group vs. control, typically with wide confidence intervals; Continued, but less than at 12 months, decreased use of GP for home-visited children vs. control children; increase in being seen by doctor at home in community services group vs. control; 31% of home-visited participants vs. 24% of control considered financial status worse compared with prior year (RR, 1.26 [95% CI, 0.23 to 1.73]); Similar proportion of mothers and partners in home visiting and control group were not in paid employment (64% to 65% of mothers and 22% to 25% of partners); Fewer participants in home-visiting arm had unsatisfactory social support (41% vs. 47% in community services arm and 45% in control); proportion experiencing low levels of partner support was similar across groups but lowest in control arm (13% to 17%); In socially excluded population, increased maternal use of GPs and hospital doctors and higher risk of using any health services in previous month (RR, 1.25 [95% CI, 1.00 to 1.55]) in intervention group compared with control

Abbreviations: AFDC=Aid to Families with Dependent Children; AOR=adjusted odds ratio; CI=confidence interval; GP=general practitioner; ITT= intention-to-treat; mo=months; N=number; NS=not statistically significant; NR=not reported; NZ=New Zealand; OR=odds ratio; RR=relative risk; SD=standard deviation; SDOH=social determinants of health; SES=socioeconomic status; SNAP=Supplemental Nutrition Assistance Program; TANF=Temporary Assistance to Needy Families; U.K.=United Kingdom; U.S.=United States; WIC=Special Supplemental Insurance Program for Women, Infants, and Children