# References

1 Siu AL, U.S. Preventive Services Task Force. Screening for speech and language delay and disorders in children aged 5 years or younger: U.S. Preventive Services Task Force recommendation statement. Pediatrics. 2015 Aug;136(2):e474–81. doi: 10.1542/peds.2015-1711. PMID: 26152670.26152670
2 Law J, Boyle J, Harris F, Prevalence and natural history of primary speech and language delay: findings from a systematic review of the literature. Int J Lang Commun Disord. 2000 Apr-Jun;35(2):165–88. doi: 10.1080/136828200247133. PMID: 10912250.10912250
3 Centers for Disease Control and Prevention. Language and speech disorders in children. Atlanta, GA; 2021. https://www.cdc.gov/ncbddd/developmentaldisabilities/languagedisorders.html. Accessed 24 January 2023.
4 Lewis BA, Freebairn L, Tag J, Adolescent outcomes of children with early speech sound disorders with and without language impairment. Am J Speech Lang Pathol. 2015 May;24(2):150–63. doi: 10.1044/2014_AJSLP-14-0075. PMID: 25569242.25569242
5 Catts HW, Bridges MS, Little TD, Reading achievement growth in children with language impairments. J Speech Lang Hear Res. 2008 Dec;51(6):1569–79. doi: 10.1044/1092-4388(2008/07-0259). PMID: 18695010.18695010
6 Conti-Ramsden G, Mok PL, Pickles A, Adolescents with a history of specific language impairment (SLI): strengths and difficulties in social, emotional and behavioral functioning. Res Dev Disabil. 2013 Nov;34(11):4161–9. doi: 10.1016/j.ridd.2013.08.043. PMID: 24077068.24077068
7 Glogowska M, Roulstone S, Peters TJ, Early speech- and language-impaired children: linguistic, literacy, and social outcomes. Dev Med Child Neurol. 2006 Jun;48(6):489–94. doi: 10.1017/S0012162206001046. PMID: 16700942.16700942
8 Dubois P, St-Pierre MC, Desmarais C, Young adults with developmental language disorder: a systematic review of education, employment, and independent living outcomes. J Speech Lang Hear Res. 2020 Nov 13;63(11):3786–800. doi: 10.1044/2020_JSLHR-20-00127. PMID: 33022192.33022192
9 Schoon I, Parsons S, Rush R, Children's language ability and psychosocial development: a 29-year follow-up study. Pediatrics. 2010 Jul;126(1):e73–80. doi: 10.1542/peds.2009-3282. PMID: 20587683.20587683
10 Guiberson M. Bilingual Myth-Busters Series Language Confusion in Bilingual Children. Perspectives on Communication Disorders and Sciences in Culturally and Linguistically Diverse (CLD) Populations. 2013;20(1):5–14. doi: 10.1044/cds20.1.5.
11 Adesope OO, Lavin T, Thompson T, A systematic review and meta-analysis of the cognitive correlates of bilingualism. Review of Educational Research. 2010;80(2):207–45. doi: 10.3102/0034654310368803.
12 Peristeri E, Silleresi S, Tsimpli IM. Bilingualism effects on cognition in autistic children are not all-or-nothing: The role of socioeconomic status in intellectual skills in bilingual autistic children. Autism. 2022 Nov;26(8):2084–97. doi: 10.1177/13623613221075097. PMID: 35102760.35102760
13 Berkman ND, Wallace I, Watson L, Screening for speech and language delays and disorders in children age 5 years or younger: a systematic review for the U.S. Preventive Services Task Force. Rockville, MD; 2015.
14 Ene D, Der G, Fletcher-Watson S, Associations of socioeconomic deprivation and preterm birth with speech, language, and communication concerns among children aged 27 to 30 months. JAMA Netw Open. 2019 Sep 4;2(9):e1911027. doi: 10.1001/jamanetworkopen.2019.11027. PMID: 31509207.31509207
15 Bitsko RH, Holbrook JR, Robinson LR, Health care, family, and community factors associated with mental, behavioral, and developmental disorders in early childhood United States, 2011–2012. MMWR Morb Mortal Wkly Rep. 2016 Mar 11;65(9):221–6. doi: 10.15585/mmwr.mm6509a1. PMID: 26963052.26963052
16 Deoni SC, Beauchemin J, Volpe A, The COVID-19 pandemic and early child cognitive development: a comparison of development in children born during the pandemic and historical references. medRxiv. 2022 Aug 16doi: 10.1101/2021.08.10.21261846. PMID: 34401887.34401887
17 Horwitz SM, Irwin JR, Briggs-Gowan MJ, Language delay in a community cohort of young children. J Am Acad Child Adolesc Psychiatry. 2003 Aug;42(8):932–40. doi: 10.1097/01.CHI.0000046889.27264.5E. PMID: 12874495.12874495
18 Collisson BA, Graham SA, Preston JL, Risk and protective factors for late talking: an epidemiologic investigation. J Pediatr. 2016 May;172:168–74 e1. doi: 10.1016/j.jpeds.2016.02.020. PMID: 26968834.26968834
19 Institute of Medicine, National Academies of Sciences, Engineering, Medicine. Speech and language disorders in children: implications for the Social Security Administration's Supplemental Security Income Program. Washington, DC: The National Academies Press; 2016.
20 Black LI, Vahratian A, Hoffman HJ. Communication disorders and use of intervention services among children aged 3–17 years: United States, 2012. NCHS Data Brief. 2015 Jun(205):1–8. PMID: 26079397.26079397
21 Straub L, Bateman BT, Hernandez-Diaz S, Neurodevelopmental disorders among publicly or privately insured children in the United States. JAMA Psychiatry. 2022 Mar 1;79(3):232–42. doi: 10.1001/jamapsychiatry.2021.3815. PMID: 34985527.34985527
22 Gladfelter A, Wendt O, Subramanian A. Evidence-based speech and language intervention techniques for the birth-to-3 population. EBP Briefs. 2011;5(5):1–10.
23 Burne B, Knafelc V, Melonis M, The use and application of assistive technology to promote literacy in early childhood: a systematic review. Disabil Rehabil Assist Technol. 2011;6(3):207–13. doi: 10.3109/17483107.2010.522684. PMID: 20923322.20923322
24 Desch LW, Gaebler-Spira D, Council on Children With Disabilities. Prescribing assistive-technology systems: focus on children with impaired communication. Pediatrics. 2008 Jun;121(6):1271–80. doi: 10.1542/peds.2008-0695. PMID: 18519500.18519500
25 Sanchez D, Reiner JF, Sadlon R, Systematic review of school telehealth evaluations. J Sch Nurs. 2019 Feb;35(1):61–76. doi: 10.1177/1059840518817870. PMID: 30798692.30798692
26 Lipkin PH, Macias MM, Council On Children With Disabilities SOD, Promoting optimal development: identifying infants and young children with developmental disorders through developmental surveillance and screening. Pediatrics. 2020 Jan;145(1)doi: 10.1542/peds.2019-3449. PMID: 31843861.31843861
27 Hirai AH, Kogan MD, Kandasamy V, Prevalence and variation of developmental screening and surveillance in early childhood. JAMA Pediatr. 2018 Sep 1;172(9):857–66. doi: 10.1001/jamapediatrics.2018.1524. PMID: 29987317.29987317
28 Sheldrick RC, Marakovitz S, Garfinkel D, Comparative accuracy of developmental screening questionnaires. JAMA Pediatr. 2020 Apr 1;174(4):366–74. doi: 10.1001/jamapediatrics.2019.6000. PMID: 32065615.32065615
29 King TM, Tandon SD, Macias MM, Implementing developmental screening and referrals: lessons learned from a national project. Pediatrics. 2010 Feb;125(2):350–60. doi: 10.1542/peds.2009-0388. PMID: 20100754.20100754
30 United Nations Development Programme. Human Development Report 2020: the next frontier: human development and the Anthropocene. New York; 2020. http://report2020.archive.s3-website-us-east-1.amazonaws.com/. Accessed 24 January 2023.
31 Sterne JA C, Savovic J, Page MJ, RoB 2: a revised tool for assessing risk of bias in randomised trials. BMJ. 2019 Aug 28;366:14898. doi: 10.1136/bmj.14898. PMID: 31462531.31462531
32 Whiting PF, Rutjes AW, Westwood ME, QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
33 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. Rockville, MD; 2017. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual. Accessed 24 January 2023.
34 Agency for Healthcare Research and Quality Effective Health Care Program. Methods guide for effectiveness and comparative effectiveness reviews. Rockville, MD; Content last reviewed October 2022. https://effectivehealthcare.ahrq.gov/products/collections/cermethods-guide. Accessed 24 January 2023.
35 Deeks JJ, Altman DG. Diagnostic tests 4: likelihood ratios. BMJ. 2004 Jul 17;329(7458):168–9. doi: 10.1136/bmj.329.7458.168. PMID: 15258077.15258077
36 West SL, Gartlehner G, Mansfield AJ, Comparative effectiveness review methods: clinical heterogeneity. Rockville, MD; 2010.
37 Kok EC E, To CK S. Revisiting the cutoff criteria of intelligibility in context scale-traditional Chinese. Lang Speech Hear Serv Sch. 2019 Oct 10;50(4):629–38. doi: 10.1044/2019_LSHSS-18-0073. PMID: 31298988.31298988
38 Visser-Bochane MI, van der Schans CP, Krijnen WP, Validation of the Early Language Scale. Eur J Pediatr. 2021 Jan;180(1):63–71. doi: 10.1007/s00431-020-03702-8. PMID: 32533257.32533257
39 Nayeb L, Lagerberg D, Westerlund M, Modifying a language screening tool for three-year-old children identified severe language disorders six months earlier. Acta Paediatr. 2019 Sep;108(9):1642–8. doi: 10.1111/apa.14790. PMID: 30896050.30896050
40 Holzinger D, Weber C, Barbaresi W, Language screening in 3-year-olds: development and validation of a feasible and effective instrument for pediatric primary care. Front Pediatr. 2021;9:752141. doi: 10.3389/fped.2021.752141. PMID: 34888268.34888268
41 Nayeb L, Lagerberg D, Sarkadi A, Identifying language disorder in bilingual children aged 2.5 years requires screening in both languages. Acta Paediatr. 2021 Jan;110(1):265–72. doi: 10.1111/apa.15343. PMID: 32869381.32869381
42 Frisk V, Montgomery L, Boychyn E, Why screening Canadian preschoolers for language delays is more difficult than it should be. Infants & Young Children. 2009;22(4):290–308. doi: 10.1097/IYC.0b013e3181bc4db6.
43 Sachse S, Von Suchodoletz W. Early identification of language delay by direct language assessment or parent report? J Dev Behav Pediatr. 2008 Feb;29(1):34–41. doi: 10.1097/DBP.0b013e318146902a. PMID: 18300723.18300723
44 Sachse S, von Suchodoletz W. Response. Journal of Developmental & Behavioral Pediatrics. 2009;30(2):176. doi: 10.1097/DBP.0b013e31819f1c9f.19363373
45 Wetherby AM, Goldstein H, Cleary J, Early identification of children with communication disorders. Infants & Young Children. 2003;16(2):161–74. doi: 10.1097/00001163-200304000-00008.
46 Alberts FM, Davis BL, Prentice L. Validity of an observation screening instrument in a multicultural population. Journal of Early Intervention. 1995;19(2):168–77. doi: 10.1177/105381519501900209.
47 Allen DV, Bliss LS. Concurrent validity of two language screening tests. J Commun Disord. 1987 Aug;20(4):305–17. doi: 10.1016/0021-9924(87)90012-8. PMID: 3624526.3624526
48 Bliss LS, Allen DV. Screening kit of language development: a preschool language screening instrument. J Commun Disord. 1984 Apr;17(2):133–41. doi: 10.1016/0021-9924(84)90019-4. PMID: 6725626.6725626
49 Drumwright A, Van Natta P, Camp B, The Denver articulation screening exam. J Speech Hear Disord. 1973 Feb;38(1):3–14. doi: 10.1044/jshd.3801.03. PMID: 4698385.4698385
50 Klee T, Carson DK, Gavin WJ, Concurrent and predictive validity of an early language screening program. J Speech Lang Hear Res. 1998 Jun;41(3):627–41. doi: 10.1044/jslhr.4103.627. PMID: 9638927.9638927
51 Klee T, Pearce K, Carson DK. Improving the positive predictive value of screening for developmental language disorder. J Speech Lang Hear Res. 2000 Aug;43(4):821–33. doi: 10.1044/jslhr.4304.821. PMID: 11386471.11386471
52 Laing GJ, Law J, Levin A, Evaluation of a structured test and a parent led method for screening for speech and language problems: prospective population based study. BMJ. 2002 Nov 16;325(7373):1152. doi: 10.1136/bmj.325.7373.1152. PMID: 12433766.12433766
53 Law J. Early language screening in city and Hackney: the concurrent validity of a measure designed for use with 2 1/2-year-olds. Child Care Health Dev. 1994 Sep-Oct;20(5):295–308. doi: 10.1111/j.1365-2214.1994.tb00392.x. PMID: 7988000.7988000
54 Stokes SF. Secondary prevention of paediatric language disability: a comparison of parents and nurses as screening agents. Eur J Disord Commun. 1997;32(2 Spec No):139–58. doi: 10.1111/j.1460-6984.1997.tb01628.x. PMID: 9279431.9279431
55 Stott CM, Merricks MJ, Bolton PF, Screening for speech and language disorders: the reliability, validity and accuracy of the General Language Screen. Int J Lang Commun Disord. 2002 Apr-Jun;37(2):133–51. doi: 10.1080/13682820110116785. PMID: 12012612.12012612
56 Sturner RA, Heller JH, Funk SG, The Fluharty Preschool Speech and Language Screening Test: a population-based validation study using sample-independent decision rules. J Speech Hear Res. 1993 Aug;36(4):738–45. doi: 10.1044/jshr.3604.738. PMID: 8377486.8377486
57 Sturner RA, Funk SG, Green JA. Preschool speech and language screening: further validation of the sentence repetition screening test. J Dev Behav Pediatr. 1996 Dec;17(6):405–13. doi: 10.1097/00004703-199612000-00006. PMID: 8960570.8960570
58 Pace A, Curran M, Van Horne AO, Classification accuracy of the Quick Interactive Language Screener for preschool children with and without developmental language disorder. J Commun Disord. 2022 Nov-Dec;100:106276. doi: 10.1016/j.jcomdis.2022.106276. PMID: 36335826.36335826
59 Wilson P, Rush R, Charlton J, Universal language development screening: comparative performance of two questionnaires. BMJ Paediatr Open. 2022 Jan;6(1)doi: 10.1136/bmjpo-2021-001324. PMID: 36053598.36053598
60 Gibbard D. Parental-based intervention with pre-school language-delayed children. Eur J Disord Commun. 1994;29(2):131–50. doi: 10.3109/13682829409041488. PMID: 7865920.7865920
61 Girolametto L, Pearce PS, Weitzman E. Interactive focused stimulation for toddlers with expressive vocabulary delays. J Speech Hear Res. 1996 Dec;39(6):1274–83. doi: 10.1044/jshr.3906.1274. PMID: 8959612.8959612
62 Wake M, Tobin S, Girolametto L, Outcomes of population based language promotion for slow to talk toddlers at ages 2 and 3 years: Leťs Learn Language cluster randomised controlled trial. BMJ. 2011 Aug 18;343:d4741. doi: 10.1136/bmj.d4741. PMID: 21852344.21852344
63 McLeod S, Davis E, Rohr K, Waiting for speech-language pathology services: a randomised controlled trial comparing therapy, advice and device. Int J Speech Lang Pathol. 2020 Jun;22(3):372–86. doi: 10.1080/17549507.2020.1731600. PMID: 32366124.32366124
64 McLeod S, Baker E, McCormack J, Cluster-randomized controlled trial evaluating the effectiveness of computer-assisted intervention delivered by educators for children with speech sound disorders. J Speech Lang Hear Res. 2017 Jul 12;60(7):1891–910. doi: 10.1044/2017_JSLHR-S-16-0385. PMID: 28672376.28672376
65 Thordardottir E, Cloutier G, Menard S, Monolingual or bilingual intervention for primary language impairment? A randomized control trial. J Speech Lang Hear Res. 2015 Apr;58(2):287–300. doi: 10.1044/2014_JSLHR-L-13-0277. PMID: 25381447.25381447
66 Peredo TN, Mancilla-Martinez J, Durkin K, Teaching Spanish-speaking caregivers to implement EMT en Espanol: a small randomized trial. Early Child Res Q. 2022 1st Quarter;58:208–19. doi: 10.1016/j.ecresq.2021.08.004. PMID: 35058673.35058673
67 Acosta-Rodriguez VM, Ramirez-Santana GM, Hernandez-Exposito S. Intervention for oral language comprehension skills in preschoolers with developmental language disorder. Int J Lang Commun Disord. 2022 Jan;57(1):90–102. doi: 10.1111/1460-6984.12676. PMID: 34882931.34882931
68 Namasivayam AK, Huynh A, Granata F, PROMPT intervention for children with severe speech motor delay: a randomized control trial. Pediatr Res. 2021 Feb;89(3):613–21. doi: 10.1038/s41390-020-0924-4. PMID: 32357364.32357364
69 Wilcox MJ, Gray S, Reiser M. Preschoolers with developmental speech and/or language impairment: efficacy of the Teaching Early Literacy and Language (TELL) curriculum. Early Childhood Research Quarterly. 2020;51:124–43. doi: 10.1016/j.ecresq.2019.10.005. PMID: 2020-21742-012.
70 Almost D, Rosenbaum P. Effectiveness of speech intervention for phonological disorders: a randomized controlled trial. Dev Med Child Neurol. 1998 May;40(5):319–25. PMID: 9630259.9630259
71 Girolametto L, Pearce PS, Weitzman E. Effects of lexical intervention on the phonology of late talkers. J Speech Lang Hear Res. 1997 Apr;40(2):338–48. doi: 10.1044/jslhr.4002.338. PMID: 9130202.9130202
72 Glogowska M, Roulstone S, Enderby P, Randomised controlled trial of community based speech and language therapy in preschool children. BMJ. 2000 Oct 14;321(7266):923–6. doi: 10.1136/bmj.321.7266.923. PMID: 11030677.11030677
73 Jones M, Onslow M, Packman A, Randomised controlled trial of the Lidcombe programme of early stuttering intervention. BMJ. 2005 Sep 24;331(7518):659. doi: 10.1136/bmj.38520.451840.E0. PMID: 16096286.16096286
74 Lewis C, Packman A, Onslow M, A phase II trial of telehealth delivery of the Lidcombe Program of Early Stuttering Intervention. Am J Speech Lang Pathol. 2008 May;17(2):139–49. doi: 10.1044/1058-0360(2008/014). PMID: 18448601.18448601
75 Robertson SB, Ellis Weismer S. The influence of peer models on the play scripts of children with specific language impairment. J Speech Lang Hear Res. 1997 Feb;40(1):49–61. doi: 10.1044/jslhr.4001.49. PMID: 9113858.9113858
76 Robertson SB, Ellis Weismer S. Effects of treatment on linguistic and social skills in toddlers with delayed language development. J Speech Lang Hear Res. 1999 Oct;42(5):1234–48. doi: 10.1044/jslhr.4205.1234. PMID: 10515518.10515518
77 Wake M, Tobin S, Levickis P, Randomized trial of a population-based, home-delivered intervention for preschool language delay. Pediatrics. 2013 Oct;132(4):e895–904. doi: 10.1542/peds.2012-3878. PMID: 24043276.24043276
78 Campbell TF, Dollaghan CA, Rockette HE, Risk factors for speech delay of unknown origin in 3-year-old children. Child Dev. 2003 Mar-Apr;74(2):346–57. doi: 10.1111/1467-8624.7402002. PMID: 12705559.12705559
79 Rescorla L, Achenbach TM. Use of the language development survey (LDS) in a national probability sample of children 18 to 35 months old. J Speech Lang Hear Res. 2002 Aug;45(4):733–43. doi: 10.1044/1092-4388(2002/059). PMID: 12199403.12199403
80 Morgan PL, Hammer CS, Farkas G, Who receives speech/language services by 5 years of age in the United States? Am J Speech Lang Pathol. 2016 May 1;25(2):183–99. doi: 10.1044/2015_AJSLP-14-0201. PMID: 26579989.26579989
81 Davidson MM, Alonzo CN, Stransky ML. Access to Speech and Language Services and Service Providers for Children With Speech and Language Disorders. Am J Speech Lang Pathol. 2022 Jul 12;31(4):1702–18. doi: 10.1044/2022_ajslp-21-00287. PMID: 35613324.35613324
82 Harris RP, Helfand M, Woolf SH, Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20(3 Suppl):21–35. doi: 10.1016/s0749-3797(01)00261-6. PMID: 11306229.11306229
83 Faldt A, Fabian H, Dahlberg A, Infant-Toddler Checklist identifies 18-month-old children with communication difficulties in the Swedish child healthcare setting. Acta Paediatr. 2021 May;110(5):1505–12. doi: 10.1111/apa.15696. PMID: 33251672.33251672
84 Vehkavuori SM, Stolt S. Screening language skills at 2;0. Infant Behav Dev. 2018 Feb;50:174–9. doi: 10.1016/j.infbeh.2018.01.001. PMID: 29407426.29407426
85 Visser-Bochane M, Luinge M, Dieleman L, The Dutch well child language screening protocol for 2-year-old children was valid for detecting current and later language problems. Acta Paediatr. 2021 Feb;110(2):556–62. doi: 10.1111/apa.15447. PMID: 32585043.32585043
86 Roberts MY, Kaiser AP. Early intervention for toddlers with language delays: a randomized controlled trial. Pediatrics. 2015 Apr;135(4):686–93. doi: 10.1542/peds.2014-2134. PMID: 25733749.25733749
87 Hampton LH, Kaiser AP, Roberts MY. One-year language outcomes in toddlers with language delays: an RCT follow-up. Pediatrics. 2017 Nov;140(5)doi: 10.1542/peds.2016-3646. PMID: 29054980.29054980
88 Curtis PR, Kaiser AP, Estabrook R, The longitudinal effects of early language intervention on children's problem behaviors. Child Dev. 2019 Mar;90(2):576–92. doi: 10.1111/cdev.12942. PMID: 28872672.28872672
89 Roberts MY. Using empirical benchmarks to assess the effects of a parent-implemented language intervention for children with language impairments: ProQuest Information & Learning; 2014.
90 Delgado-Cruz A, Ramírez-Santana GM, Acosta-Rodríguez VM. Intervention in the cohesion of narrative discourse in pupils with developmental language disorder. Psicología Educativa. 2022;28(2):135–40. doi: 10.5093/psed2021a21. PMID: 2023-06592-006.
91 Madsen KM, Peters-Sanders LA, Kelley ES, Optimizing vocabulary instruction for preschool children. Journal of Early Intervention. 2022;45(3):227–49. doi: 10.1177/10538151221116596.
92 Parra-López P, Olmos-Soria M, Valero-García AV. Nonverbal oro-motor exercises: do they really work for phonoarticulatory difficulties? Int J Environ Res Public Health. 2022 Apr 29;19(9)doi: 10.3390/ijerph19095459. PMID: 35564854.35564854
93 Chen Y, Lin W-J. Efficacy of an integrated intervention with vocabulary and phonetic training for Mandarin-speaking children with developmental language disorders. Child Language Teaching and Therapy. 2022;38(3):288–302. doi: 10.1177/02656590221101180. PMID: CN-02494332.