# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Justin Mills, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, Scientific Director, USPSTF Division, AHRQ; current and former members of the USPSTF; expert reviewers Abigail D. Delehanty, PhD, CCC-SLP, Duquesne University; Virginia Moyer, MD, MPH, University of North Carolina at Chapel Hill; and Thelma E. Uzonyi, PhD, CCC-SLP, IMH-E, Kennedy Krieger Institute; Federal partners from the Centers for Disease Control and Prevention; Eunice Kennedy Shriver National Institute of Child Health and Human Development; and National Institute on Deafness and Other Communication Disorders; Manny Schwimmer, MPH, and Christiane E. Voisin, MSLS, RTI-UNC EPC; Robin A. Paynter, MLIS, Scientific Resource Center for the AHRQ EPC Program; Christina Bougatsos, MPH, Pacific Northwest Evidence-based Practice Center; Mary Gendron and Sharon Barrell, MA, editors; Alexander Cone, Teyonna Downing, and Michelle Bogus, publications specialists; and Roberta C. Wines, MPH, EPC Project Manager.