# Chapter 4 Discussion

## Summary of Evidence

Table 4 provides a summary of the main findings in this evidence review organized by KQ along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability.

Table 4 Summary of Evidence for Screening and Treatment of Speech and Language Delay and Disorders in Children Age 5 Years or Younger

Key Question and Topic | No. of Studies; No. of Participants (n) | Summary of Findings | Consistency and Precision | Study Quality | Limitations (Including Reporting Bias) | Overall Strength of Evidence | Applicability
KQ 1. Benefits of Screening | No eligible study identified | NA | NA | NA | NA | Insufficient | NA
KQ 2. Accuracy of Screening | Parent-reported global language: 6 studies^38, 42, 45, 54, 55, 59^ (1,941) | Sensitivity median: 74%; range: 55% to 89%. Specificity median: 79%; range: 73% to 95%. The Infant-Toddler Checklist had the highest sensitivity at 89% and 86% for each of its two age groups. The ELS and the ASQ with toddlers^59^ had the highest specificity at 93% and 95%, respectively. | Mostly consistent and imprecise (for both sensitivity and specificity). | 1 Good, 5 Fair | Only one instrument (ASQ) was included in more than one study. Reference measures differed across studies. One study included all screen failures and a random sample of those who passed. Not all studies indicated criteria for screen failure. Studies had a wide age range. | Low | North American and European parents of infants, toddlers, and preschool children.
| Parent-reported specific language skills: 4 studies ^40, 43, 44, 59^ (3,245) | Sensitivity median: 91%; range: 83% to 93%; specificity: 88%; range: 81% to 96%. The LDS (revised scoring) displayed a large positive LR and a large negative LR; the ELFRA-2 had a large negative LR. | Sensitivity: fairly consistent; specificity: fairly consistent; sensitivity: imprecise. Specificity varies by instrument; the SPES-3 is precise. | 1 Good, 3 Fair | Different reference measures were used. Small sample size in one study. Three of the studies included all screen failures and a random sample of those who passed. | Moderate | American and European parents of 2- and 3-year-old children.
| Parent-reported articulation: 1 study^37^ (780) | Sensitivity: 86%; specificity: 32% | Consistency: sensitivity, and specificity: unknown; sensitivity: imprecise; specificity: precise | 1 Fair | There was only one study of Chinese children. Studies had a wide age range. May only be appropriate for 4-year-old children. | Insufficient | Although the study included parents of children who were speakers of traditional Chinese in Hong Kong and was applicable for them, the instrument would not be applicable to English-speaking children.
| Examiner-reported global language; 10 studies^39, 41, 46–48, 52–54, 56, 57^ (2,287) | Sensitivity median: 88%; range: 17% to 100%; specificity median: 89%; range: 69% to 98% | Mostly consistent, with some instruments showing high (>90%) sensitivity and/or specificity and others showing low or moderate values.; Precision is inconsistent, varying by instrument. The HELST and SKOLD are precise for sensitivity; the DOCT, SST, two of the three age levels of the SKOLD, and the SRST are precise for specificity. | 2 Good, 8 Fair | Three instruments were examined in one study each; three instruments were examined in two studies. The reference measure varied. Criteria for screening failure was not always indicated. | Low | Children seen in medical practices in the United Kingdom, Sweden, and Australia and in schools in the United States. One instrument was used with bilingual children.
| Examiner-reported specific language: 3 studies^42, 47, 58^ (418)^*^ | Sensitivity median: 86%; range: 56% to 94%. Specificity median: 70%; range: 58% to 90% | Unclear; both sensitivity and specificity are inconsistent and imprecise; however, tools assess different types of language problems across heterogeneous populations. | 3 Fair | One study included three instruments, accounting for five of the seven accuracy indices. | Insufficient | Children at risk for developmental delays in Canada and childcare centers in the United States.
| Examiner-reported articulation: 3 studies^49, 56, 57^ (673) | Sensitivity median: 66%; range: 43% to 92%; specificity median: 96%; range: 93% to 97% | Sensitivity is inconsistent; specificity is consistent; precision is unknown (two studies do not report CIs). | 3 Fair | Studies had a wide age range. | Low | Children in schools in the United States.
KQ 3. Harms of Screening | No eligible study identified | NA | NA | NA | NA | Insufficient | NA
KQ 4. Speech and Language Outcomes of Intervention | Language delay (parent delivered); 4 RCTs (378 participants)^60–62, 66^ | Parent-delivered, group training interventions: two RCTs assessing interventions delivered over a longer duration (11 bimonthly 60- to 75-minute sessions^60^ and 11 weekly 2.5-hour sessions plus 3 weekly home visits^61^) found benefit in expressive language outcomes; one shorter intervention (6 weekly 2-hour sessions) found no significant difference between groups.^62^; One RCT of individual home-based parental training intervention found mixed results. | Parent-delivered, group training interventions: inconsistent; precise; Individual home-based parent training: unknown consistency; imprecise | 2 Good, 2 Fair | Studies of parental group training differed in duration, intensity, content, and timing of outcome assessment. | Parent-delivered, group training interventions: Low; Parent-delivered individual training: Insufficient | Parental group-based training trials that showed benefit enrolled children and parents in the 1990s, results may not be applicabile to current practice.
| Language delay (SLP or trained staff delivered):; 4 RCTs (270 participants)^65, 75–77^ | One RCT enrolling toddlers (mean age 21 to 30 months) found benefit associated with an individual intervention delivered by an SLP over 12 weeks on multiple measures of expressive language;^76^ three other RCTs assessed different interventions among older children (mean age 49.5 to 59.6 months) found inconsistent results.^65, 75, 77^ | Unknown consistency; mostly imprecise | 4 Fair | All studies focused on children with language delay and interventions delivered by an SLP or trained staff; however, populations, settings, and outcome measures were heterogeneous. | Insufficient | Children with language delay, who were identified via referrals or advertisements
| School-based (Tier 1) interventions:; 2 cluster RCTs (339 participants)^67, 69^ | Both found improved receptive and expressive language outcomes associated with the intervention over 52 weeks; however, 1 found benefit in some measures (receptive and expressive 1-word picture vocabulary tests focused on vocabulary) but not others (no improvement on standardized measures of oral language).^69^ | Mostly consistent; imprecise | 2 Fair | One RCT reported only F-statistics from ANOVA analyses and p-values, limiting the ability to determine the magnitude of effect; one RCT found benefit in some measures of oral language and literacy but not others. | Low | Unclear applicability to current preschool curricula in the United States; one study was set in Spain and one in the United States.
| Community-based speech and language disorders; 2 RCTs (260 participants)^63, 72^ | Studies found mixed results with improvement on some domains of speech and language but not others, and no consistent benefit on similar measures or outcome domains. | Inconsistent; imprecise | 1 Good, 1 Fair | Studies both focus on children newly referred from primary care for any speech and language disorder, but differ in country setting (United Kingdom and Australia), mean age of enrolled children (34 vs. 53 months), and outcome measures reported. | Insufficient | Children newly referred from primary care to existing community-based treatment for speech and language problems in the United Kingdom and Australia
| Fluency disorders (Lidcombe Program of Early Stuttering Intervention); 2 RCTs (76 participants)^73, 74^ | Both RCTs found benefit for stuttering fluency associated with the intervention at 9 months; one found a 2.3% reduction in the percentage of syllables stuttered among the intervention vs. control group, and the second found the mean number of syllables in the intervention group was significantly lower than the control group (−3.0; p=0.02). | Consistent; precise | 2 Fair | One RCT delivered the intervention via face-to-face visits, and one delivered the intervention via telehealth. | Moderate | Children ages 42 to 56 months identified with stuttering
| Speech-sound disorders; 3 RCTs (194 participants)^64, 68, 70^ | One RCT enrolling children with a severe phonological disorder but normal receptive language function found improvement associated with an individual SLP intervention at 16 weeks for multiple speech and sound outcomes; one RCT assessing an intervention for children with speech motor delay found mixed results; one RCT assessing a software-based intervention set in schools for children identified with a speech-sound disorder found no improvement on measures of speech production and speech intelligibility. | Unknown; imprecise | 3 Fair | Studies focus on children with different types of speech-sound disorders and assess different interventions. | Insufficient | Unclear; RCTs are set in different countries and enroll heterogeneous populations of children who differ in age, spoken language, and type of speech disorder.
KQ 5. Health Outcomes of Intervention (school performance, function, or quality-of-life outcomes) | 8 RCTs (1,239 participants) report on one or more outcomes specific to school performance (or early literacy), function, and QOL^62–64, 68, 69, 72, 76, 77^ | No two studies assessing a similar intervention type reported on the same outcome domain; in four RCTs assessing a measure of early literacy, three found no significant difference between groups and one RCT assessing a home-based language delay intervention delivered by trained assistants found benefit for improving letter knowledge associated with the intervention^77^ No study reported benefit for improving function or QOL; one individual intervention for language delay found significant improvement favoring the intervention for improving socialization and parental stress level.^76^ | Unknown; imprecise | 2 Good, 6 Fair | No two studies assessing the same type of intervention reported on a similar outcome measure, limiting the ability to assess consistency of findings. | Insufficient | Unclear; RCTs are set in different countries and assess different outcomes among different groups of children, who vary in terms of setting and type of speech and language disorder.
KQ 6. Harms of Intervention | No eligible study identified | NA | NA | NA | NA | Insufficient | NA

* Frisk, 2009^42^ examined three instruments and included separate accuracy calculations for the expressive and receptive PLS-4 reference measure. We omitted the accuracy outcomes for the Battelle Developmental Inventory Screening Test with the PLS-4 Expressive Communication Scale due to a possible reporting error in the study.

Abbreviations: ANOVA=analysis of variance; DOCT=Davis Observational Checklist for Texas; ELFRA-2=Elternfragebogen für die Fruberkennung von Riskokindern; ELS=Early Language Scale; GLS=General Language Screen; HELST=Hackney Early Language Screening Test; LDS=Language Development Survey; LR=likelihood ratio; NA=not applicable; PLS-4=Preschool Language Scale, Fourth Edition; QOL=quality of life; RCT=randomized, controlled trial; SKOLD=Screening Kit of Language Development; SKOLDBE=Screening Kit of Language Development Black English; SLP=speech-language pathologist; SPES-3=Sprachentwicklungsscreening; SRST=Sentence Repetition Screening Test; SST=Structured Screening Test.

### Evidence on the Benfit and Harms of Screening

We did not find direct evidence on the benefits and harms of screening. Potential harms include false-positive screening results that can lead to unnecessary referrals (and the associated time and economic burden), labeling or stigma, parent anxiety, and other psychosocial harms. Other harms of screening are likely to be minimal because screening is noninvasive.

### Accuracy of Screening Questionnaires

Included studies of screening test accuracy assessed 23 different tools that varied in terms of whether the tools were completed by parents vs. trained examiners and whether they were designed to detect global speech or language problems vs. problems related to specific language skills or articulation (Table 2). Some available screening tools for clinical practice may reasonably identify children who have a speech or language disorder; however, overall evidence was mixed and few screening tools were assessed by more than one study each, limiting our ability to make stronger conclusions about the accuracy of specific tools. Parent-reported screening instruments designed to assess expressive language skills displayed consistently high sensitivity and specificity, although precision varied by instrument. Given the pattern of results, we graded the overall strength of evidence of the accuracy of these screening tools as moderate. In contrast, accuracy of the parent-reported instruments for global language was inconsistent, and precision of the accuracy measures varied by instrument.

Overall, the accuracy of examiner-administered screening instruments varied, particularly for instruments designed to assess specific language skills. Accuracy of trained examiner instruments of global language were mostly consistent, with some instruments showing both high sensitivity and specificity. Due to imprecision and study limitations, we rated the overall strength of evidence as low. Finally, the accuracy of trained examiner instruments for specific language skills varied by tool and was generally imprecise. Included studies assessed tools designed to detect different types of speech or language skills among heterogeneous populations. Given the inability to compare tools designed to detect similar speech or language problems, we rated the strength of evidence as insufficient.

### Benfits and Harms of Treatment

Few studies of interventions for speech and language delay or disorder enrolled similar populations and evaluated similar types of interventions. Although two RCTs of treatment enrolled children who were newly referred from primary care, it is not clear whether the children were identified via routine screening vs. case finding. In addition, the two RCTs differed in setting, mean age of enrolled children, and other factors. Other included studies enrolled children referred or recruited via advertisements, and most focused on a specific type of speech delay or disorder. Given these factors, the included body of evidence on treatment may not be applicable to the type and severity of disorders that would be detected via routine screening in primary care settings. For children with language delay and no obvious speech-sound or fluency disorder, evidence suggests that group training interventions offering at least 22 hours of parent training improve expressive language outcomes. In addition, school-based whole-class curriculum components (or Tier 1 interventions) designed to advance language and literary skills over the course of an academic year improve receptive and expressive language outcomes in favor of the intervention. For children identified with stuttering, the Lidcombe Program of Early Stuttering Intervention delivered by SLPs improves stuttering fluency at 9 months, when delivered either in person or via telehealth. Three RCTs assessed interventions for three different types of speech-sound disorders and reported on various measures of speech-sound; results were generally inconsistent across different measures of speech. Eight RCTs reported on one or more outcomes specific to school performance or early literacy, health-related quality of life, function, behavior, or socialization. No studies assessing the same type of intervention among similar groups of children reported on similar outcomes; most studies found no difference between groups for measures of early literacy, function, and quality of life. However, most trials may not have followed children for a long enough duration to detect an improvement in quality of life or function that could result from early treatment of a speech and language delay or disorder. No RCTs reported on the harms of interventions.

## Limitations

The limitations of the included studies are discussed above in Results and Summary of Evidence sections. Here we focus on the limitations of this review. We excluded studies that were limited to children who had a condition known to cause a speech or language problem (e.g., hearing loss). We also excluded head-to-head comparisons of different interventions because the scope was designed to provide evidence on the benefits of treatments compared with no treatment rather than to assess the comparative effectiveness of interventions. Finally, we excluded studies that assessed primary prevention strategies to promote speech and language development (e.g., among groups considered “at risk” or school-based curricula emphasizing language development among children with no developmental delay or disorder). Our aim was to limit the review to interventions relevant to children who are screen-detected and that are appropriate to deliver in primary care settings or refer to from primary care.

## Future Research Needs

Trials directly assessing the benefit of screening specifically for speech and language problems compared with no screening (or routine screening for general developmental delay, with no separate score for speech and language problems) and enrolling asymptomatic or unselected populations from general primary care are needed, as are studies on the potential harms of screening, such as labeling, and harms from false-positive results (with the burden on parents due to unnecessary referrals). Such studies would also inform the potential for overdiagnosis associated with routine screening, given that many children who have a speech delay may recover without intervention. Similarly, studies assessing the accuracy of screening tools among unselected populations, who are ideally recruited through primary care settings, are needed because the prevalence of speech and language problems may vary compared to populations enrolled via advertisements or specialty settings. Specifically, studies that assess the accuracy of existing tools, compared with similar reference standards, would help determine the consistency of findings; because few included studies evaluated the same instrument, our ability to make a strong conclusion about accuracy was limited. Trials of treatment that are applicable to U.S. populations would inform future recommendations based on the benefit of screening; for example, trials enrolling populations recruited from primary care settings, using brief screening questionnaires to assess interventions specific to the variety and severity of conditions likely to be detected by routine screening. Trials that follow children for a sufficiently long duration to detect improvement in academic performance, function, and quality of life would help in the understanding of whether immediate changes in speech and language outcomes (e.g., short-term expansion of vocabulary words) translate into benefit for health and social outcomes. Finally, future studies that utilize similar measures of speech and language outcomes across studies would help assess the consistency of findings. Future studies on this topic should aim to enroll children representative of the diversity of families served in U.S. primary care settings, including those who speak languages other than English at home.

## Conclusion

We found no eligible studies that reported on benefits directly arising from screening when compared with usual care or no screening. Parent-reported screening tools of emerging expressive language skills had reasonable accuracy for detecting expressive language delay; however, the accuracy of global language instruments based on parent reports was inconsistent. Accuracy of examiner-administered instruments was also variable, especially for examiner-administered instruments of specific language skills. Existing evidence supports the benefit of group parent training programs for speech delay that provide at least 11 parental training sessions for improving receptive language skills, as well as the Lidcombe Program of Early Stuttering Intervention delivered by SLPs for reducing stuttering frequency.