# Chapter 3 Results

## Literature Search

We identified 7,929 unique records and assessed 594 full-text articles for eligibility (Figure 2). We excluded 553 articles for various reasons, as detailed in Appendix C, and included 41 articles representing 38 studies. Details of quality assessments of the newly included studies are in Appendix D Tables 1–6.

Figure 2 Summary of Evidence Search and Selection

Note: The sum of the number of studies per KQ exceeds the total number of studies because some studies were applicable to multiple KQs.

Abbreviations: ERIC=Education Resources Information Center; KQ=key question; LLBA=Linguistics and Language Behavior Abstracts; WHO ICTRP=World Health Organization International Clinical Trials Registry Platform.

Figure 2 is a flow diagram that documents the search and selection of evidence. Records were identified by searching ClinicalTrials.gov: 153; Cochrane Library: 766; Education Resources Information Center: 162; Linguistics and Language Behavior Abstracts (ProQuest): 95; PsycInfo: 1,284; PubMed: 5,382; and World Health Organization International Clinical Trials Registry Platform: 46. In addition, 41 records were identified from the 2015 Screening for Speech and Language Delays and Disorders in Children Age 5 Years or Younger: A Systematic Review for the U.S. Preventive Services Task Force. In total, 7,929 unique titles and abstracts were screened for potential inclusion. Of these, 594 were deemed appropriate for full-text review to determine eligibility. After full-text review, 553 were excluded: 1 for non-English publication; 156 for ineligible population; 84 for ineligible/no screening; 21 for ineligible/no treatment; 128 for ineligible/no comparison; 46 for ineligible/no outcome; 1 for ineligible setting; 97 for ineligible study design; 7 for ineligible country; 1 for being an abstract only; and 11 for poor quality. Thirty-eight studies represented in 41 articles met inclusion criteria. No study was included for Key Question (KQ) 1. Twenty-one studies represented in 23 articles were included for KQ 2. No study was included for KQ 3. Seventeen studies represented in 18 articles were included for KQ 4. Eight studies were included for KQ 5. No study was included for KQ 6.

## Results by Key Question

### KQ 1. Does Screening for Speech and Language Delay or Disorders in Children Age 5 Years or Younger Improve Speech and Language Outcomes, School Performance, Function, or Quality-of-Life Outcomes?

We found no eligible study that addressed this KQ.

### KQ 2. What Is the Accuracy of Screening Tools to Detect Speech and Language Delay or Disorders in Children Age 5 Years or Younger?

#### Summary

Twenty-one studies (23 articles; 7,489 participants) assessed the accuracy of 23 instruments for detecting speech and language disorders in young children.^37–59^ Seven studies were new to this update.^37–41, 58, 59^ About half of the studies recruited at least a portion of their participants from primary care or health departments. Of the 23 instruments, 13 were speech and language instruments administered to children by a trained examiner, and 10 were parent reports of children’s speech or language skills. Twelve instruments were designed to screen for global language delay or disorders (any type); nine were designed to screen for specific language problems such as expressive language skills or understanding of syntactic forms; and four instruments were used to screen for articulation problems, two of which also screened for global language problems. Excluding two studies^43, 45^ that enrolled all children who screened positive and a random sample of children who screened negative, the overall prevalence of speech and language disorders ranged between 4 percent and 33 percent, with a median prevalence of 14 percent. The sensitivity of instruments for detecting speech and language delay and disorders ranged between 17 and 100 percent with a median of 86 percent, and specificity ranged between 32 and 98 percent with a median of 87 percent. When parent-reported and trained examiner instruments were considered separately, we found that the median sensitivity of parent reports was 84 percent, with a range of 55 to 93 percent, and the median specificity was 84 percent, with a range of 32 and 96 percent. For trained examiner instruments, the median sensitivity was 87 percent, with a range of 17 to 100 percent, and the median specificity was 88 percent, with a range of 58 to 98 percent.

#### Detailed Evidence

Four good-quality studies (reported in 5 articles)^43, 44, 52–54^ and 17 fair quality studies (reported in 18 articles)^37–42, 45–51, 55–59^ assessed the accuracy of 23 instruments for detecting speech and language disorders in young children. Seven studies were new to this update.^37–41, 58, 59^ Study designs included both cross-sectional and prospective cohort designs.

Enrolled populations ranged from ages 12 to 70 months, with an average age of 38.9 months (Table 1). In the 16 studies that reported sex of the participants, on average, 47 percent were female. Children were recruited in a variety of ways, including through pediatric and other primary care practices (n=8), childcare centers/preschools/kindergartens (n=9), health/public health centers (n=3), birth announcements (n=2), and public advertisements in local media (n=1), WIC offices (n=1), mailed invitations to children born within a public health district (n=2), a child welfare clinic (n=1), and a program providing services for children at risk of delay (n=1). Some studies recruited participants from multiple venues so that the number exceeds the number of included studies. Nine studies were conducted in the United States,^45–50, 56–58^ one in Canada,^42^ one in Hong Kong,^37^ one in Australia,^54^ four in the United Kingdom,^52, 53, 55, 59^ and five in other Western European countries.^38–41, 43^ Of the 13 studies in which a trained examiner directly assessed children (see below), four were screened in a health facility, five were screened in a child care center or school, and the location of the screening was unclear in the remaining four studies. Of the 10 studies that included parent reports, one was completed in the pediatric office; in seven studies, parents completed the reports at home; in one study, the reports were completed either in the home or the clinic; and in one study, the location was not described.

Table 1 Characteristics of Included Studies of Diagnostic Accuracy (KQ 2)

First Author, Year, Country | N | Study Design | Study Quality | Screening Tool | Recruitment Setting | Mean Age Months/Range | % F
Alberts, 1995^46^; United States | 59 | Cross-sectional | Fair | DOCT | Head Start centers in Central Texas | 48; 52–67 | 51
Allen, 1987^47^; United States | 182 | Cross-sectional | Fair | FPST, NSST | Childcare centers in suburban Dallas | 36–47 | NR
Bliss, 1984^48^; United States | 602 | Cross-sectional | Fair | SKOLD, SKOLDBE | Childcare centers in metropolitan Detroit | 40; 30–48 | 48
Drumwright, 1973^49^; United States | 150 | Prospective cohort | Fair | DASE | Head Start, public and private childcare centers, schools, and pediatric clinics in Denver | 30–72 | NR
Frisk, 2009^42^; Canada | 110 | Prospective cohort | Fair | ASQ-CD, BDIST-CD, BPS, ESP | Programs providing early intervention services to at-risk children in Ontario | 54 | 32
Holzinger, 2021^40^; Austria | 2,044^*^ | Prospective cohort | Fair | SPES-3 | Pediatric medical practices in Upper Austria | 36; 34–38^†^ | 49
Klee, 1998^50^ (Study 2); Klee, 2000^51^; United States | 64 | Prospective cohort | Fair | LDS | Birth announcements, and local physicians, health departments, and WIC offices in Laramie and Casper, Wyoming | 25; 24–26 | 39
Kok, 2019^37^; Hong Kong | 789 | Cross-sectional | Fair | ICS-TC | 11 community kindergartens in Hong Kong | 53; 28–81 | 47
Laing, 2002^52^; United Kingdom | 458 | Cross-sectional | Good | SST | Health center in London | 30 | 44
Law, 1994^53^; United Kingdom | 189 | Prospective cohort | Good | HELST | Pediatric practice in London | 30 | NR
Nayeb, 2019^39^; Sweden | 105^ǂ^ | Prospective cohort | Fair | Nurse Screening (Swedish and maternal language) | Child health centers in Gävle Sweden | 30 | 47
Nayeb, 2021^41^; Sweden | 111^§^ | Prospective cohort | Fair | Nurse Screening | Child health centers in Gävle, Sweden | 30; 29–33 | 51
Pace, 2022^58^; (Study 2 only); United States | 126 | Cross-sectional | Fair | QUILS | University SH clinic; inclusive public preschool and kindergarten classrooms; Head Start centers | 56; 38–70 | 50
Sachse, 2008^43^; Sachse, 2009^44^; Germany | 117 | Prospective cohort | Good | ELFRA-2 (German version of CDI Words and Sentences) | Birth announcements in Germany | 25; 24–26 | 33
Stokes, 1997^54^; Australia | 398 | Prospective cohort | Good | DNS, Parent Questionnaire | Child Health centres in metropolitan Perth | 37; 34–40 | 51
Stott, 2002^55^; United Kingdom | 596 | Prospective cohort | Fair | GLS | Mailed invitations to children born within Cambridge Health Authority | 36 | NR
Sturner, 1993^56^; United States | Study 1: 51; Study 2: 147 | Prospective cohort | Fair | FPSLST | Schools in a rural county in North Carolina | Study 1: 61; 53–68; Study 2: 62; 55–69 | Study 1: 54; Study 2: 48
Sturner, 1996^57^; United States | 337^†^ | Prospective cohort | Fair | SRST | Schools in a rural county in North Carolina | 60; 54–66 | 52
Visser-Bochane, 2021^38^; Netherlands | 265 | Prospective cohort | Fair | ELS | Well-child clinics, kindergartens, and schools in the Netherlands | 44; 15–72 | 51
Wetherby, 2003^45^ (Study 1); United States | 232 | Prospective cohort | Fair | ITC from CSBS | Public announcements, healthcare providers, childcare providers, and a public healthcare agency | 12–24 | NR
Wilson, 2022^59^; United Kingdom | 357 | Propsective cohort | Fair | ASQ; SSLM | Mailed invitations to parents of children who were due to receive their universal developmental assessment | 26; 23–30 | 47

* Full sample size, based on multiple imputation.

ǂ Includes 11 children (10.5%) who did not cooperate during screening and were considered screen positive.

§ Includes 11 children who were noncooperative during screening. For Model 4, parents of 10 children did not complete parental information.

† Based on full sample.

Abbreviations: ASQ-CD=Ages and Stages Questionnaire-Communication Domain; BDIST-CD=Battelle Developmental Inventory Screening Test-Communication Domain; BPS=Brigance Preschool Screen; CDI=MacArthur-Bates Communicative Development Inventory; CSBS=Communication and Symbolic Behavior Scales; DASE=Denver Articulation Screening Exam; DNS=Developmental Nurse Screen; DOCT=Davis Observation Checklist for Texas; ELFRA-2=Elternfragebogen für die Fruberkennung von Riskokindern; ELS=Early Language Scale; ESP=Early Screening Profiles; F=female; FPSLST=Fluharty Preschool Speech and Language Screening Test; FPST=Fluharty Preschool Screening Test; GLS=General Language Screen; HELST=Hackney Early Language Screening Test; ICS-TC=Intelligibility in Context Scale–Traditional Chinese; ITC=Infant-Toddler Checklist; LDS=Language Development Survey; NR=not reported; NSST=Northwestern Syntax Screening Test; QUILS=Quick Interactive Language Screening; SH=speech and hearing; SKOLD=Screening Kit of Language Development; SKOLDBE=Screening Kit of Language Development Black English; SPES-3=Sprachentwicklungsscreening; SRST=Sentence Repetition Screening Test; SSLM=Sure Start Language Measure; SST=Structured Screening Test; WIC=Women, Infants, and Children.

Most studies did not report race/ethnicity.

Overall, 23 instruments provide data on accuracy and assess a variety of speech and language skills (Table 2). Ten instruments, described in 10 studies (12 articles), used parent reports to detect speech and language delay and disorders.^37, 38, 40, 42–45, 50, 51, 54, 55, 59^ All but four of the parent report instruments have a limited number of items, ranging from four to 26. Four other instruments^40, 43, 50, 59^ ask parents to report on a range of vocabulary items and syntactic forms and contain from 50 to several hundred items in a checklist form. Thirteen instruments, described in 13 studies, require a trained examiner to administer them to children,^39, 41, 42, 46–49, 52–54, 56–58^ although in one case, the examiner can be an aide who only needs to monitor the child’s use of a touchscreen.^58^ The instruments range from six to 50 items, but only a portion of items need be administered in some cases. All but three instruments were examined in only one study each. These instruments were the Ages and Stages Questionnaire.^42, 59^ Hackney Early Language Screening Test/Structured Screening Test,^52, 53^ and the Nurse Screening.^39, 41^ In addition, two studies examined the Fluharty Preschool Screening Test^47^ and a later version with a language component, the Fluharty Preschool Speech and Language Screening Test.^56^ Although the Sprachentwicklungsscreening (SPES-3)^40^ was designed as both a parent report and trained examiner instrument, the authors recommended that only the parent report subscales be include as a screen for language delay; therefore, we have classified the SPES-3 as a parent report instrument.

Table 2 Instruments Examined in KQ 2 Studies

Instrument | Screening Source | Appropriate Ages | Domains/Skills Assessed | Summary Scores | Number of Items
Ages and Stages Questionnaire –Communication Domain^42, 59^ | Parent reported | Ages 4 to 60 months | Broad communication skills | Communication | 6 at each age level
Battelle Developmental Inventory Screening Test – Communication Domain^42^ | Trained examiner | Ages 1 to 8 years | Receptive and expressive language skills^*^ | Receptive language; Expressive language | 9 per each subtest
Brigance Preschool Screen^42^ | Trained examiner | Ages 45 to 56 months | Receptive and expressive language skills | Understanding reading (i.e., receptive language); Expressive language | Receptive: 2; Expressive: 4
Davis Observation Checklist for Texas^46^ | Trained examiner | Ages 4 to 5 years | Speaking, understanding, speech fluency, voice, and hearing | Communication | 2–5 behaviors in each of 6 areas
Denver Articulation Screening Exam^49^ | Trained examiner | Ages 2.5 to 7 years | Articulation skills | Articulation | 34 sound elements
Developmental Nurse Screen^54^ | Trained examiner | Ages 34 to 40 months | Broad language skills | Global language | NR
Early Language Scale^38^ | Parent reported | Ages 1 to 6 years | Vocabulary, syntax, morphology, and pragmatics | Global language | 26
Early Screening Profiles^42^ | Trained examiner | Ages 2 years and 0 months to 6 years and 11 months | Word comprehension and production | Verbal concepts | 25
ELFRA-2; German version of MacArthur CDI Words and Sentences^43, 44^ | Parent reported | Ages 16 to 30 months | German expressive vocabulary, morphology, and grammar | Expressive language | Vocabulary: 260; Syntax: 25; Morphology: 11
Fluharty Preschool Screening Test^47^/Fluharty Preschool Speech and Language Screening Test^56^ | Trained examiner | Ages 2 to 5 years | Articulation, and expressive and receptive language skills | Articulation; Language | 35
General Language Screen^55^ | Parent reported | Age 36 months | Comprehension, expression, articulation, and pragmatics | Global language | 11
Hackney Early Language Screening Test/Structured Screening Test^52, 53^ | Trained examiner | Age 30 months | Expressive and receptive language skills | Global language | 20
Infant-Toddler Checklist from CSBS^45^ | Parent reported | Ages 6 to 24 months | Emotion and use of eye gaze, communication, gestures, sound use, word use, word understanding, and object use | Social, Speech, and Symbolic composites; Total score | 24
Intelligibility in Context Scale–Traditional Chinese^37^ | Parent reported | Ages 28 to 71 months | Functional intelligibility | Articulation | 7
Language Development Survey^50, 51^ | Parent reported | Ages 18 to 35 months | Expressive vocabulary and word combinations | Expressive language | 310
Northwestern Syntax Screening Test^47^ | Trained examiner | Ages 3 to 8 years | Expressive and receptive knowledge of syntactic forms | Syntactic expression; Syntactic comprehension | 20 per each subtest
Nurse Screening^39, 41^ | Trained examiner | Age 2.5 years | Language comprehension and language production | Global language | 5 and observation
Parent Questionnaire^54^ | Parent reported | Ages 34 to 40 months | Sentence use, comprehension, articulation, and global problems | Global language | 4
Quick Interactive Language Screener^58^ | Trained examiner | Ages 3 years through 6 years and 11 months | Comprehension of vocabulary (nouns, verbs, prepostions, conjuncutions), syntax (WH questions, past tense, prepostional phrases, embedded clauses), and language learning (noun learning, adjective learning, verb learning, converting active to passive) | Vocabulary, syntax, process, and overall (composite) scores | 48
Screening Kit of Language Development/Screening Kit of Language Development Black English^48^ | Trained examiner | Ages 54 to 66 months | Vocabulary comprehension, story completion, sentence completion, paired sentence repetition, individual sentence repetition with and without pictures, and comprehension of commands | Global language | 20–50 items per each of 7 subtests
Sentence Repetition Screening Test^57^ | Trained examiner | Ages 54 to 66 months | Expressive morphology and articulation | Global language; articulation | 15
SPES-3^40^ | Parent reported^ǂ^ | Age 3 years | Expressive vocabulary, expressive grammar | Expressive language | 113
Sure Start Language Measure^59^ | Parent reported to examiner | Ages 2 to 2.5 years | Expressive vocabulary | Expressive vocabulary | 50

* Only the Battelle Developmental Inventory Test Receptive Language Scale is included in accuracy analyses.

ǂ Although the SPES-3 was designed as both a parent-reported and trained examiner instrument, the authors recommended that only the parent-reported subscales be included as a screen for language delay; therefore, we have classified the SPES-3 as a parent-reported instrument.

Abbreviations: CSBS=Communication and Symbolic Behavior Scales; ELFRA-2=Elternfragebogen für die Fruberkennung von Riskokindern; NR=not reported; NSST=Northwestern Syntax Screening Test; SPES-3=Sprachentwicklungsscreening; WH questions=who, when, where, why, what, and how.

Most instruments evaluated by included studies are designed to screen for global language problems. Twelve instruments (the Ages and Stages Questionnnaire,^42, 59^ the Davis Observation Checklist for Texas,^46^ the Developmental Nurse Screen,^54^ the Early Language Scale,^38^ the Fluharty Preschool Screening Test,^47^ the General Language screen,^55^ the Hackney Early Language Screening Test/Structured Screening Test,^52, 53^ the Infant-Toddler Checklist,^45^ the Nurse Screening,^39, 41^ the Parent Questionnaire,^54^ the Screening Kit of Language Development (SKOLD)/Screening Kit of Language Development Black English (SKOLDBE),^48^ and the Sentence Repetition Screening Test (language component)^57^ provide an overall score for language that was compared with a reference measure.

In contrast, nine screening tools provide scores for specific aspects of language: the Brigance Preschool Screen^42^ includes both receptive and expressive language scores; the Early Screening Profiles^42^ screens for semantic development; the Elternfragebogen für die Fruberkennung von Riskokindern (ELFRA-2),^43, 44^ the SPE-3,^40^ and the Language Development Survey (LDS) measure early expressive language;^50, 51^ the Quick Interactive Language Screener (QUILS)^58^ screens for vocabulary and syntax comprehension along with learning of new vocabulary and syntactic structures; the Sure Start Language Measure (SSLM)^59^ measures vocabulary; and the Northwest Syntax Screening Test^47^ screens for expressive and receptive knowledge of syntax. Note that although the Battelle Developmental Inventory Screening Test-Communication^42^ provides both expressive and receptive scores, the authors only provided accuracy for the receptive score.

Three of the trained examiner tools specifically screen for articulation skills—the Denver Articulation Screening Exam^49^ and the articulation portion of both the Fluharty Preschool Speech and Language Screening Test,^56^ and the Sentence Repetition Screening Test.^57^ In addition, one parent-administered instrument measured articulation.^37^ In our analysis of accuracy, we consider the articulation instruments separately from specific language instruments.

Studies used a variety of reference standards to document speech and language disorders. Measures included both global assessments of language skill such as the Preschool Language Scale, Fourth and Fifth Editions, the Reynell Developmental Language Scales, and the Test of Language Development, Primary and specific indices such as the Templin-Darley Tests of Articulation, the British Picture Vocabulary Scale, and the Test for Auditory Comprehension of Language. In some cases, studies used more than one reference measure to provide appropriate comparisons for different screening measures that were examined (e.g., Sentence Repetition Screening Test Articulation subtest with the Arizona Articulation Proficiency Scale and Sentence Repetition Screening Test Language scale with the Illinois Test of Psycholinguistic Abilities and the Bankson Language Screening Test) (Table 3).

Table 3 Accuracy of Screening Instruments to Detect Speech and Language Disorders

Instruments (Cut Point) | Screening Subtest | N | Reference Standard | Prevalence (%) | Sensitivity (%) (95% CI) | Specificity (%) (95% CI) | PPV (%) | NPV (%) | LR+ | LR−
Parent Reported
Global Language Instruments
ASQ-CD^42^; (“recommended cutoff”) | | 110 | PLS-4-C | 4 | 67 (45 to 88)^*^ | 73 (64 to 82)^*^ | 32^*^ | 92^*^ | 2.4^*^ | 0.46^*^
| | 110 | PLS-4-E | 7 | 73 (54 to 91)^*^ | 76 (67 to 85)^*^ | 43^*^ | 92^*^ | 3.0^*^ | 0.36^*^
ASQ-CD^59^; Full sample; (37.5)^†^ | | 357 | PLS-5 Total Language | 23 | 55 (44 to 66) | 95 (91 to 97) | 53 | 95 | 10.0 | 0.48
English-only sample; (47.5)^†^ | | 248 | PLS-5 Total Lanugage | NR^ǂ^ | 85 (70 to 94) | 84 (78 to 88) | 37 | 98 | 5.2 | 0.18
ELS^38^; (15) | | 265 | Composite based on LS, CCC-2, LLC, LLP, SLC, SWP, SSP | 11 | 62 (44 to 77)^*^ | 93 (89 to 96)^*^ | 53 | 95 | 9.2 | 0.41
GLS^55^; (≥2 failures) | | 596 | DP-II | 18^§^ | 75 (67 to 83)^*^ | 81 (77 to 84)^*^ | 47 | 94 | 3.9 | 0.31^*^
ITC (Study 1)^45^ (NR) | Ages 12 to 17 months version | 151 | CSBS Behavior Sample | 35 | 89 (80 to 97)^*^ | 74 (66 to 83)^*^ | 65 | 92 | 3.5^*^ | 0.15^*^
| Ages 19 to 24 months version | 81 | CSBS Behavior Sample | 52 | 86 (75 to 96)^*^ | 77 (64 to 90)^*^ | 80 | 83 | 3.7^*^ | 0.19^*^
Parent Questionnaire^54^; (≥1 abnormal response) | | 381 | SLP rating using language sample,; RDLS, Comprehension Scale | 13 | 78 (66 to 89)^†^ | 91 (88 to 94)^*^ | 56 | 96 | 8.3^*^ | 0.24^*^
Specific Language Instruments
ELFRA-2 (CDI Words and Sentences)^43, 44^; (<50 words or 50–80 words and scores for syntax <7 and morphology <2) | | 117 | SETK-2 | 59 | 93 (87 to 99)^*^ | 88 (78 to 97)^*^ | 91 | 89 | 7.3^*^ | 0.08^*^
LDS^50^ (Study 2);; (<50 words or no word combinations) | | 64 | Clinical judgment on infant MSEL language scales, MLU | 17 | 91 (74 to 100)^*^ | 87 (78 to 96)^*^ | 59 | 98 | 6.9^*^ | 0.10^*^
LDS^51^; (>28 screening score) | | 64 | | | 91 (74 to 100)^*^ | 96 (91 to 100)^*^ | 83 | 98 | 24.1^*^ | 0.09^*^
SPES-3^40^; (<41.69) | | 2,044^‖^ | Composite of SETK-3, AWST-R, language sample | 10^¶^ | 88 (77 to 98) | 88 (86 to 90) | 44 | 98 | 7.1 | 0.14
SSLM^59^; Full sample; (19.5)^†^ | | 357 | PLS-5 | 23 | 83 (74 to 91) | 81 (76 to 85) | 33 | 98 | 4.4 | 0.21
English-only sample; (16.5)^†^ | | 248 | PLS-5 | NR^ǂ^ | 80 (64 to 91) | 87 (82 to 91) | 41 | 98 | 6.2 | 0.23
Articulation
ICS-TC^37^; (4.29) | | 789 | HKCAT | 19^*^ | 86 (79 to 90)^*^ | 32 (28 to 36)^*^ | 22^*^ | 91^*^ | 1.3^*^ | 0.45^*^
Trained Examiner
Global Language Instruments
DOCT^46^ (NR) | | 59 | Composite of MSCA, GFTA, informal language sample | 17 | 80 (55 to 100)^*^ | 98 (94 to 100)^*^ | 89^*^ | 96^*^ | 39.2^*^ | 0.20^*^
DNS^54^ (NR) | | 378 | SLP rating using language sample and RDLS, Comprehension Scale | NR | 76 | 97 | 80 | 96 | NR | NR
FPST^47^; (≥1 subtest) | | 182 | SICD | 14 | 60 (41 to 79)^*^ | 81 (75 to 87)^*^ | 33^*^ | 93^*^ | 3.1^*^ | 0.49^*^
FPSLST^56^ (NR) | Language Study 1; Language Study 2 | 51; 147 | TACL-R; TOLD-P | 17; 22^¶^ | 38; 17 | 85; 97 | 42; 50 | NR; NR | NR; NR | NR; NR
HELST^53^; (≤10) | | 189 | RDLS | 26 | 98 (94 to 100)^*^ | 69 (61 to 77)^*^ | 53 | 98 | 3.1^*^ | 0.03^*^
SST^52^; (<10) | | 282 | RDLS | 23 | 66 (53 to 76)^*^ | 89 (85 to 93)^*^ | 65^*^ | 90^*^ | 6.2^*^ | 0.38^*^
Nurse Screening^39^; (<3 words) | | 105^#^ | RDLS, Comprehension Scale and spontaneous language observation | 10 | 100 (72 to 100) | 81 (71 to 88) | 38 | 100 | 5.2 | 0
Nurse Screening^39^; (≥3 comprehension questions and ≥2 word combinations) | | 105^#^ | RDLS, Comprehension Scale and spontaneous language observation | 10 | 91 (71 to 88) | 91 (59 to 100) | 56 | 99 | 19.7 | 0.1
Nurse Screening^41^; (≥3 comprehension questions and ≥2 word combinations) | Model 3 – screening in Swedish and maternal language | 111^#^ | RDLS, Comprehension Scale and spontaneous language observation | 29 | 88 (71 to 96) | 82 (72 to 90) | 67 | 94 | 4.9 | 0.15
SKOLD/SKOLDBE^48^; (<11) | S30 | 47 | SICD | 6 | 100 (100 to 100)^*^ | 98 (93 to 100)^*^ | 75^*^ | 100^*^ | 44.0^*^ | 0^*^
(<10) | S37 | 93 | SICD | 11 | 100 (100 to 100)^*^ | 91 (85 to 97)^*^ | 33^*^ | 100^*^ | 11.1^*^ | 0
(<19) | S43 | 100 | SICD | 9 | 100 (100 to 100)^*^ | 93 (88 to 98)^*^ | 60^*^ | 100^*^ | 15.2^*^ | 0^*^
(<9) | B30 | 75 | SICD | 12 | 89 (68 to 100)^*^ | 86 (78 to 95)^*^ | 47^*^ | 98^*^ | 6.5^*^ | 0.13^*^
(<14) | B27 | 91 | SICD | 9 | 88 (65 to 100)^*^ | 86 (78 to 92)^*^ | 37^*^ | 99^*^ | 6.0^*^ | 0.15^*^
(<19) | B43 | 54 | SICD | 33 | 94 (84 to 100)^*^ | 78 (64 to 91)^*^ | 68^*^ | 97^*^ | 4.2^*^ | 0.07^*^
SRST^57^; (<20th percentile) | SRST Language | 323^**^ | ITPA/BLST | 11 | 62 (45 to 78)^*^ | 91 (87 to 94)^*^ | 44 | 95^*^ | 6.6^*^ | 0.42^*^
Specific Language Instruments
BDIST-CD^42^; (ROC optimal cutoff) | Receptive^††^ | 110 | PLS-4-C | 4 | 56 (33 to 78)^*^ | 70 (60 to 79)^*^ | 26^*^ | 89^*^ | 1.8^*^ | 0.89^*^
BPS^42^; (ROC optimal cutoff) | Receptive | 110 | PLS-4-C | 4 | 61 (39 to 84)^*^ | 60 (50 to 70)^*^ | 23^*^ | 89^*^ | 1.5^*^ | 0.65^*^
| Expressive | 110 | PLS-4-E | 7 | 91 (79 to 100)^*^ | 78 (70 to 87)^*^ | 51^*^ | 97^*^ | 4.2^*^ | 0.12^*^
ESP^42^; (>1 SD below mean) | Verbal concepts | 110 | PLS-4-C | 4 | 94 (84 to 100)^*^ | 68 (59 to 78)^*^ | 40^*^ | 98^*^ | 3.0^*^ | 0.08^*^
| Verbal concepts | 110 | PLS-4-E | 7 | 86 (72 to 100)^*^ | 81 (72 to 89)^*^ | 53^*^ | 96^*^ | 4.5^*^ | 0.17^*^
NSST^47^; (Failure ≥1 subtest) | | 182 | SICD | 14 | 92 (81 to 100)^*^ | 48 (41 to 56)^*^ | 22^*^ | 97^*^ | 1.8^*^ | 0.16^*^
QUILS^58^ (Study 2 only) (<25th percentile) | Composite | 126 | PLS-5 Auditory Comprehension | 20 | 60 (51 to 69)^*^ | 90 (70 to 96)^*^ | 95^*^ | 35^*^ | 6.0 | 0.66
Articulation Instruments
DASE^49^; (<15th percentile) | | 150 | HAT | NR | 92 | 97 | NR | NR | NR | NR
FPSLST^56^ (NR) | Articulation Study 1; Articulation Study 2 | 51; 147 | AAPS-R; TD | 4^¶^; 5^¶^ | 74; 43 | 96; 93 | 50; 26 | NR; NR | NR; NR | NR; NR
SRST^57^; (<20th percentile) | SRST Articulation | 325^**^ | AAPS-R | 19 | 57 (45 to 69)^*^ | 95 (93 to 98)^*^ | 75 | 90^*^ | 12.5^*^ | .045^*^

* Calculated by the EPC.

† Optimal cut point using Youden’s index

ǂ Prevalence was not reported for this subsample. Median for sensitivity/specificity includes full sample only and not the English-speaking subsample.

§ Prevalence for screen failures >1.5 SD below the mean is 18 percent; study calculated accuracy using this value as well as prevalence using cut point of >2 SD below the mean, which was 6 percent. We only include data for the former prevalence.

‖ Sample size and prevalence based on imputed sample, which corrected for oversampling of children with positive screening.

¶ Prevalence data provided by study authors.

# Includes 11 children who were noncooperative during screening.

** The study investigators weighted the n’s based on a stratified sample of 69.

†† Only the BDIST-CD Receptive Scale is included in accuracy analyses.

Abbreviations: AAPS-R=Arizona Articulation Proficiency Scale-Revised; ASQ-CD=Ages and Stages Questionnaire-Communication Domain; AWST-R=Aktiver Wortschatztest für 3-bis 5-jährige Kinder; BDIST-CD=Battelle Developmental Inventory Screening Test-Communication Domain; BLST=Bankson Language Screening Test; BPS=Brigance Preschool Screen; BPVS=British Picture Vocabulary Scale; CCC-2=Children’s Communication Checklist, 2^nd^ Edition-Netherlands; CI=confidence interval; CSBS=Communication and Symbolic Behavior Scales; DASE=Denver Articulation Screening Exam; DNS=Developmental Nurse Screen; DOCT=Davis Observational Checklist for Texas; DP-II=Developmental Profile-II; EAT=Edinburgh Articulation Test; ELFRA-2=Elternfragebogen für die Fruberkennung von Riskokindern; ELS=Early Language Scale; EPC=Evidence-based Practice Center; ESP=Early Screening Profiles; FPSLST=Fluharty Preschool Speech and Language Screening Test; FPST=Fluharty Preschool Screening Test; GFTA=Goldman-Fristoe Test of Articulation; GLS=General Language Screen; HAT=Henja Articulation Test; HELST=Hackney Early Language Screening Test; HKCAT=Hong Kong Cantonese Articulation Test; ICS-TC=Intelligibility in Context Scale-Traditional Chinese; ITPA=Illinois Test of Psycholinguistic Abilities; LDS=Language Development Survey; LLC=Lexilist Comprehension; LLP=Lexilist Production; LR+=positive likelihood ratio; LR=negative likelihood ratio; LS=Language Standard; MLU=Mean Length of Utterance; MSCA=McCarthy Scales of Children’s Abilities; MSEL=Mullen Scales of Early Learning; NPV=negative predictive value; NR=not reported; NSST=Northwestern Syntax Screening Test; PLS-4-C=Preschool Language Scale, Fourth Edition-Comprehension, PLS-4-E=Preschool Language Scale, Fourth Edition-Expression; PLS-5=Preschool Language Scale, Fifth Edition; PPV=positive predictive value; QUILS=Quick Interactive Language Screener; RDLS=Reynell Developmental Language Scales; SD=standard deviation; SETK-2=Sprachentwicklungstest für zweijahrige Kinder; SETK-3=Sprachentwicklungstest für zweijahrige Kinder; SICD=Sequenced Inventory of Communication Development; SKOLD=Screening Kit of Language Development; SKOLDBE=Screening Kit of Language Development Black English; SLC=Schlichting Tests for Language Comprehension; SLP=speech-language pathologist; SPES-3=Sprachentwicklungsscreening; SSP=Schlichting Tests for Sentence Production; SRST=Sentence Repetition Screening Test; SSLM=Sure Start Language Measure; SST=Structured Screening Test; SWP=Schlichting Tests for Word Production; TACL-R=Test for Auditory Comprehension of Language–Revised; TD=Templin-Darley Tests of Articulation Consonant Singles Subtest; TOLD-P=Test of Language Development Primary.

Excluding the two studies^43, 45^ that enrolled all children who screened positive and a random sample of children who screened negative, the prevalence of speech and language disorders based on reference standards ranged between 4 percent and 33 percent, with a median prevalence of 14 percent (Table 3). For studies that included multiple instruments using the same reference measure, the prevalence was calculated only once. Although we did include different prevalence values for studies that included different reference measures, we did not consider prevalence based on different reference measure cut points.

#### Accuracy of Instruments

To examine accuracy, we considered both the source of the information (parent report vs. trained examiner) and whether the instrument was designed as a global index of language, a specific measure of language skills (e.g., word knowledge), or a measure of articulation. Table 3 provides accuracy for instruments categorized by global language, specific language, and articulation instruments within parent-reported tools and within trained examiner tools.

##### Parent Reported

As shown in Table 3, both sensitivity and specificity varied greatly in screening tools that used parent reports. Across the 14 indices of sensitivity, the median was 84 percent, with a range of 55 to 93 percent. The median specificity was 84 percent, and the variability was somewhat greater than for sensitivity, ranging between 32 percent and 96 percent. Note that some instruments included two subtests or calculated accuracy with different reference measures that did figure into the median calculations, but two indices in Table 3 are for an English-speaking-only subset whose values were not included in the median calculations.

Instruments for global language vs. specific language vs. articulation. Just examining the global language instruments based on parent reports, the median sensitivity was 74 percent, ranging between 55 percent and 89 percent. Specificity was somewhat less variable, ranging between 73 percent and 95 percent with a median of 79 percent. In contrast, both sensitivity and specificity of the parent-reported instruments of specific skills (all emerging expressive language skills) were fairly consistent and high: median sensitivity of 91 percent, ranging between 83 percent and 93 percent, and the median specificity was 88 percent, ranging between 81 percent and 96 percent. The one parent-rated measure of articulation had a reasonably high sensitivity (86%) but a low specificity (32%). In the studies in which parent reports were used, two showed high positive likelihood ratios indicating a high likelihood of a language delay or disorder for children who screened positive, the LDS^51^ (using a revised scoring method) and one study of the ASQ—24.1 and 10.0, respectively.^59^ The two studies assessing the ASQ found inconsistent results, but also varied in terms of population (age and recruitment setting, and used different reference standards.^42, 59^ Both the LDS and the ELFRA-2^43, 44^ displayed high negative LRs (0.09 and 0.08, respectively), indicating low odds of a language delay in children with a negative screen. No other parent report instrument showed either large positive LRs or negative LRs, although quite a few displayed moderate LRs, suggesting utility for identifying children for whom further evaluation could be beneficial.

##### Trained Examiners

Table 3 provides the accuracy of 13 screening tools that trained examiners administered to children. The median sensitivity of these instruments was 87 percent, with a range of 17 to 100 percent, and the median specificity was 88 percent, with a range of 58 to 98 percent. Similar to parental-reported instruments, there is substantial variability in the accuracy of examiner-administered tools.

Instruments for global language vs. specific language vs. articulation. Restricting the accuracy summary to trained examiner screenings of global language shows that the median sensitivity and specificity were 88 and 89 percent, respectively; sensitivity ranged between 17 percent and 100 percent, and specificity ranged between 69 percent and 98 percent. The median sensitivity of trained examiner instruments for specific language skills was 86 percent, ranging between 56 percent and 94 percent, but the median specificity was 70 percent, ranging between 58 percent and 90 percent. Across the three trained examiner tools for assessing articulation, the median sensitivity was only 66 percent, ranging between 43 percent and 92 percent; however, the median specificity was 96 percent, with a range of 93 to 97 percent. Several trained examiner instruments display high likelihood ratios, suggesting that they may be useful for both ruling in a diagnosis and ruling out a diagnosis of a language delay or disorder. Failures on three trained examiner global instruments, the Davis Observation Checklist for Texas,^46^ the Nurse Screening revised scoring,^39^ and the SKOLD/SKOLDBE,^48^ each indicate a large increase in the likelihood of a language delay or disorder. Failure on the articulation portion of the Sentence Repetition Screening Test^57^ also indicates a large increase in the likelihood of an articulation disorder. Passing scores on two trained examiner instruments of global language, the Hackney Early Language Screen Test^53^ and the SKOLD/SKOLDBE^48^ and on one examiner instrument of specific language skills, the Early Screening Profiles,^42^ indicate a large decrease in the likelihood of a language disorder.

### KQ 3. What Are the Harms of Screening for Speech and Language Delay or Disorders in Children Age 5 Years or Younger?

We found no eligible study that addressed this question.

### KQ 4. Do Interventions for Speech and Language Delay or Disorders in Children Age 6 Years or Younger Improve Speech and Language Outcomes?

#### Summary

Seventeen RCTs (18 articles) compared an intervention for a speech and language delay or disorder (SLD) with an inactive control. Eight RCTs assessed interventions specific to children with language delay and no obvious fluency or speech-sound impairment. Of these, three RCTs focused on parent-delivered, group training interventions, with two evaluating more intensive interventions delivered over a longer duration (11 bimonthly 60- to 75-minute sessions^60^ and 11 weekly 2.5-hour sessions followed by 3 weekly home visits^61^) found benefit for different expressive language outcome measures. One intervention delivered over six weekly 2-hour sessions found no significant difference between groups for any language outcome measure.^62^ Other interventions for language delay varied by delivery setting, population, and other factors. In general, results were inconsistent, with some studies showing improvement in some measures of receptive or expressive language but others not. Two RCTs assessed treatment for young children based on the Lidcombe Program of Early Stuttering Intervention delivered by an SLP. This intervention features parent training to provide verbal contingencies for stutter-free speech (e.g., “that was smooth talking”) and stuttering (e.g., “that was a bit bumpy”). Both RCTs found benefit for reducing stuttering frequency associated with the intervention at 9 months. One delivered the intervention face-to-face in a clinic setting and showed a 2.3 percent lower proportion of syllables stuttered (95% CI, 0.8 to 3.9) compared with the control group, and one RCT that delivered the intervention via telehealth showed a larger reduction from baseline mean number of syllables in the intervention group than controls (-3.0; p=0.02). Three RCTs assessed interventions for three distinct types of speech-sound disorders with inconsistent results; each showed improvement on some measures of speech but not others. Two RCTs evaluated treatment for children newly referred from primary care for any speech or language problem and found inconsistent results, with improvement on some domains of speech and language but not others, and no consistent benefit across similar outcome domains.

#### Detailed Evidence

Seventeen RCTs (18 articles) compared an intervention for SLD with an inactive control (either no treatment or wait-list control/delayed treatment).^60–77^ Characteristics of studies are shown in Appendix E Table 1. Most RCTs were set in the United States (4 studies),^66, 69, 75, 76^ Australia (5 studies),^62–64, 74, 77^ or Canada (4 studies).^61, 65, 68, 70^ Two studies were set in the United Kingdom^60, 72^ and one study each was set in Spain^67^ and New Zealand.^73^ No studies enrolled children identified by routine screening in primary care settings; however, one cluster-randomized trial of Australian maternal and child health centers recruited participants, who had not been previously referred for cognitive problems, autism, or major medical problems, during their routine 12-month visit (or by mail if they did not attend). Parents who consented to participate in the trial and spoke sufficient English to participate were mailed screening expressive vocabulary checklists to determine eligibility.^62^ Most studies recruited participants from schools or early childhood education centers (4 studies),^64, 67, 69, 75^ or from referrals to speech and language treatment centers (6 studies).^60, 63, 68, 70, 72, 73^ Four studies recruited participants via advertisements^74^ or a mix of advertisements and outreach to schools, clinical settings, or community-based programs to identify participants,^65, 66, 76^ and one recruited participants from two previous population-based early childhood trials that focused on promoting literacy and language development.^77^

The mean age of enrolled populations ranged from 18.1 to 67.8 months; most (10 studies) included a population with a mean age of 48.4 months or older. The proportion of enrolled children who were female ranged from 10 to 49 percent. Few (4 studies) described the race/ethnicity of enrolled children. Three of these were set in the United States, one enrolled a population that was 100 percent Latino,^66^ one enrolled a population that was 100 percent White,^76^ and one enrolled a population that was mostly White (54%) and also inclusive of persons who identified as Black (2%), Hispanic (26%), multiracial (12%), American Indian (2%), and Asian (3%).^69^ Study sample size ranged from 20 to 301.

Included RCTs evaluated heterogeneous interventions that were targeted to different populations of children (e.g., any delay or disorder, speech disorders only) and also varied by setting, intensity/duration, and delivery personnel (Appendix E Table 1). Most studies focused on individual therapy administered by an SLP in a clinical setting, or parent training to deliver interventions for young children with language delay. Three focused on interventions delivered in schools, including two that featured whole-class curriculum components to advance language and literary skills^67, 69^ and one individual intervention for children with a speech sound disorder.^64^ Results are summarized below by intervention target and setting.

#### Results

##### Language Delay Interventions

Across eight RCTs (9 articles) evaluating interventions for young children with delayed acquisition of expressive language or “late talkers,” six RCTs demonstrated positive effects on child receptive and expressive communication,^60, 61, 65, 66, 71, 75, 76^ and two found mixed results or no statistically significant differences between groups with regard to child language outcomes.^62, 77^ Four interventions were primarily implemented by parents who were trained by clinicians;^60–62, 66^ others were primarily delivered by SLPs either alone^76^ or in collaboration with parents^65^ or trained peers,^75^ and one was delivered by trained but nonspecialist staff.^77^ Detailed results are shown in Appendix E Table 2.

Parent-implemented language delay interventions. Four RCTs assessed parent-implemented interventions involving parent participation in community workshops where parents were trained by program leaders in naturalistic strategies for promoting their child’s language development.^60–62, 66^ Although training approaches and specific content varied, all included naturalistic strategies such as expanding a child’s utterances, following the child’s interests, repeating what the child says, and setting up the environment to encourage communication.

In the three RCTs evaluating group training interventions, two RCTs evaluated modifications of the Hanen Program^®^ for Parents curriculum, which uses a combination of group training sessions composed of a small group of parents and a trained SLP or other trained facilitator, and individual consultations with the SLP while the child is present,^61, 62^ and one evaluated a parental training program to improve child linguistic complexity.^60^ Two RCTs that assessed group training over a longer duration and higher intensity found benefit for various language outcomes measures. (Appendix E Table 2). One RCT (n=25), which delivered the training program with the addition of specific vocabulary targets over eight 2.5-hour parent training sessions and three home coaching visits, saw statistically significant improvements in child vocabulary, utterance length, and utterance complexity in favor of the intervention at 14 weeks. (Cohen’s d effect sizes ranged from 0.62 to 1.13 across measures, indicating a medium to large effect size,^61^ and the second evaluated parental training delivered more than 11 bimonthly 60- to 75-minute training sessions (n=36) and found statistically significant improvement in child expressive and receptive language outcomes among the intervention group compared to the control group (Appendix E Table 2).^60^ The RCT assessing a condensed version of the Hanan program (n=301) that delivered more than six weekly 2-hour parent educational sessions found no statistically significant differences between groups on language outcomes at 6 and 18 months post-intervention (2 and 3 years from baseline).^62^

The RCT evaluating parent training delivered during individual home-based sessions led by trained coaches ^60^ (n=21), culturally and linguistically tailored to Spanish-speaking families in the United States, found mixed results.^66^ The intervention group had significantly higher scores on measures of receptive language vocabularies (measured by the Receptive One-Word Picture Vocabulary Test-4, Spanish-Bilingual Edition) than the control group at 26 weeks (mean score: 11.29 vs. 6.53; p=0.050). However, no statistically significant difference between groups was found for other outcomes, including expressive vocabulary number of different words used and number of total words used (Appendix E Table 2).^66^

Clinician-implemented interventions. Four RCTs assessing an intervention for language delay enrolled heterogeneous populations and evaluated different interventions.^65, 75–77^ One RCT (n=21) enrolled toddlers (mean age 21 to 30 months) identified with language delay but normal oral and speech motor abilities and compared an individual intervention delivered by an SLP over 12 weeks, including twice weekly 75-minute sessions designed to be interactive and emphasizing vocabulary development, with a wait-list control group.^76^ At 12 weeks, children in the intervention group showed statistically significant improvements on all measures of linguistic growth and speech intelligibility, including total number of words used, number of different words used, mean length of utterances, and others (Appendix E Table 2).

Three other RCTs assessed various interventions for slightly older children with language delay (mean age ranged from 49.5 to 59.6 months).^65, 75, 77^ Interventions differed in terms of setting. Two individual interventions found improvement on some outcome measures but not others. One RCT (n=20) evaluated an intervention providing individual home-based therapy delivered by trained assistants to promote narrative skills, vocabulary, grammar, phonological awareness, and preliteracy skills (18 1-hour sessions in total).^77^ One year after enrollment, children in the intervention group had a significantly higher improvements from baseline in terms of phonological awareness than the control group (between-group difference in Comprehensive Test of Phonological Processing score change: 5.0; 95% CI, 2.2 to 7.8) but not other measures, including expressive and receptive language and pragmatic language skills (Appendix E Table 2). The second RCT (n=29) evaluated two versions of individual therapy for bilingual children (set in Canada) compared with a wait-list control.^65^ Both active interventions included individual treatment plans based on targets set by SLPs, vocabulary training, and activities involving retelling stories as well as homework assignments delivered over 16 weekly individual sessions (50 minutes each). In the monolingual treatment arm, the intervention was delivered by French SLPs with no parental participation. In the bilingual treatment arm, the SLP collaborated with home-speaking parents who helped provide models of therapy targets in their respective languages (with instruction by SLPs for how to participate and demonstrate goals). Results were mixed. Significantly greater gains in French vocabulary were seen in both treatment groups compared with the control group, but no statistically significant differences were seen between groups on formal language test measures, such as the Expressive One-Word Picture Vocabulary Test and Reynell Developmental Language Scales (Appendix E Table 2).

Finally, one RCT (n=20) evaluated an intervention that focused on pairing children with specific language impairment (SLI) with a peer who had typical language development in a research setting designed for an interactive plan.^75^ Verbal scripts for playing house were elicited from children at baseline and at followup by investigators who told the children they were trying to teach younger children how to play house and encouraged the children to tell what they knew using prompting questions (e.g., “What do you do when you play house?”). During the intervention, children with SLI were paired with a different peer for four 15-minute play sessions. At 3 weeks, based on transcripts from play scripts, children in the intervention group had a statistically significant increase in the number of words used, the number of different words used, and the number of linguistic markers used (terms indicating temporal sequence) compared with the control group (authors report p-values only).^75^

##### School-Based Curriculum Interventions

Two RCTs delivered interventions featuring school-based whole-class curriculum components (or Tier 1 interventions) designed to advance language and literary skills over the course of an academic school year.^67, 69^ Curriculum components focus on story retelling and generation supported by activities and resources provided by research staff. Although all children in the intervention schools received the curriculum, outcomes were measured in children with developmental speech and/or language impairment. Both RCTs demonstrated improved receptive and expressive language outcomes in favor of the intervention; however, one found improvement for some measures but not others.^69^ One RCT (n=50) reported F-ratios from analysis of variance measures and p-values only (no pre-post means or differences between groups in score changes). The authors report statistically significant differences in favor of the intervention for measures of oral comprehension, verbal working memory, and semantic fluency (Appendix E Table 3).^67^ The second RCT (n=289) found significant improvements in favor of the intervention group on a receptive and expressive one-word picture vocabulary test that assessed higher-level receptive and expressive vocabulary targeted by the intervention that were measured pre- vs. post-intervention each fall and spring school session.^69^

##### Clinic-Based Speech-Language Interventions

Two RCTs evaluated the benefit of clinic-based individualized speech-language treatment among referred children with SLD with mixed results.^63, 72^ Both RCTs focus on the benefit of available treatment in community clinics for children recently referred from primary care for speech and/or language problems. The intervention strategies are not clearly defined; however, they reflect usual care for children recently identified with speech or language concerns who have no specific criteria in terms of the type of disorder or whether they met specific diagnostic criteria prior to starting therapy. One RCT (n=159) enrolled children referred to 16 speech-language clinics in the United Kingdom and found benefit for auditory comprehension at 12 months among the intervention group compared with controls (difference in means on the age-adjusted Preschool Language Scale, auditory comprehension subscale: 4.1; 95% confidence interval [CI], 0.5 to 7.6; p=0.025) but not for measures of expressive language or phonological error rate.^72^ Of note, children received relatively few contact hours of intervention over the 12-month study period (mean=6.2 hours; range 1 to 15 hours).^72^ The second RCT (n=101) compared individual therapy offered at two Australian community-based centers for speech and/or language problems with two control groups involving brief advice or referral to a website for resources (both groups were on a wait-list). The treatment consisted of 12 weekly 45-minute individualized speech-language therapy sessions. There were statistically significant improvements in child speech as measured by the mean percent of consonants correct, among the intervention group (7.40) compared with the advice control (-4.72) and device control (-3.57) at 6 months (p<0.001), but no difference between groups for measures of intelligibility or language outcomes.^63^

##### Speech Sound Interventions

Three RCTs assessed the benefit of treatments specific to speech sound disorders.^64, 68, 70^ One RCT set in schools delivered a software-based intervention with assistance from teachers,^64^ and two were clinic-based treatments delivered by SLPs.^68, 70^

The intervention set in schools was a cluster RCT assessing an individual customizable software-based intervention for children diagnosed with a speech disorder who had no difficulty with receptive language over 9 weeks in 18 individual sessions.^64^ The software included seven interactive games that could be customized based on the speech sound targets of a specific child. Children listened and responded to auditory and visual cues, and teachers provided technical support when needed. No difference was found between groups in change from baseline at 6 to 8 weeks post-intervention on the percentage of correct consonants spoken (measured using the Diagnostic Evaluation of Articulation and Phonology); similar improvement was seen in the intervention and control groups (+6.15 versus +5.43, respectively; p=0.874).^64^ Similarly, no significant between-group difference was seen for speech intelligibility (measured by a validated parent-reported instrument, the Intelligibility in Context Scale) in the intervention group (+0.22) versus the control group (+0.11) at 6 to 8 weeks post-intervention (p=0.726).

The two RCTs assessing an intervention delivered by SLPs in a clinical setting differed in terms of the specific type of speech disorder targeted. One RCT (n=26), which compared individual phonological therapy and was administered by an SLP twice weekly in a clinical setting for 4 months, compared with a no treatment control group of children with a severe phonological disorder who had normal receptive language function.^70^ At 4 months, the intervention group had statistically significant lower phonological processing errors than the control group, as well as statistically significant improvements across multiple measures of speech articulation (Appendix E Table 3). The second RCT (n=45) examined the efficacy of the Prompts for Restructuring Oral Muscular Phonetic Targets intervention for children with severe speech motor delay.^68^ Following twice weekly 45-minute sessions over 10 weeks, statistically significant improvements were seen in speech motor control, articulation, and word-level speech intelligibility associated with the intervention, but no significant differences between groups was seen for measures of sentence-level speech intelligibility or functional communication compared with the control group (Appendix E Table 3).

##### Fluency Interventions

Two RCTs assessed fluency treatment for young children, with both studies focusing on the Lidcombe Program of Early Stuttering Intervention.^73, 74^ This intervention is led by an SLP who trains parents to provide verbal contingencies for stutter-free speech (e.g., “that was smooth talking”) and stuttering (e.g., “that was a bit bumpy”), and requests for self-evaluation and self-correction (e.g., “can you say that again?”). The treatment starts at a high intensity of daily parent-implemented sessions and weekly meetings with the SLP and is systematically withdrawn as the child’s fluency improves. In one RCT, the intervention was delivered in a face-to-face format in a clinical setting^73^ and in the other it was delivered via telehealth.^74^ Results were consistent in showing a statistically significant improvement in stuttering fluency associated with the intervention. In the face-to-face intervention, children in the intervention group had a 2.3 percent lower proportion of syllables stuttered than children in the control group (95% CI, 0.8 to 3.9) at 9 months. Per the authors, this is above the minimum clinically important difference of 1.0 percent of syllables stuttered (the minimum difference that a listener would be able to distinguish).^73^ However, no reference or clear rationale was provided to support this threshold. In the RCT using telehealth delivery of the intervention, the difference between the intervention and control group in change from baseline mean number of syllables stuttered was -3.0% (p=0.02) at 9 months.^74^

### KQ 5. Do Interventions for Speech and Language Delay or Disorders in Children Age 6 Years or Younger Improve School Performance, Function, or Quality-of-Life Outcomes?

#### Summary

Eight RCTs reported on one or more outcomes specific to school performance, function, or quality of life using heterogeneous measures. No studies of the same intervention reported on similar measures of school performance, behavior, or well-being.^62–64, 68, 69, 72, 76, 77^ No two studies assessing a similar intervention type reported on the same outcome domain. In four RCTs reporting on a measure of early literacy, three found no significant difference between groups and one RCT assessing a home-based language delay intervention delivered by trained assistants found benefit for improving letter knowledge associated with the intervention.^77^ No study reported benefit for improving function or quality of life among children; one individual intervention for language delay found significant improvement favoring the intervention for improving socialization and parental stress levels.^76^

#### Detailed Evidence

Eight RCTs reported on one or more outcomes specific to school performance, function, or quality of life using heterogeneous measures.^62–64, 68, 69, 72, 76, 77^ Characteristics are described above in KQ 4 and detailed results are shown in Appendix E Table 4.

##### Function

Two RCTs of different intervention types measured functional communication, including participation and function in contexts of speech, language use, play, and socialization; neither of the trials found a statistically significant difference between intervention and control groups at followup.^63, 68^

##### Academic Performance

Four RCTs collected data on early academic skills, specifically early or emergent literacy skills. ^63, 64, 69, 77^ Of these, one RCT of individual home-based therapy for children with language delay found improved letter knowledge among the intervention group compared with children in the control group at 52 weeks.^77^ No significant difference was seen on measures of emergent literacy skills in three other RCTs, including one assessing a preschool classroom-based language and literacy intervention one cluster RCT of a school-based individual intervention for children with a speech disorder,^64^ and one community-based clinical intervention for children referred from primary care (Appendix E Table 4).^63^

##### Attention/Behavior/Socialization or Play Skills

Three studies reported on attention, behavior, social, or play outcomes of intervention in children with SLD. ^62, 72, 76^ In one RCT of speech-language treatment in the United Kingdom, no significant differences between groups were found for measures of child attention, socialization, and play at one year following a low-intensity individual treatment with community-based SLPs.^72^ One RCT featuring a 12-week clinician-implemented language intervention program for late talkers found a significant increase in child socialization skills among the intervention group compared with the wait-list control group as measured by the Socialization Domain of the Vineland Adaptive Behavior Scales (p=0.003).^76^ Finally, no difference was seen on measures of child behavior in an RCT comparing a 6-week parent training program on naturalistic language strategies and control at 1 and 2 years post-intervention.^62^

##### Well-Being

Two RCTs reporting on child well-being using different measures and assessing different intervention types found no significant difference between intervention and control groups (Appendix E Table 4).^64, 72^ One RCT reported on change in parental stress following a 12-week individual clinician-implemented language intervention and reported significant reductions in stress among the intervention group parents compared with the control group parents.^76^

### KQ 6. What Are the Harms of Interventions for Speech and Language Delay or Disorders?

We found no eligible study that addressed this question.