# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope and KQs were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers. The analytic framework and KQs that guided the review are shown in Figure 1. Six KQs were developed for this review:

1. Does screening for speech and language delay or disorders in children age 5 years or younger improve speech and language outcomes, school performance, function, or quality-of-life outcomes?
2. What is the accuracy of screening tools to detect speech and language delay or disorders in children age 5 years or younger?
3. What are the harms of screening for speech and language delay or disorders in children age 5 years or younger?
4. Do interventions for speech and language delay or disorders in children age 6 years or younger improve speech and language outcomes?
5. Do interventions for speech and language delay or disorders in children age 6 years or younger improve school performance, function, or quality-of-life outcomes?
6. What are the harms of interventions for speech and language delay or disorders?

Figure 1 Analytic Framework

Figure 1 depicts the key questions within the context of the eligible populations, screenings, interventions, comparisons, outcomes, settings, and study designs. On the left, the population of interest is children age 5 years or younger. Moving from left to right, the figure illustrates the overarching key question (KQ): Does screening for speech and language delay or disorders in children age 5 years or younger improve speech and language outcomes, school performance, function, or quality-of-life outcomes (KQ 1). The figure depicts the question: What is the accuracy of screening tools to detect speech and language delay and disorders in children age 5 years or younger (KQ 2). Screening may result in harms (KQ 3). After detection of speech and language delay or disorders, the figure illustrates the following questions: Do interventions for speech and language delay or disorders in children age 6 years or younger improve speech and language outcomes (KQ 4) and do interventions for speech and language delay or disorders in children age 6 years or younger improve school performance, function, or quality-of-life outcomes (KQ 5). Interventions for speech and language delay or disorders may result in harms (KQ 6).

In addition to addressing the KQs, this review also looked for evidence related to the three contextual questions (CQs) listed below. These CQs were not a part of this systematic review. They are intended to provide additional background information. Literature addressing the CQs is summarized in Appendix A.

1. Are there disparities in the prevalence of speech and language delay or disorders among specific populations of children? If so, what factors contribute to these disparities?
2. Are there disparities in the detection of speech and language delay or disorders in clinical practice and referral for diagnostic evaluation among specific populations of children? If so, what factors contribute to these disparities?
3. Are there disparities in the provision and utilization of treatment for speech and language delay or disorders among specific populations of children? If so, what factors contribute to these disparities?

## Data Sources and Searches

PubMed/MEDLINE, the Cochrane Library, APA PsycInfo, ERIC, and Linguistic and Language Behavior Abstracts (ProQuest) were searched for English language articles published through January 17, 2023. Medical Subject Headings were used as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. The model PubMed/MEDLINE search was peer reviewed by the Scientific Resource Center librarian for the EPC Program, who recommended the addition of database searches for interventions in ERIC and Linguistic and Language Behavior Abstracts. Complete search terms and limits are listed in Appendix B. Targeted searches for unpublished literature were conducted by searching ClinicalTrials.gov. To supplement electronic searches, the reference lists of pertinent review articles and studies that met the inclusion criteria were reviewed. Studies suggested by peer reviewers or public comment respondents were also reviewed and, if appropriate, incorporated into the final review. Since January 17, 2023, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on November 24, 2023, and no additional studies meeting eligibility criteria were identified. All literature search results were managed using EndNote™ version 9.2 (Thomson Reuters, New York, NY).

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs with input from the USPSTF (Appendix B). We included studies published in English enrolling children age 5 years or younger who communicate using any language conducted in countries categorized as “very high” on the Human Development Index.^30^ We excluded studies limited to children who were preterm infants (<36 weeks of gestation) or who had known conditions associated with speech and language delay or disorders, such as selective mutism, hearing impairment, developmental disorders (e.g., Down syndrome, fragile X syndrome, and autism), craniofacial anomalies, or neurological and neurogenetic disorders.

For studies relevant to KQs specific to the benefits and harms of screening (KQs 1 and 3) and screening test accuracy (KQ 2), we included unselected or explicitly asymptomatic children age 5 years or younger enrolled from primary care settings or primary care–relevant settings, including childcare, schools, and other education settings. Studies using any validated screening questionnaire or procedure designed to identify speech and/or language delay or disorder applicable for use in primary care settings were eligible, including those requiring 10 minutes or less to administer or to be interpreted in a primary care setting, as well as longer questionnaires completed by parents or teachers that are interpreted by primary care providers. General developmental screening instruments that do not include a separate component for speech and language skills were excluded.

For studies assessing the benefits and harms of interventions (KQs 4, 5, and 6), studies enrolling children referred for treatment from primary care, or children identified by educators or parents as having a possible speech or language problem were also eligible. Treatment studies enrolling children up to age 6 years were also eligible given that children who would be screened at age 5 years and referred for treatment may not receive services immediately. Any interventions designed to improve speech and/or language among eligible populations of children were eligible, including those delivered in various formats (e.g., individual or group settings, face-to-face, or via telehealth) and delivery personnel (e.g., SLPs or other clinicians, parents, or teachers).

We included randomized, controlled trials (RCTs); nonrandomized, controlled trials; and controlled cohort studies reporting on the benefit and harms of screening compared with no screening (or usual care) (KQs 1 and 3), or harms of interventions for children with a speech or language delay or disorder compared with an inactive control group (KQ 6). For studies reporting on the benefit of interventions to improve speech and language outcomes (KQ 4) or academic skills, behavior, function, or quality of life (KQ 5), we limited to RCTs comparing an intervention to an inactive control group. For studies assessing the accuracy of screening tools (KQ 2), we included cross-sectional or cohort studies comparing screening tools with a reference standard (diagnostic evaluation by a qualified clinical professional) reporting on measures of test accuracy (e.g., sensitivity and specificity).

Titles and abstracts were independently reviewed by two investigators. Those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. The full texts were then independently reviewed by two investigators to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

For newly identified studies, two experienced reviewers independently assessed each study’s methodological quality using predefined criteria developed by the USPSTF (Appendix B) and informed by tools designed for various study designs (Cochrane Risk of Bias 2.0 tool for RCTs;^31^ Quality Assessment of Diagnostic Accuracy Studies-2 for screening test accuracy).^32^ We spot-checked and carried forward quality ratings of eligible studies included in the previous update for this topic. Disagreements were resolved by discussion. Only studies rated as having good or fair quality were included in the synthesis.

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. All data extractions were checked by a second investigator for completeness and accuracy.

## Data Synthesis and Analysis

Findings for each KQ were summarized in tabular and narrative format. The overall strength of the evidence for each KQ was assessed as high, moderate, low, or insufficient based on the overall quality of the studies, consistency of results between studies, precision of findings, risk of reporting bias, and limitations of the body of evidence using methods developed for the USPSTF (and the EPC program).^33, 34^ Additionally, the applicability of the findings to U.S. primary care populations and settings was assessed. Discrepancies were resolved through consensus discussion.

For studies included for KQ 2 (accuracy of screening tools) we calculated sensitivity, specificity, likelihood ratios, and predictive values based on data reported by articles, when sufficient, in order to compare consistency across similar measures. When qualitatively evaluating likelihood ratios, we considered positive likelihood ratios (PLRs) to indicate a minimal (1–2), small (2–5), moderate (5–10), or large (>10) increase in the risk of a language delay or disorder. We considered negative likelihood ratios (NLRs) to indicate a minimal (0.5–1), small (0.2–0.5), moderate (0.1–0.2), or large (<0.1) decrease in the risk of a language delay or disorder. Likelihood ratios below 0.1 or above 10 are typically thought to provide strong evidence for ruling out (NLR<0.1) or ruling in (PLR>10) a diagnosis.^35^

To determine whether meta-analyses were appropriate, the clinical heterogeneity and methodological heterogeneity of the studies were assessed following established guidance.^36^ The populations, tests, treatments, comparators, outcomes, and study designs were assessed qualitatively, looking for similarities and differences. Due to heterogeneity and few studies assessing the same screening tool or interventions, meta-analysis was not appropriate.

## Expert Review and Public Comment

The draft research plan for this topic was posted on the USPSTF website for public comment from January 20, 2022, to February 16, 2022. In response to public comments, the USPSTF clarified that children who communicate using any language at home are eligible, not just spoken language, and that studies enrolling unselected as well as asymptomatic populations are eligible. Studies enrolling an unselected population may include children with conditions listed as excluded who have not yet been diagnosed. Finally, the USPSTF added minor edits to clarify that screening and treatment for speech disorders, language disorders, or both are included. The final version of the research plan was posted on the USPSTF website on June 9, 2022. The draft evidence review was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and minor revisions were made based on comments received, mostly related to clarifying information summarized in the Introduction. The draft evidence review was posted for public comment from July 25, 2023, through August 21, 2023. Most comments related to contextual issues specific to current clinical practice and future research needs. In response to comments, a minor revision was made to the Discussion to note that future research on this topic should aim to enroll a population representative of families living in the United States, including those who speak languages other than English at home..

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions, as well as to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided project oversight, conducted reviews of the draft report, and helped facilitate an external review of the evidence synthesis. Although AHRQ staff and members of the USPSTF participated in developing the scope of work and reviewed draft reports, the authors are solely responsible for the report’s content.