# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this review to update its recommendation on screening for speech and language delay and disorders in children. In 2015, the USPSTF concluded that the evidence was insufficient to assess the balance of benefits and harms of screening for speech and language delay and disorders in children age 5 years or younger (I statement).^1^

## Condition Definition

Speech or language delay refers to children who are developing speech and language in the correct sequence but at a slower rate than expected, whereas speech or language disorders refer to children with speech or language ability that is qualitatively different from typical development. There is no universally accepted threshold for “delay” in speech or language development. For research purposes, performance on a standardized assessment of language that falls at least one standard deviation below the mean for their age is often considered a delay.^2^ Speech disorders are defined by difficulty with forming specific sounds or words correctly (articulation or phonological disorders) or making words or sentences flow smoothly (fluency disorders like stuttering).^3^ Language disorders are characterized by difficulty understanding (receptive language) or speaking (expressive language) relative to their peers.^3^ Speech and language disorders can exist alone or together.

The focus of this review is routine screening for developmental (or “primary”) speech or language delay and disorders that are not caused by another condition known to affect speech or language development. Acquired or “secondary” causes of speech and language delay or disorders result from an injury or condition known to cause speech or language problems (e.g., acquired aphasia secondary to a seizure disorder; neurologic impairment secondary to tumors, infections, or radiation; autism). Routine screening in primary care settings would not be appropriate for children who have a suspected or known acquired cause of speech and language delay. Evaluation and treatment of communication difficulties in children with secondary speech or language disorders would be part of disease management. However, in the context of routine screening, some children identified with a speech or language delay or disorder may go on to receive a primary diagnosis for a disorder such as hearing loss subsequent to the screening and diagnostic evaluation. This may be considered an additional outcome of screening.

## Etiology and Natural History

Heterogeneous terminology has been used to categorize speech and language disorders based on etiology, in addition to other factors. As outlined above, disorders may be developmental (primary) or acquired (secondary). The focus of this review is on speech and language delay and disorders that become apparent as development unfolds but which are thought to be present at birth with unknown etiology. Some risk factors, such as adverse social conditions (as outlined below), are thought to increase the risk of speech and language delay. In terms of natural history, many children identified with speech or language delay go on to recover without an intervention. One systematic review (18 cohort studies) that included studies published through 1997 estimated that approximately 60 percent of children identified with an early expressive language delay and 25 percent with a receptive and expressive language delay will recover without intervention.^2^ However, evidence suggests that school-age children with speech or language delay may be at increased risk of learning and literacy disabilities, including difficulties with reading and writing.^4–6^ Observational cohort studies suggest that children with these conditions may also be at higher risk for social and behavioral problems in addition to learning problems,^7^ some of which may persist through adulthood.^8, 9^ The extent to which these studies accounted for treatment history and confounding factors is limited.

## Risk Factors

Risk factors for developmental speech and language delay and disorders are not well understood. Observational evidence has shown an association with multiple factors, including male sex, family history, and various adverse social conditions and higher rates of various speech and language problems. Despite popular myth, children raised in bilingual or multilingual households are not at increased risk for speech and language disorders.^10^ In fact, some studies have found cognitive^11, 12^ advantages to bilingualism over monolingualism in children with and without developmental disorders. The previous USPSTF evidence review for this topic included a key question (KQ) about risk factors for speech and language delay and disorders.^13^ Based on evidence from observational studies, the following were identified as possible risk factors: male sex, family history of speech or language impairment, lower levels of parental education, and various perinatal risk factors (e.g., low birth weight).^13^

More recent studies have evaluated risks associated with various adverse social conditions. For example, one population-based cohort study from the United Kingdom (28,634 children born between January 2011 and December 2014) found that speech, language, and communication concerns at ages 27 to 30 months are common (with a prevalence of 13%) and are significantly associated with increasing levels of neighborhood deprivation, categorized using the Scottish Index of Multiple Deprivation 2016 quintiles (taking into consideration level of income, employment, health status, education, geographic access to services, crime, and housing).^14^ Other studies have shown an association between speech and language diagnoses and poverty, poor parental mental health, and lack of medical home or reliable access to medical services.^15^ Finally, emerging evidence suggests that environmental changes associated with the COVID-19 pandemic (e.g., stay-at-home orders, mask mandates, social distancing requirements) may increase the risk of language delay. Preliminary results (preprint publication) from a longitudinal cohort study enrolling healthy, neurotypically developing children from Rhode Island (n=700) found statistically significantly reduced verbal, motor, and overall cognitive performance (by approximately 2 standard deviations) among children age 1 year or younger born during the pandemic (2020 and 2021) compared with children born between 2011 and 2019, controlling for multiple confounding factors. Similar findings were seen among all children younger than age 3 years who were assessed in 2021 compared with historical controls.^16^ These results suggest that males have been most affected and that higher levels of maternal education was a protective factor.

## Prevalence and Burden

Nationally representative estimates of the prevalence of speech and language delay and disorders in children are limited. Published estimates vary in terms of population age, measurement or definition of delay and disorder, and other factors. In terms of speech and language delay, a 2003 U.S. cohort study enrolling a random sample of children ages 12 to 39 months (n=1,189) born at Yale New Haven Hospital estimated a 13.5 percent prevalence (among those ages 18 to 23 months) to 17.5 percent prevalence (among those ages 30 to 36 months) for expressive language delay measured by the MacArthur Communicative Development Inventories (CDIs), short-form versions.^17^ This prevalence is similar to more recent estimates from a cohort study in Canada, which found a 12.6 percent prevalence among those ages 24 to 30 months using the same measure.^18^ In terms of speech and language disorders, using data from both peer-reviewed studies and national surveys, the National Academy of Sciences estimated that the prevalence of speech and language disorders ranges between 3 and 16 percent of U.S. children ages 3 to 18 years.^19^ Multiple studies have demonstrated a higher prevalence among boys than girls and among certain groups defined by race/ethnicity.^19, 20^ For example, based on data from the 2012 National Health Interview Survey, nearly 8 percent of children ages 3 to 17 years had a communication disorder (any speech or language disorder), with boys almost twice as likely to be affected than girls (9.6% vs. 5.7%, respectively).^20^ In the same study, approximately 10 percent of non-Hispanic Black children were affected compared with 7.8 percent and 6.9 percent of children identified as White or Hispanic, respectively.^20^ Disparities in the prevalence of speech and/or language delay has also been observed based on various measures of socioeconomic status, including type of insurance. For example, a nationally representative U.S. cohort study found that by age 8 years, the prevalence of speech or language disorders was significantly higher among publicly insured children than privately insured children (8.4% vs. 4.5%, respectively).^21^

Children with speech and language difficulties are at risk for both learning and behavioral problems, some of which may persist through adulthood.^8, 9^ The burden associated with untreated speech delay and disorders is addressed under the Etiology and Natural History section.

## Rationale for Screening and Screening Strategies

The rationale for screening for speech and language delay or disorders among children without a known condition that affects speech and language development is to identify these conditions early and provide effective interventions before the condition interferes with school learning or psychosocial adjustment. A variety of screening tools exist that could be used in primary care settings to detect speech and language problems. Some tools, such as the Ages and Stages Questionnaires (ASQ-3), are part of a larger instrument designed to assess general development and includes multiple questions specific to speech and language. Other tools are designed to assess only speech and language development. Screening instruments may be broadly characterized as those that are designed to be administered to the child and those that are completed by a knowledgeable informant such as a parent, caregiver, or teacher. In a few cases, both procedures are used. Most screening instruments are unable to discern the difference between a child who has a delay (i.e., a child with late-emerging language during the first 2 years of life) that will subsequently resolve without treatment, and one who will go on to display a speech and language disorder (i.e., a child who will later receive a formal diagnosis of specific language impairment). Children who screen positive for speech and language difficulties require referral for a diagnostic evaluation to confirm the suspected delay or disorder.

## Treatment Approaches

Once a formal speech or language disorder is diagnosed, treatment is variable and individualized to the needs of the child, their family, and their school team based on how the child’s disorder impairs their function in different settings. For example, when treating a child with an articulation disorder, the speech-language pathologist (SLP) may model the production of problematic sounds, have the child listen to and discriminate between sounds, cue the child on placement of the articulators, and provide multiple opportunities for the child to practice. Similarly, for children with language disorders, therapy will be designed to address the child’s specific weaknesses in expressive or receptive language related to vocabulary, syntax, semantics, pragmatics, or some combination of these. Strategies may include providing the child with a rich exposure to vocabulary and language structures through responsive interactions with caregivers and peers. These naturalistic strategies, often delivered by a caregiver who is coached by an SLP, include expanding the child’s utterances, recasting what the child has just said with correct grammar, describing the child’s actions as they play, providing visual supports for communication, and using child-directed speech.^22^ Interventions targeting stuttering in young children may involve similar naturalistic strategies to manage and reduce stuttering, such as training parents to provide verbal contingencies for periods of stutter-free speech in the form of acknowledgment (“That was smooth”) or praise, and contingencies for moments of stuttering (“That was a bit bumpy”) and requests for self-correction. For children who have limited or no ability to speak intelligibly, an augmentative and alternative communication system, such as a speech-generating device or a visual representation of a word on a button or board, may be used. Many assistive technology options are now available to support individuals with speech and language disorders in their daily functioning.^23, 24^

Speech-language therapy sessions may take place in natural or more structured clinical environments. Children younger than age 3 years will typically receive state-supported infant and toddler early intervention services either in a day-care setting or in their home with a caregiver. School services provided to children older than age 3 years are generally offered in a preschool classroom, either embedded in classroom routines or in a separate treatment room. Private speech-language therapy, which may occur in addition to early intervention or school services, usually takes place in a clinic, though some therapists visit family homes or provide telehealth appointments. Children may be seen individually or in a small group for treatment depending on their therapy goals. Telehealth delivery of speech-language services has become more common, and evidence suggests that treatment outcomes have been equivalent or better than traditional in-person therapy.^25^

Speech-language treatment may be delivered by a licensed SLP or a speech-language pathology assistant supervised by an SLP. In early intervention for toddlers, it is now common for caregivers to be the primary implementers of speech-language interventions with the therapist coaching them. Teachers, paraprofessionals, and even peers may also collaborate with school SLPs to support a child’s communication goals at school. The duration of treatment for speech-language disorders varies by the child’s needs and the child’s rate of progress in meeting therapy goals.

## Current Clinical Practice

The American Academy of Pediatrics recommends that children without identified risks or developmental problems receive periodic general developmental screening using a standardized tool at 9-, 18-, and 30-month well-child visits.^26^ These guidelines do not recommend screening separately for speech and language concerns or recommend a specific general developmental screening tool that is designed to provide a separate score for speech and language problems. Despite existing guidelines, routine developmental screening in clinical practice varies by practice settings and states. Based on data from the 2015 National Survey of Children’s Health, an estimated 30 percent of U.S. children ages 9 to 35 months received a parent-completed developmental screening in the past year, with variation across states (ranging from 17% in Mississippi to 59% in Oregon).^27^ Commonly used tools in practice that contain questions about global development, including the Parents’ Evaluation of Developmental Status questionnaire, ASQ-3, and the Survey of Well-being of Young Children, include items specific to speech delay but generally have low sensitivity for detecting speech delay.^28^ It is not clear what proportion of providers use general developmental screening tools in current practice that have adequate sensitivity for detecting speech and language delay or disorders.

Although screening for general developmental delay is common in practice, challenges may arise in implementing screening, particularly because of concerns about clinic flow in busy settings.^29^ Some children who screen positive may not be referred for treatment, or families may not follow through with recommended referrals.^29^ Some evidence suggests disparities in rates of referral or services by race/ethnicity for children who are identified in primary care settings as having a potential speech or language problem. For example, based on data from the 2012 National Health Interview Survey, approximately half of all children ages 3 to 17 years with a communication disorder received an intervention service in the past 12 months; however, children identified as Hispanic/Latinx and Black are less likely to receive services compared with children identified as White (47.3%, 45.8%, and 60.1%, respectively).^20^ Appendix A provides detailed information regarding disparities in rates of detection, age at diagnosis and receipt of treatment by age, race/ethnicity, and various measures of socioeconomic factors.^20^