# Appendix E Additional Tables

Appendix E Table 1 Characteristics of Included Treatment Randomized, Controlled Trials (KQs 4 and 5)

First Author, Year Study Design Quality | N | Mean Age (Months) | % F % Race/Ethnicity | Intervention Type | Recruitment Setting Country | Delivery Personnel | Duration/Frequency of Intervention | Description of Intervention Content | Control Group
Acosta-Rodríguez, 2022^67^; RCT; Fair | 50 | 67.8 | 42; NR | School-based curriculum intervention | Children identified by school staff as showing signs of developmental language delay; Spain (Canary Islands) | Teachers and speech and language therapists | 20 hours of teacher training; 95 (60-minute) sessions delivered by teachers and therapists; weekly visits from research team for support | Curriculum aimed at improving oral language comprehension skills by retelling and story generation, embedded in normal preschool curriculum, delivered jointly by teachers and therapists. Content included a wide range of language skills and activities (e.g., review of low-frequency vocabulary, summary of story highlighting main concepts). Students also completed a series of activities supported by visual material, graphic resources, and multiple-choice questions. | No treatment
Almost, 1998^70^; RCT; Fair | 26 | 42.0 | 19; NR | Speech sound disorders | Referrals to speech-language pathology clinic; Canada | SLPs | Individual biweekly 30-minute sessions over 4 months | Individual treatment for children with phonological disorders (but normal receptive language function); focused on remediation (e.g., remediation of inclusion of final consonants). Each session focused on a specific phonological process. | No treatment
Gibbard, 1994^60^; RCT; Fair | 36 | 29.5 | 31; NR | Language delay | Referrals to a speech-language therapy clinic; United; Kingdom | Parents | 11 (60- to 75-minute) parent training sessions every 2 weeks over 6 months | Parental group training at a community health center to improve child linguistic complexity. Content of sessions included setting objectives and methods and games to achieve objectives. Emphasis was placed on transferring linguistic skills during games to daily life situations. | No treatment
Girolametto, 1996; Girolametto, 1997^61, 71^; RCT; Fair | 25 | 28.6 | 12; NR | Language delay | Waiting lists for 2 self-referred, parent-focused language programs (parents responding to advertisements); Canada | Parents with coaching and feedback from SLPs | 8 (2.5-hour) parent training sessions over 11 weeks and 3 home visits from an SLP to provide support | An adapted version of the Hanen Program for Parents, administered by 2 SLPs and a parent associate. Sessions taught strategies via lectures, role-plays, and discussions. Adaptations included providing parents with target words to incorporate into daily routines, training parents to select additional lexical targets once target words were mastered, training parents to introduce new target words, and training parents to model 2-word combinations. SLPs provided 3 home visits for coaching and feedback. | Delayed treatment
Glogowska, 2000^72^; RCT; Good | 159 | 34.0 | 25; NR | Community-based speech-language disorders | Referrals to speech-language clinics from primary care; United Kingdom | Speech and language therapists | No set duration or frequency; mean hours of therapy received was 6.2 total | Individual speech and language therapy tailored to child’s needs provided by therapists at 16 NHS community clinics for children with difficulties in 1 of 3 domains (general language, expressive language, and phonology). Study aimed to evaluate the benefit of routine therapy received by referred children rather than a prescribed regimen. | Watchful waiting
Jones, 2005^73^; RCT; Fair | 54 | 54.4 | 22; NR | Fluency disorders | Preschool children presenting to speech clinics for treatment; New Zealand | Parents and speech pathologists | Parent training, daily home practice sessions; and weekly clinic visits until fluency improved, followed by less frequent visits | Lidcombe Program of Early Stuttering Intervention delivered according to the program manual. Parents were trained to provide verbal contingencies related to stuttering via acknowledgments (“That was smooth”), praise (“That was good talking”), and request for self-evaluation (“Were there any bumpy words then?”) daily, with children initially meeting with a therapist weekly. When stuttering frequency was less than 1.0% of syllables stuttered over 3 consecutive weeks, treatment decreased in frequency. | Wait-list
Lewis, 2008^74^; RCT; Fair | 22 | 52.4 | 36; NR | Fluency disorders | Parent recruited via press advertisements for a study on treatment for stuttering; Australia | Parent and SLP via telehealth (telephone, videos, email, mail, audio recordings) | Parent training, daily practice; and weekly telephone visits with SLP until fluency improved, followed by less frequent contacts | Lidcombe Program of Early Stuttering Intervention implemented as similar as possible to the program manual but delivered via telehealth. Parents were trained to provide verbal contingencies related to stuttering in the form of acknowledgments (“That was smooth”), praise (“That was good talking”), and request for self-evaluation (“Were there any bumpy words then?”) daily, supported by weekly calls with a therapist. When stuttering frequency was less than 1.0% of syllables stuttered over 3 consecutive weeks, frequency of treatment decreased. SLP observation and evaluation occurred via audio-recorded samples mailed to the therapist. Parent training was conducted using videos. | Regular telephone contacts every 8 weeks, “as a matter of courtesy, to maintain contact, and to facilitate compliance“ per authors
McLeod, 2017^64^; Cluster RCT; Fair | 123 | 56.1^*^ | 36^*^; NR | Speech sound disorders | Children recruited via screening of parents and educators for concerns about how children “talked and made speech sounds”; Australia | Preset computer-based program facilitated by untrained teachers | Individual 1-hour sessions 4 times per week over 9 weeks (18 hours total) facilitated by teachers^†^ | Software-based intervention, Phoneme Factory Sound Sorte (PFSS), consisting of 7 interactive games customized based on child’s needs. Children listened and responded to auditory and visual stimuli that target phoneme segmentation and identification, blending, minimal pair discrimination, and rhyme detection, based on preset modes (“teacher settings”) targeting common phonological error patterns. Teachers participated using headphones, assisting when necessary (e.g., when children were not proficient at using the computer mouse to respond to prompts, teachers moved it to the location on the screen where children pointed). | Standard care (typical classroom practices)
McLeod, 2020^63^; RCT; Fair | 101 | 53.10 | 43^*^; Aboriginal or Torres Strait Islander: 15;; Other groups NR | Community-based speech-language intervention | Referrals to 2 community health centers for speech and/or language problems; Australia | SLPs | 12 weekly 45-minute individual sessions delivered in 2 6-week blocks separated by a 2-week break | Individual therapy reflecting usual practice offered immediately (vs. being wait-listed). A session plan template was used to structure the content of each session. During the initial session, 3 main goals were identified in collaboration with caregivers based on the initial assessment. Common goals included phonological processes, vocabulary, and grammar (e.g., pronouns and verb tenses). Additional goals were targeted if the initial intervention goals were achieved. Home practice activities were provided at each session targeting participants’ speech, language, and/or early literacy goals. | Advice Control—brief visit with SLP to review results and resources^ǂ^; Device Control—URL for family-friendly, evidence-based website^§^ aimed at stimulating speech and language skills
Namasivayam, 2021^68^; RCT; Fair | 45 | 48.4 | 39; NR | Speech sound disorders (children with speech motor delay) | Children presenting to 3 community-based centers for treatment of speech sound disorders; Canada | SLP | 45-minute individual sessions delivered twice weekly for 10 weeks | Intervention for children with speech motor delay, PROMPT, focused on improving the accuracy and stability of speech production. Individual goals were chosen to reflect the complex interrelationships among physical-sensory, cognitive-linguistic, and social-emotional domains based on the 7 hierarchal and interactive developmental stages in speech motor control.^‖^ Techniques used to stimulate sensory input (i.e., tactile, kinesthetic, proprioceptive, auditory, and visual) to facilitate the formation of sensory and motor pathways required for the acquisition and accurate production of speech movement patterns. | Standard care provided to those on a wait-list, including a 4-page handout detailing speech, language, and literacy strategies to be carried out at home
Peredo, 2022^66^; RCT; Good | 21 | 33.1 | 43; Latino: 100 | Language delay | Participants recruited via agencies and community services working with Spanish-speaking families via advertisements and referrals; United States | Caregiver taught by trained coaches during individual home-based sessions | Caregiver training delivered over 24 sessions, twice weekly for 3 months | Intervention teaching Spanish caregivers a culturally and linguistically adapted version of EMT strategies during individual home interactions with their children. Strategies included following child’s interests, contingent responding to child’s communicative intent, matching linguistic input to the child’s zone of proximal development, and prompting language in highly motivating contexts. Contexts for intervention were play, book sharing, and naturally occurring home routines. | Wait-list
Robertson, 1997^75^; RCT; Fair | 20 | 49.7 | 35; NR | Language delay | Children identified with SLI enrolled in a language-based early childhood classroom; United States | Researchers and peers | 4 (15-minute) play sessions with peer models over 3 weeks in an environment designed for the study | Verbal scripts for playing house elicited from participating children during 4 sessions with 1–3 classmates (15–20 minutes each) before randomization; researchers told children they were trying to teach younger children how to play house and encouraged children to tell what they knew using prompts (e.g., “What do you do when you play house?”). After randomization, children in the intervention group were assigned to play with peers who had normal language abilities in a room with play prompts designed to support the verbal scripts for playing house. | No interaction with peer models^¶^
Robertson, 1999^76^; RCT; Fair | 21 | 25.12 | 43; White: 100 | Language delay | Families of children that responded to various advertisements^#^; United States | SLPs | 75-minute individual therapy sessions delivered twice weekly over 12 weeks | Interactive, individualized child-centered intervention that emphasized vocabulary development via individual therapy sessions. The intervention incorporated a “script” in conjunction with themes designed to help children organize information by providing a unifying concept to which all newly presented vocabulary could be linked. | Wait-list
Thordardottir, 2015^65^; RCT; Fair | 29 | 59.6 | 10; NR | Language delay | Recruitment of children identified with a language impairment by an SLP at various clinical treatment centers and public school settings; Canada | SLP (monolingual intervention) or SLP with active parental participation using home language (bilingual intervention) | 16 (50-minute) weekly individual sessions | Both treatments: Individual treatment plans were formulated based on needs and targets designed by SLPs; treatment goals included a vocabulary target and a syntactic target. Vocabulary training included 4 verbs and 6 nouns per session, including 5 words the child understood but did not produce and 5 that the child neither understood nor produced. A story retell probe using a wordless picture book was used to assess progress in subject-object-verb sentence formation.; Monolingual treatment—delivered by SLPs in French only. Parents were present during sessions but were asked not to participate.; Bilingual treatment—delivered by SLPs in collaboration with home language-speaking parents. Parents provided models of therapy targets in their respective languages and engaged in play responding to their child’s home language utterances. | Wait-list (no treatment)
Wake, 2011^62^; Cluster RCT; Good | 301 | 18.1 | 49; NR | Language delay | Recruitment via parent survey at participating health centers^**^; Australia | Parents completing training sessions led by interventionists (1 with speech pathology background and 2 with a psychology background) | Six weekly 2-hour group sessions at a local community center with childcare available | Parent-toddler community-based language promotion program designed for toddlers identified as “slow to talk” via routine screening. Adapted version of a manual-based program (“You Make the Difference”). The goal included promotion of child-centered interactions and language modeling responsive interaction strategies. Group sessions covered various content related to interacting with children to increase language skills and included parent-child practice during the end of the session that was videotaped. Subsequent sessions showed short video clips of positive parent-child interactions to reinforce specific strategies. | Usual care (followup for routine child health visits)
Wake, 2013^77^; RCT; Fair | 200 | 49.5 | 34; NR | Language delay | Participants recruited from 2 previous population-based early childhood trials that promoted literacy and language development; Australia | Trained language assistants (psychology and sociology university graduates) supervised by an SLP | 18 (1-hour) home-based therapy sessions delivered in 3 blocks of 6 weekly sessions every 3 months | Intervention designed to promote narrative skills, vocabulary and grammar, and phonological awareness and preliteracy skills for children identified with language delay. The language assistant conducted a language screen on the initial session to identify areas that needed to be targeted during that block. Sessions covered phonological awareness/letter knowledge, specific language target activity, and shared book reading. Each session involved a brief review with parents, activities directed at the child, and activities for home practice. | No treatment; parents were informed about local speech pathology services (if desired) by mail
Wilcox, 2020^69^; RCT; Fair | 289 | 53.1 | 30; White: 54; Black: 2; Hispanic: 26; Multi-racial: 12; American Indian: 2; Asian: 3 | School-based curriculum intervention | Children from participating preschool programs^††^ identified with developmental speech and/or language impairment; United States | Preschool classroom teachers | 34 weeks of instruction during 1 school year covering 14 thematic units that are each 2 weeks in duration with review weeks every 5th week | Whole-class curriculum that embeds incidental and explicit oral language and early literacy teaching practices within planned learning opportunities. Instruction is mapped to early learning standards, materials (pictures, books, and songs), and developmentally appropriate lesson plans that create language and early literacy learning opportunities. Learning opportunities are embedded within typical preschool activities (e.g., book reading, free play) and implemented with evidence-based teaching practices.^ǂǂ^ | Usual preschool curriculum

* Values were calculated based on information provided by the study authors.

† Participating schools were offered financial reimbursement to partially compensate for the time spent by the educators on the intervention and to maintain appropriate student–teacher ratios.

ǂ Caregivers received a 45-minute session with an SLP to review assessment results, goal setting, and resources. The authors report that this was a revised model of usual practice of wait-lists between diagnosis and beginning therapy, which were informed by literature on book sharing, language stimulation, and speech stimulability training.

§ Website titled “Waiting for Speech Pathology” that included 48 downloadable handouts covering speech, language, and early literacy, general information on speech-language pathology, and links to other websites, was provided to caregivers. The URL was sent via email during the intervention phase, with two reminder emails sent two and four months after the initial email.

‖ Seven hierarchal and interactive developmental stages in speech motor control include the following: stage I: tone, stage II: phonatory control, stage III: mandibular control, stage IV: labial–facial control, stage V: lingual control, stage VI: sequenced movements, and stage VII: prosody. These hierarchical speech motor goals are embedded into the cognitive-linguistic and social-emotional needs of the child.

¶ Children in the control group had access to a play area in their normal classroom with similar play prompts.

# This included agencies associated with families of young children (e.g., preschools, pediatricians, day-care providers, and Head Start centers), local newspapers, and advertising via local radio and public TV stations.

** Consenting parents were mailed screening expressive vocabulary checklists to determine eligibility.

†† Programs covered by the Individuals with Disabilities Education Act.

ǂǂ Teachers received ongoing professional development, including group training sessions and individualized, in-class coaching on a weekly basis in the fall and biweekly in the spring.

Abbreviations: EMT=Enhanced Milieu Teaching; F=female; N=number of participants; NHS=National Health Service; NR=not reported; PROMPT=Prompts for Restructuring Oral Muscular Phonetic Targets; RCT=randomized, controlled trial; SLI=specific language impairment; SLP=speech-language pathologist.

Appendix E Table 2 Results of Included Treatment Randomized, Controlled Trials of Language Delay Interventions (KQ 4)

First Author, Year | N | Mean Age, Months | Intervention(s) | Control | Analysis; Timing of Outcome Assessment | Expressive Language Outcomes | Receptive Language Outcomes
Gibbard, 1994^60^ | 36 | 29.5 | Parental group training to improve child linguistic complexity; 11 bimonthly 60- to 75-minute training sessions over 6 months | No treatment | Difference in post-intervention means, adjusted for baseline scores; 26 weeks | Mean (SD), intervention vs. control^*^; Mean length of utterances:^†^; 2.3 (0.7) vs. 1.4 (0.4); Cohen’s d=1.65 (p<0.001); RDLS, Expressive score:; 38.7 (8.6) vs. 20.8 (6.2); Cohen’s d=2.69 (p<0.001); DLS, Picture Test; 17.7 (2.4) vs. 7.8 (6.5); Cohen’s d=1.95 (p<0.001); DLS, Total Score:; 92.3 (70.2) vs.11.3 (11.8); Cohen's d=1.88 (p<0.001) | Mean (SD), intervention vs. control; RDLS, Comprehension score:; 40.5 (9.4) vs. 29.3 (5.6); Cohen’s d=1.95 (p<0.001); Renfrew Action Picture Test:; Grammatical ability:; 5.2 (4.6) vs. 0.3 (1.0); Cohen’s d=1.50 (p<0.001); Information content:; 15.7 (8.3) vs. 3.2 (4.9); Cohen's d=1.89 (p<0.001)
Peredo, 2022^66^ | 21 | 33.1 | Culturally and linguistically adapted version of EMT strategies for Spanish-speaking caregivers delivered during home-based twice weekly sessions (24 total) over 3 months | Wait-list | Difference in post-intervention means, adjusted for baseline age, PLS-5 total language score, baseline value;15 weeks (~2 weeks post-intervention) and 26 weeks (~12 weeks post-intervention) | Mean scores, intervention vs. control^*^; Expressive Vocabulary, EOWPVT-SBE scores: 15 weeks: 5.55 vs. 2.35, Cohen’s d=0.50; p=0.181; 26 weeks: 4.77 vs. 3.86, Cohen’s d=0.17; p=0.721; Analysis of child-caregiver interactions:^ǂ^; Unprompted no. of different words used:; 15 weeks: 12.27 vs. 11.59, Cohen’s d=0.06; p=0.836; 26 weeks:18.03 vs. 15.21, Cohen’s d=0.21; p=0.667; Unprompted total no. of words used:; 15 weeks: 33.71 vs. 24.64, Cohen’s d =0.23; p=0.427; 26 weeks: 53.88 vs. 28.39, Cohen’s d =0.77; p=0.147 | Mean scores, intervention vs. control; Receptive Language, ROWPVT-SBE scores:; 15 weeks: 12.23 vs. 7.61, Cohen’s d=0.54; p=0.318; 26 weeks: 11.29 vs. 6.53, Cohen’s d=0.60, p=0.050
Robertson, 1999^76^ | 21 | 25.1 | Individual sessions delivered by an SLP over twice weekly 76-minute sessions for 12 weeks, designed to be interactive and emphasizing vocabulary development | Wait-list | Difference between groups in post-treatment scores, adjusted for baseline scores;12 weeks | Mean (SD), intervention vs. control^*^; Outcomes based on language samples:^§^; Mean length of utterances; 1.32 (0.32) vs. 1.09 (0.11); Cohen’s d=1.40 (p=0.003); Total no. of words:; 33.3 (16.6) vs. 16.6 (12.5); Cohen’s d=2.99 (p<0.001); No. of different words:; 15.1 (5.2) vs. 8.5 (5.3); Cohen’s d=2.80 (p<0.001); No. of different words, controlling for number of words:; Mean NR: Cohen’s d=2.14 (p<0.001); % of intelligible utterances:; 88.1 (7.5) vs.71.5 (11.9); Cohen’s d=2.16 (p<0.001); Vocabulary size (CDI Words and Sentences scores):; 76.2 (37.5) vs. 51.4 (40.8); Cohen’s d=2.99 (p<0.001) | NR
Thordardottir, 2015^65^ | 29 | 59.6 | Individual treatment based on targets set by SLPs delivered over 16 weekly 50-minute sessions; 2 treatment arms: 1 monolingual: delivered by French SLPs with no parental participation; 2 bilingual: SLP collaboration with home-speaking parents to provide models of targets in their respective languages | Wait-list | Difference between groups in change from baseline scores; 16 weeks | Expressive Vocabulary (EOWPVT score):; Monolingual: 5.0; Bilingual: 3.4; No treatment: 0.9; No significant differences per the authors; Improvement on intervention-specific expressive vocabulary probes:^‖^; Pre-post change in the monolingual and bilingual treatment groups was significantly larger compared with the control group (p=0.000 and p=0.001, respectively) | Receptive Language (EVIP score):; Monolingual: 6.2; Bilingual: 4.1; No treatment: 6.0; Receptive Language (RDLS score):; Monolingual: 16.3; Bilingual: 13.5; No treatment: 8.6; No significant differences per the authors^¶^; Improvement on intervention-specific receptive vocabulary probes:^‖^; Pre-post change in the monolingual and bilingual treatment groups was significantly larger compared with the control group (p=0.000 and p=0.003, respectively)
Wake, 2011^62^ | 301 | 18.1 | Parent-toddler community-based language promotion program designed for toddlers identified as “slow to talk” via routine screening; 6 weekly 2-hour group sessions | Usual care (followup for routine child health visits) | Difference between groups at outcome assessment, adjusted for clustering, potential confounders (sex, exact age at outcome assessment, local government area, 3 indicators of SES, and baseline values | Difference in mean scores (95% CI); MCDI vocabulary raw score:; 2 year: 2.1 (−3.0 to 7.2); p=0.42; 3 year: 4.1 (−2.3 to 10.6); p=0.21; PLS expressive communication standard score:; 2 year: 1.2 (−1.6 to 4.0); p=0.41; EVT expressive vocabulary standard score:; 3 year: −0.5 (−4.4 to 3.4); p=0.80 | Difference in mean scores (95% CI); PLS Auditory Comprehension standard score:; 2 year: 1.4 (−2.2 to 5.0); p=0.44; 3 year: −0.3 (−4.2 to 3.7); p=0.90
Wake, 2013^77^ | 200 | 49.5 | Individual home-based therapy delivered by trained assistants to promote narrative skills, vocabulary, grammar, phonological awareness, and preliteracy skills; 18 (1-hour) sessions delivered in 3 blocks of 6 weekly sessions | No treatment | Difference in mean scores between groups at followup, adjusted for child’s gender, mother’s education level, recruitment setting, and baseline scores; 52 weeks | Expressive Language, CELF-P2 score:; 2.0 (−0.5 to 4.4); p=0.12 | CELF-P2, Receptive Language score:; 0.6 (−2.5 to 3.8); p=0.69; Phonological Awareness, CTOPP score:; 5.0 (2.2 to 7.8); p<0.001; Pragmatic language skills, CCC-2 total score:; -1.0 (−3.7 to 1.6); p=0.4
Girolametto, 1996; Girolametto, 1997^61, 71^ | 25 | 28.6 | An adapted version of the Hanen Program for Parents; parents attended 8 (2.5-hour) sessions over 11 weeks and received 3 home visits from an SLP | Delayed treatment | Difference in post-intervention means adjusted for baseline values;14 weeks | CDI, completed by parent:; Expressive vocabulary size (No. of words):^*^; 187.7 (181) vs. 65.4 (66); Cohen’s d=0.88 (p<0.01); Structural complexity:; 16.7 (13) vs. 5.2 (10); Cohen’s d=0.68 (p<0.04); Videotapes of the parent-child play sessions:; No. of different words used:; 64.5 (46) vs. 25.2 (22); Cohen’s d=1.13 (p<0.02); No. of different learned (target) words:; 3.0 (2.1) vs. 1.0 (1.2); Cohen’s d=1.67 (p<0.01); Talkativeness (no. of utterances or words/minute):; Mean NR; Cohen’s d=0.62 (p<0.06) | NR
Robertson, 1997^75^ | 20 | 49.7 | 4 (15-minute) play sessions with peer models who had normal language development over 3 weeks in an environment designed for the study, using play scripts created by researchers and participating children | No interaction with peer models | Difference from baseline to followup, adjusted for baseline values; 3 weeks | Based on transcripts from play script reports (response to prompts): (1); No. of words used: F=70.72 (p<0.0001); No. of different words used: F=73.79 (p<0.0001); No. of linguistic markers (terms used that indicated temporal sequence): F=73.51 (p<0.01)^*^ | NR

* Cohen’s d calculated by the authors of the previous evidence review on this topic.

† Number of words or utterances from recorded language samples.

ǂ Outcomes measured via videotapes of caregiver-child interactions; transcribed interactions were analyzed via the Systematic Analysis of Language Transcripts software.

§ Audiotaped transcripts of 15-minute spontaneous language samples gathered at pre- and post-test intervals were transcribed and analyzed using Systematic Analysis of Language Transcripts software.

‖ Refers to vocabulary used during intervention training sessions, which included 47 age-appropriate vocabulary items based on the MacArthur-Bates Communicative Development Inventory.

¶ Means increased on the EVIP, EOWPVT, and RDLS for all the groups. However, only the RDLS approached significance (p=.057).

Abbreviations: CBCL=Child Behavior Checklist; CCC-2=Children’s Communication Checklist, Second Edition; CDI=MacArthur Communicative Developmental Inventory; CELF-P2=Clinical Evaluation of Language Fundamentals-Preschool, Second Edition; CI=confidence interval; CTOPP=Comprehensive Test of Phonological Processing; DLS: Derbyshire Language Scheme; EMT=Enhanced Milieu Teaching; EOWPVT=Expressive One-Word Picture Vocabulary Test; EOWPVT-SBE=Expressive One-Word Picture Vocabulary Test, Spanish-Bilingual Edition; EVIP=Échelle de vocabulaire en images Peabody; EVT=Expressive Vocabulary Test; F=F-statistic; MCDI=MacArthur-Bates Communicative Development Inventory; N=sample size; no.=number; NR=not reported; PLS=Preschool Language Scale; PLS-5=Preschool Language Scale, Fifth Edition; RDLS=Reynell Developmental Language Scales; ROWPVT-SBE=Receptive One-Word Picture Vocabulary Test-4-Spanish-Bilingual Edition; SD: standard deviation: SES=socioeconomic status; SLP=speech-language pathologist.

Appendix E Table 3 Results of Included Treatment Randomized, Controlled Trials of School-Based Curriculum and Community-Based Speech-Language Disorder Interventions (KQ 4)

First Author, Year Intervention Category | N | Mean Age, Months | Intervention Description, Dose, and Duration | Control | Analysis; Timing of Outcome Assessment | Speech and Sound Outcomes | Language Outcomes
Wilcox, 2020^69^; School-based curriculum | 289 | 53.1 | Whole-class curriculum that embeds incidental and explicit oral language and early literacy teaching practices within planned learning opportunities; 34 weeks of instruction during 1 school year covering 14 thematic units, 2 weeks in duration each with review weeks every 5th week | Usual preschool curriculum | Differences between group at followup, adjusted for maternal education, baseline scores; p-values adjusted to address multiplicity of tests using the false-discovery rate control method; 34 weeks | NR | Mean post-test scores (SD), intervention vs. control:; CELF-P2 Standard scores:; Core language: 90.27 (0.91) vs. 89.52 (0.86); p=0.6182; Receptive language; 94.40 (1.12) vs. 93.11 (1.06); p=0.5943; Expressive language; 87.86 (0.85) vs. 84.98 (0.80); p-value=0.0630; Vocabulary Tests targeted by the curriculum:^*^; Fall expressive vocabulary:; 18.27 (0.56) vs.14.47 (0.54); p<0.0001; Fall receptive vocabulary:; 35.73 (0.49) vs. 33.01 (0.52); p=0.0055; Spring expressive vocabulary:; 23.15 (0.68) vs.18.44 (0.63); p<0.0001; Spring receptive vocabulary:; 36.75 (0.45) vs. 33.49 (0.54); p<0.0001
Acosta-Rodríguez, 2022^67^; School-based curriculum | 50 | 67.8 | Curriculum intervention with 95 (60-minute) sessions each delivered jointly by teachers and SLPs involving retelling and story generation | Usual classroom practices | Difference between groups in change from baseline to post-intervention, controlled for baseline scores; means and SD shown in figures only; numerical results reported as F-statistic from ANOVA models and generalized η2 (effect size) only;^†^ ~52 weeks^§^ | NR | Oral comprehension. subsets of the CELF-4, Spanish:; Concepts and Following Directions:; F(1;97)=40.3, η2=0.30; p ≤0.001; Word Classes-Receptive:; F(1;97)=156.6, η2=0.62; p ≤0.001; Sentence Structure:; F(1;97)=134.8; η2=0.59; p ≤0.001; Comprehension of paragraphs and narratives (correct responses to 2 tasks assessing comprehension):^ǂ^; F(1;97)=20.7, η2=0.18; p ≤0.001; Semantic Fluency, COWAT (no. of animals named in 60 seconds): F(1;97)=11.7, η2=0.11; p ≤0.001
Glogowska, 2000^72^; Community-based speech-language disorders | 159 | 34 | Referrals to speech-language clinics from primary care; no set frequency/duration; mean hours of therapy received was 6.2 total^‖^ | Watchful waiting | Difference between groups at 12-month followup, adjusted for baseline measure; 52 weeks | Mean phonology error rate:; −4.4 (95% CI, −12.0 to 3.3); p=0.26; Improvement on criteria used for study entry:^¶^; OR=1.3 (95% CI, 0.67 to 2.4); p=0.46 | Difference in age-adjusted PLS component scores:; Expressive language:; 1.4 (−2.1 to 4.8); p=0.44; Auditory comprehension:; 4.1 (0.5 to 7.6), d=~0.3; p=0.025; BLADES:; 0.1 (−0.4 to 0.6); p=0.73
McLeod, 2020^63^; Community-based speech-language disorders | 101 | 53.1 | Individual therapy reflecting usual practice offered immediately (vs. being wait-listed) at 2 community-based treatment centers; 12 weekly 45-minute sessions delivered in 26-week blocks separated by 2-week breaks | Advice control: brief visit with SLP to review results and resources^**^; Device control: link to evidence-based website with resources | Mean differences in outcomes at followup controlling for baseline measures; 26 weeks | % of consonants correct, mean (SE):^#^; Therapy: 7.40 (2.45); Advice: -4.72 (2.69); Device: -3.57 (2.49); p=0.001 for comparison of Therapy vs. both Advice and Device groups; Speech Intelligibility; ICS, mean score (SE):; Therapy: 4.01 (0.08); Advice: 3.89 (0.09); Device: 3.92 (0.08); Comparison across groups NS (p=0.500) | Expressive and receptive language skills; CELF-P2 mean score (SE):; Therapy: 49.56 (1.09); Advice: 50.18 (1.19); Device: 48.10 (1.10); Comparison across groups NS (p=0.502)

* Refers to receptive and expressive one-word picture vocabulary test that assessed higher-level receptive and expressive vocabulary targeted in the curriculum intervention and many other preschool curricula.

† Per the authors, an η2 around 0.01 is generally considered a small effect, an η2 around 0.06 indicates a medium effect, and an η2 >0.14 is a large effect.

ǂ Two tasks were completed, with correct responses scoring 1-point in both cases. The first task consisted of reading a short paragraph out loud and clearly to peers once, at a steady, leisurely pace, one word per second. The second task involved telling a story with the help of picture cards.

§ Duration of intervention was approximately one school year. Baseline measures were obtained prior to the intervention at the end of the 2017–2018 school year. The intervention was e implemented during the 2018–2019 school year (from the first week of November to the first week of April), with post-intervention outcomes obtained in the second half of April.

‖ All participants were children newly referred from primary care who were living in a monolingual home and who had no diagnosis of severe learning difficulties, autism, oromotor deficits, or primary diagnosis of stuttering or dysphonia.

¶ This refers to a binary variable indicating whether the child had improved sufficiently on the single clinical measure on which he or she had entered the study to no longer satisfy that particular criterion by 12 months, which may have been a speech or language outcome.

# Children’s speech production was assessed using the Phonology Assessment from the Diagnostic Evaluation of Articulation and Phonology software.

** Caregivers received a 45-minute session with an SLP to review assessment results, goal setting, and resources. The authors report that this was a revised model of usual practice of wait-lists between diagnosis and beginning therapy, informed by literature on book sharing, language stimulation, and speech stimulability training.

Abbreviations: ANOVA=analysis of variance; BLADES=Bristol Language Development Scales; CELF-4=Clinical Evaluation of Language Fundamentals- Fourth Edition, Spanish; CELF-P2=Clinical Evaluation of Language Fundamentals-Preschool, Second Edition (Australian Standardized Edition); CI=confidence interval; COWT=Controlled Oral Word Association Test; F=F-statistic from ANOVA models; ICS=Intelligibility in Context Scale; η2=Eta-squared effect size; N=sample size; no.=number; NR=not reported; NS=not significant; OR=odds ratio; PLS=Preschool Language Scale; SD=standard deviation; SE=standard error; SLP=speech-language pathologist.

Appendix E Table 4 Results of Included Treatment Randomized, Controlled Trials of Fluency and Speech-Sound Disorder Interventions (KQ 4)

First Author, Year Intervention Category | N | Mean Age, Months | Intervention Description, Dose, and Duration | Control | Analysis; Timing of Outcome Assessment | Speech and Sound Outcomes
Jones, 2005^73^; Fluency disorders | 54 | 54.4 | Lidcombe Program of Early Stuttering Intervention delivered according to manual; weekly face-to-face clinic visits with a therapist until improvement in stuttering occurred, then less frequently; parents were trained to provide verbal contingencies specific to stuttering | Wait-list | Difference between groups at followup, controlled for baseline stuttering frequency (measured via parent-recorded speech samples); 39 weeks | Mean % of syllables stuttered (SD), treatment vs. control:; 1.5 (SD 1.4) vs. 3.9 (SD 3.5); Difference between groups in change from baseline % syllables stuttered:; 2.3 (95% CI, 0.8 to 3.9); p=0.003
Lewis, 2008^74^; Fluency disorder | 22 | 52.4 | Lidcombe Program of Early Stuttering Intervention delivered according to manual; weekly telehealth visits with a therapist until improvement occurred, then less frequently; parents were trained to provide verbal contingencies specific to stuttering | Regular telephone contacts every 8 weeks^*^ | Difference between groups in change from baseline mean syllables stuttered;^†^39 weeks | Mean % of syllables stuttered treatment vs. control:; Baseline: 6.7 vs. 4.5; 39 weeks: 1.1 vs. 1.9; Difference between groups in change from baseline mean % syllables stuttered:; 3.0 (95% CI, NR)
Almost, 1998^70^; Speech sound disorder | 26 | 42 | Individual biweekly 30-minute sessions with an SLP for 4 months; treatment specific to children with a severe phonological disorder but normal receptive language function | No treatment | Difference in means at followup, adjusted for baseline scores and means across different timepoints; mean values NR, numerical results provided as F-statistic from ANOVA models and p-values;^ǂ^ 16 weeks | Phonological processes (APP-R score): F=8.64, Cohen's d=1.15; p=.007; Articulation (GFTA score): F=8.92, Cohen’s d=1.17; p=0.007; % consonants correct: F=8.06, Cohen’s d=1.11; p=0.009
McLeod, 2017^64^; Speech sound disorder | 123 | 56.1^*^ | Interactive software-based intervention, PFSS, for children with speech sound disorders was delivered in schools with teacher assistance | Standard care (typical classroom practices) | Difference between groups in change from baseline mean over time (1 week and 6–8 weeks post-intervention); 10 and 15–17 weeks | Mean (SD), intervention vs. control; Speech production, % of consonants correct (assessed via DEAP):; Baseline: 69.25 (9.13) vs. 64.34 (11.74); Between-group difference in change from baseline:; 6.15 vs. 5.43; p=0.874; Speech Intelligibility, ICS (parent reported):; Baseline: 3.75 (0.36) vs. 3.90 (0.38); Between-group difference in change from baseline:; 0.22 vs. 0.11; p=0.726
Namasivayam, 2021^68^; Speech sound disorder | 45 | 48.4 | Intervention for children with speech motor delay, PROMPT, focused on improving the accuracy and stability of speech production; 45-minute individual sessions twice weekly for 10 weeks | Standard care provided to those on a wait-list, including a 4-page handout detailing speech, language, and literacy strategies to be carried out at home | Difference between groups in change from baseline to followup scores, adjusted for baseline scores;10 weeks | Speech motor control outcomes:; VMPAC-FOC score: 6.270 (1.223 to 11.318); p=0.016; VMPAC-SEQ score (95% CI): 4.769 (−3.050 to 12.587); p=0.225; Probe Words score: 28.790 (3.784 to 58.832); p=0.025; Speech articulation outcomes:; Single-word articulation subtest of DEAP: 5.157 (2.061 to 8.252); p=0.002; Phonological process errors subtest of DEAP: 1.858 (−1.807 to 5.523); p=0.311; % of consonants correct: 10.855 (6.166 to 15.545); p<0.001; Speech intelligibility outcomes:; Word level (CSIM score): 8.595 (3.283 to 13.907); p=0.002; Sentence level (BIT score): -1.632 (−11.059 to 7.796); p=0.728

* Per the authors, regular phone contact was made to the control group as a matter of courtesy to maintain contact and to facilitate compliance.

† Outcomes assessed via three different parent audiotape recordings of conversational speech in everyday, nontreatment situations, both before and after treatment; one made with the child’s knowledge at home, one made with the child’s knowledge away from home, and one made covertly at home. Each recording contained a minimum of 300 syllables, which required approximately 10 minutes of conversation between the child and an adult; mean percentage of syllables stuttered was averaged across the different recordings.

ǂ Cohen’s d effect size values were calculated by the authors of the previous evidence review on this topic.

Abbreviations: ANOVA=analysis of variance; APP-R=Assessment of Phonological Processes- Revised; BIT=Beginner’s Intelligibility Test; CI=confidence interval;; CSIM=Children’s Speech Intelligibility Measure; DEAP=Diagnostic Evaluation of Articulation and Phonology Assessment; F=F-statistic from ANOVA models; GFTA=Goldman-Fristoe Test of Articulation; ICS=Intelligibility in Context Scale; N=sample size; NR=not reported; PFSS=Phoneme Factory Sound Sorter; PROMPT=Prompts for Restructuring Oral Muscular Phonetic Targets; SD=standard deviation; SLP=speech-language pathologist; VMPAC-FOC: Verbal Motor Production Assessment for Children- Focal Oromotor Control; VMPAC-SEQ=Verbal Motor Production Assessment for Children- Sequencing.

Appendix E Table 5 Results of Included Treatment Randomized, Controlled Trials Reporting on School Performance, Function, or Quality-of-Life (KQ 5)

First Author, Year Intervention Category | N | Mean Age, Months | Intervention Description, Dose, and Duration | Control | Analysis; Timing of Outcome Assessment | Emerging Literacy Outcomes | QOL, Function, Socialization or Behavior Outcomes
Wilcox, 2020^69^; School-based curriculum | 289 | 53.1 | Whole-class curriculum that embeds incidental and explicit oral language and early literacy teaching practices within planned learning opportunities; 34 weeks of instruction during 1 school year covering 14 thematic units, 2 weeks each in duration with review weeks every 5th week | Usual preschool curriculum | Differences between group at followup, adjusted for maternal education, baseline scores; p-values adjusted to address multiplicity of tests using the false-discovery rate control method; 34 weeks | TOPEL standard post-test scores (SD), intervention vs. control definitional vocabulary: 96.77 (1.18) vs. 96.16 (1.11); p=0.7067; Phonological awareness: 92.74 (1.41) vs. 91.16 (1.33); p=0.5943; PALS-PreK scores (no. correct):; Uppercase letter recognition:; 7.72 (0.33) vs. 7.25 (0.31); p=0.5943; Lowercase letter recognition:; 22.60 (0.37) vs. 23.05 (0.37); p=0.5943; Letter names:; 17.57 (0.74) vs. 18.34 (0.73); p=0.5943; Beginning sound awareness:; 20.15 (0.62) vs. 17.67 (0.58); p=0.0630 | NR
Glogowska, 2000^72^; Community-based speech-language disorders | 159 | 34 | Referrals to speech-language clinics from primary care; no set frequency/duration; mean hours of therapy received was 6.2 total | Watchful waiting | Difference between groups at 12-month followup, adjusted for baseline measure; 52 weeks | NR | Vineland socialization skills:; 0.6 (−3.1 to 4.2); p=0.76
McLeod, 2020^63^; Community-based speech-language disorders | 101 | 53.1 | Individual therapy reflecting usual practice offered immediately (vs. being wait-listed) at 2 community-based treatment centers; 12 weekly 45-minute sessions delivered in 26-week blocks separated by 2-week breaks | Advice control—brief visit with SLP to review results and resources.; Device control—link to evidence-based website with resources | Mean differences in outcomes at followup controlling for baseline measures; 26 weeks | PWPA mean score (SE):; Therapy: 10.26 (0.51); Advice: 9.03 (0.56); Device: 8.71 (0.52); Comparison across groups: NS (p=0.087) | NR
McLeod, 2017^64^; Speech sound disorder | 123 | 56.1 | Interactive software-based intervention, PFSS, for children with speech sound disorders delivered in schools with teacher assistance | Standard care (typical classroom practices) | Difference between groups in change from baseline mean over time (1 week and 6–8-weeks post-intervention); 10 and 15–17 weeks | Mean (SD), intervention vs. control; PWPA scores:; Baseline: 6.29 (3.43) vs. 5.69 (3.09); 5–8 weeks post-intervention: 7.59 (2.75) vs. 7.29 (3.16); Between-group difference in change from baseline:; 1.3 vs. 1.6; p=0.053; Letter Knowledge^*^; Baseline: 8.02 (8.58) vs. 5.95 (7.96); 6–8 weeks post-intervention: 11.75 (9.40) vs. 9.02 (9.43); Between-group difference in change from baseline:; 3.37 vs. 3.07; p=0.190 | Functional communication (FOCUS score); Baseline 253.4 (49.25) vs. 256.5 (38.09); 6–8 weeks post-intervention:; 261.1 (49.57) vs. 267.5 (49.69); p=0.668; KiddyCAT:; Baseline: 3.68 (2.42) vs. 3.76 (2.48); 6–8 weeks post-intervention:; 2.26 (2.39) vs. 3.15 (2.37); p=0.292; SPAA-C:; Baseline: 6.95 (2.76) vs. 5.60 (3.04); 6–8 weeks post-intervention; 5.90 (2.62) vs. 5.64 (2.71); p=0.151
Namasivayam, 2021^68^; Speech sound disorder | 45 | 48.4 | Intervention for children with speech motor delay (PROMPT) focused on improving the accuracy and stability of speech production; 45-minute individual sessions twice weekly for 10 weeks | Standard care provided to those on a wait-list, including a 4-page handout detailing speech, language, and literacy strategies to be carried out at home | Difference between groups in change from baseline to followup scores, adjusted for baseline scores; 10 weeks | NR | Functional communication (FOCUS score):; 2.042 (95% CI, −14.971 to 19.056); p=0.809
Robertson, 1999^76^; Language delay | 21 | 25 | Individual sessions delivered by an SLP over twice weekly 76-minute sessions for 12 weeks, designed to be interactive and emphasizing vocabulary development | Wait-list | Difference between groups in post-treatment scores, adjusted for baseline scores;^†^ 12 weeks | NR | Socialization (VABS socialization domain score):; 50.5 (6.1) vs. 46.2 (5.3); Cohen’s d=1.52; p=0.003); Parental stress (PSI Child Domain score):; 103.6 (15.1) vs. 110.2 (17.3); Cohen’s d=3.19; p<0.001)
Wake, 2011^62^; Language delay | 301 | 18.1 | Parent-toddler community-based language promotion program designed for toddlers identified as “slow to talk” via routine screening; 6 weekly 2-hour group sessions | Usual care (followup for routine child health visits) | Difference between groups at outcome assessment, adjusted for clustering, potential confounders (sex, exact age at outcome assessment, local government area, three indicators of SES), and baseline values; 24weeks | NR | Child Behavior; CBCL, externalizing behavior raw score (95% CI); 2 year: −0.3 (−1.6 to 1.1); p=0.71; 3 year: −0.1 (−1.6 to 1.4); p=0.86; CBCL internalizing behavior raw score: (95% CI); 2 year: 0.1 (−0.9 to 1.1); p=0.78; 3 year: −0.1 (−1.3 to 1.2); p=0.92
Wake, 2013^77^; Language delay | 200 | 49.550 | Individual home-based therapy delivered by trained assistants to promote narrative skills, vocabulary, grammar, phonological awareness, and preliteracy skills; 18 (1-hour) sessions delivered in 3 blocks of 6 weekly sessions | No treatment | Difference in mean scores between groups at followup, adjusted for child gender, mother’s education level, recruitment setting, and baseline scores; 52 weeks | Difference in mean scores at followup:; Letter knowledge:^ǂ^; 2.4 (0.3 to 4.5); p=0.03 | Behavioral problems. SDQ score:; -0.5 (−1.7 to 0.7); p=0.43; Health-related quality of life:; Peds QL total score: -0.8 (−5.2 to 3.5); p=0.71; HUI3 overall score: 0.03 (−0.02 to 0.09); p=0.22

* Letter knowledge was determined by showing children pairs of each capital and lowercase letter of the alphabet in a random sequence. Children were asked to identify letters that they knew (e.g., Mm, Tt) and tell the SLP the name of the letter (e.g., em, tee) and the sound it made (e.g., /m/, /t/).

† Cohen’s d effect size values were calculated by the authors of the previous evidence review on this topic.

ǂ Based on Letter Knowledge Task, 26 alphabet letters summed, with possible range from 0 to 26.

Abbreviations: CI=confidence interval; CBCL=Child Behavior Checklist; FOCUS=Focus on the Outcomes of Children Under Six; HUI3=Health Utilities Index Mark 3; KiddyCAT=Communication Attitude Test for Preschool and Kindergarten Children Who Stutter; N=sample size; NR=not reported; no.=number; NS=not significant; PALS-PreK=Phonological Awareness and Literacy Screening PreK; Peds QL=Pediatric Quality of Life Inventory (parent-proxy); PFSS=Phoneme Factory Sound Sorter; PROMPT=Prompts for Restructuring Oral Muscular Phonetic Targets; PSI=Parenting Stress Index; PSI-CD=Parenting Stress Index child domain score; PWPA=Preschool Word and Print Awareness; QOL=quality of life; SES=socioeconomic status; TOPEL=Test of Preschool Early Literacy; SD=standard deviation; SDQ=Strengths and Difficulties Questionnaire; SE=standard error; SLP=speech-language pathologist; SPAA-C=Speech Participation and Activity Assessment of Children; VABS=Vineland Adaptive Behavior Scale.