# Appendix D Quality Assessments

Appendix D Table 1 Quality Ratings of Studies of Screening Questionnaires and Clinical Prediction Tools (KQ 2), Part 1

First Author, Year | Index Test | Reference Standard | Bias Due to Patient Selection | Comments | Bias Due to Index Test | Comments | Bias Due to Reference Standard | Comments
Faldt, 2021^83^ | ITC (Swedish version) | Behavior Sample from CSBS | Low | None | Low | None | Unclear | Unclear if reference standard was scored without knowledge of screening test result.
Holzinger, 2021^40^ | SPES-3 (Sprachentwicklungscreening) | Independent diagnoses by two experienced clinical linguists using; SETK-3, AWST-R, and spontaneous language sample | Unclear | All screen-positive children from four practices were invited to participate and a random sample of other children who had not had a reference test already (regardless of screening result); the authors partially address potential for spectrum bias using modeling and imputation. | Low | None | Low | None
Kok, 2019^37^ | ICS-TC | HKCAT | Low | None | Low | None | Low | None
Nayeb, 2019^39^ | Nurse Screenng Nurse-administered comprehensive test (5 items) and ability to use 2-word or; 3-word sentences | SLP-administered Reynell Development Language Scales III; (Swedish version) and observation of communication | Low | None | Low | None | Low | None
Nayeb, 2021^41^ | Nurse Screening Swedish measure—5 comprehension questions, use of two-word utterances; —combined screening in both Swedish and maternal langauge | SLP conducted a structured observation during a play session to assess child’s ability to talk in multi-word utterances and receptive portion of RDLS | Low | None | Low | None | Low | Authors state that a blinded RA sent de-identified protocols to the SLP who scored screening tests. The same SLP conducted assessments for the reference standard. Since the SLP was not aware of child names on the screening tests, assume that results were not known at the time of the reference test examination.
Pace, 2022^58^ (Study 2 only) | QUILS | Auditory Component Subtest of the PLS-5 | Unclear | There is no description of how students were selected from participating sites (university speech and hearing clinic, a public school with inclusive preschool and kindergarten classrooms, and preschool programs and Head Start centers in four university sites), whether it was consistent across sites or if there were specific exclusion criteria at the point of recruitment. | Low | Threshold was determined based on optimal sensitivity/specificity values from ROC curves. | Low | None
Vehkavuori, 2018^84^ | CDI-SF and CSBS (Finnish) | RDLS III | Unclear | No description of how sample was recruited from larger cohort study. | Unclear | Authors reported using a threshold for the screener, but it was unclear if this was prespecified or based on results of the current analysis. | Unclear | Unclear if results of reference test were interpreted independently of index tests; however, this is unlikely to be a concern given that the reference test is a standardized assessment.
Visser-Bochane, 2021^85^ | Dutch well-child language screening protocol (producing a 2-word sentence and pointing out 5 body parts on a doll) | Home visit by SPL, who administered three standardized diagnostic tests; diagnosis was made on a combination of test results | High | Risk of spectrum bias; all children who failed the screening were invited to participate, along with gender-matched children who passed the screening test. | Low | None | Low | None
Visser-Bochane, 2021^38^ | ELS | Home visit by language specialist, who administered multiple standardized age-appropriate diagnostic tests^*^ | Low | None | Low | Unclear how the threshold was chosen and whether it was prespecified or based on analyses that informed an optimal threshold. | Unclear | Unclear whether reference test was administered without knowledge of index test results; screening questionnaire was collected by the person conducting a home visit to conduct reference tests.
Wilson, 2022^59^ | ASQ and SSLM | PLS-5 | Low | None | Low | No single threshold was used for the index test-optimal cutoff scores determined from ROC curve analysis. | Low | None

* Lexilist Comp and Production, Schilchting Lang Comp, Word Prod, Sentence Prod, Language Standard, Communication Checklist.

Abbreviations: ASQ=Ages and Stages Questionnaire; AWST-r=Aktiver Wortschatztest für 3-bis 5-jährige Kinder; CDI-SF=Children’s Depression Inventory-Short Form. CSBS=Communication and Symbolic Behavior Scales; ELS=Early Language Scale; HKCAT=Hong Kong Cantonese Articulation Test; ITC=Intelligibility in Context Scale; ICS-TC=Intelligibility in Context Scale–Traditional Chinese; PLS-5= Preschool Language Scale, Fifth Edition; QUILS= Quick Interactive Language Screener; RDLS=Reynell Developmental Language Scales; ROC=receiver operating characteristic; SETK-3=Sprachentwicklungstest für zweijahrige Kinder; SLP=speech-language pathologist; SPEC-3=Sprachentwicklungsscreening; SSLM=Sure Start Language Measure.

Appendix D Table 2 Quality Ratings of Studies of Screening Questionnaires and Clinical Prediction Tools (KQ 2), Part 2

First Author, Year | Bias Due to Flow and Timing | Comments | Overall Quality Rating | Comments | Are There Concerns That the Included Patients Do Not Match the Review Question? | Comments on Applicability
Faldt, 2021^83^ | High | Overall, a small proportion of those who had the screening test were evaluted with the reference standard (26% of screen positives and 9% of screen negatives). Sampling from the larger pool who had the index test differed by group (random sampling of screen negatives and nonrandom referral of positives). Although the authors say the children referred were similar to those who were not referred, the reasons for referral are not clear and the children may differ in characteristics not reported or measured. Those not referred had screen-postiive results close to the reference standard and were not incuded in the analysis. | Poor | None | NA | NA
Holzinger, 2021^40^ | Low | It is unclear how many children were excluded based on missing data or other factors. | Fair | There is a risk of spectrum bias based on sampling of all positive results and a selection of other children. This was partially addressed using modeling and imputation to estimate accuracy for a larger population. | Yes | Sample limited to German children.
Kok, 2019^37^ | Unclear | It is unclear whether the 11% who were excluded for missing data were simiilar to the population analyzed in terms of risk factors for an SLD. | Fair | It is unclear whether the 11% who were excluded for missing data were simiilar to the population analyzed in terms of risk factors for an SLD. | Yes | Population is from those speaking Cantonese in Hong Kong; reference test is specific to this language only.
Nayeb, 2019^39^ | Unclear | Reference standard was conducted within 2 months of the screening, which may be an interval that allows some children who had a positive test result to catch up; 25% were lost to attrition and were excluded from analysis. | Fair | The reference standard was conducted within 2 months of the screening, which may be an interval that allows some children who had a positive test result to catch up; 25% were lost to attrition and were excluded from analysis. | Yes | Sample limited to Swedish children.
Nayeb, 2021^41^ | Unclear | Of those screened, 10% did not have the reference test and were excluded from the analysis. It is unclear if they were more or less likely to have an SLD compared with the completers. | Fair | There was a risk of bias related to flow and timing. Not all the participants were included in the analysis; 10% who were screened did not have the reference test and were excluded. It is unclear if they were more or less likely to have an SLD compared with the completers. | Yes | Screening was conducted in Swedish and various other lanaguages not commonly spoken in the United States. The screening occurred in the home setting and was conducted by trained nurses and preschool staff; may not be applicable to screening in U.S. primary care settings.
Pace, 2022^58^ (Study 2 only) | Unclear | There is no information on missing data; authors note final sample represented those who “completed both the QUILS and the standardized assessment administered for validation.” | Fair | There is no information on methods to select participats from sites or missing data; authors note final sample represented those who “completed both the QUILS and the standardized assessment administered for validation.” | Yes | QUILS screener is intended for use in a classroom or community context; it takes approximately 15 minutes to complete.
Vehkavuori, 2018^84^ | Unclear | There is no description of attrition, and it is unclear if the analyzed sample includes all those who completed the index test or a subset of those who completed the index and reference test. | Poor | There was unclear patient selection and no description of attrition or whether those analyized included all who were recruited vs. only the sample that completed the screening and the index test. It is unclear whether the screening test cut point was prespecified. | NA | NA
Visser-Bochane, 2021^85^ | Unclear | The reference standard was conducted within 4 months of the screening, which may be an interval that allows some children who had a positive test result to catch up. | Poor | There was a risk of spectrum bias given the recruitment of all children with screen-positive results and the age-matched sample of children with negative screening results. The reference standard was conducted within 4 months of screeing, which may be an interval that allows some children who had a positive test result to catch up. | Yes | Sample limited to Dutch children.
Visser-Bochane, 2021^38^ | Low | None | Fair | It is unclear how the threshold was chosen for the screener and unclear whether the SLP knew the results of screener before administering the reference measure. | Yes | Sample limited to Dutch children.
Wilson, 2022^59^ | Unclear | A large proportion of participants who completed the index test did not attend an appointment for the reference test (44%); however, characteristics of those who attended and those who did not were similar, and the reasons for not attending were primairly due to COVID-19 lockdown. | Fair | A large proportion of participants who completed index test did not attend appointment for reference test (44%); however, characteristics of those who attended and those who did not were similar, and reasons for not attending were primairly due to COVID-19 lockdown. | Yes | Children enrolled from the U.K.

Abbreviations: NA=not applicable; QUILS=Quick Interactive Language Screening; SLD=speech language disorder; SLP=speech-language pathologist.

Appendix D Table 3 Quality Ratings of Treatment Cluster Randomized, Controlled Trials (KQs 4 and 5)

First Author, Year | Bias Due to Randomization Process | Comment on Randomization Process | Bias Due to Timing of Identification or Recruitment of Participants | Comment on Timing of Identification or Recruitment of Participants | Bias Due to Deviations From Intended Interventions | Comment on Deviations From Intended Interventions | Bias Due to Missing Outcome Data | Comment on Missing Outcome Data
McLeod, 2017^64^ | Low | None | Low | None | Low | None | Low | None
Wilcox, 2020^69^ | Some concerns | None | Low | None | Low | None | Low | Overall, 9% of teachers (clusters) and the children in their classrooms (9% of all children) were lost to attrition due to teachers not continuing in trial; the reasons for attrition varied (moving, teachers let go, and other personal reasons). Of the included children, another 10% had missing data at 1 or more time point.

Appendix D Table 4 Quality Ratings of Treatment Cluster Randomized Controlled Trials (KQs 4 and 5)

First Author, Year | Bias Due to Measurement of the Outcome | Comment on Measurement of the Outcome | Bias Due to Selection of the Reported Result | Comment on Selection of the Reported Result | Overall Bias | Comment for Overall Bias
McLeod, 2017^64^ | Low | None | Some concerns | None | Some concerns | No information about selection of reported results or whether multiple eligible analyses of data were conducted. the authors report conducting analyses using multiple imputation but only report primary analyses that includes those with complete data.
Wilcox, 2020^69^ | Some concerns | Pre- and post-testing completed by blinded research assistants, but curriculum-based measures in intervention group were completed by teachers (completed by research assistants in the control group) | Some concerns | Data were missing for 10.7% of these measurement points and we assumed that these data were missing at random for all analyses. | Some concerns | Allocation sequence described as a “lottery” with no other information provided. Unclear whether allocation was concealed until all clusters (teachers) were enrolled and assigned to invertenion groups. Only maternal education level and income were described; includes no other baseline characteristics of children or teachers. Intervention assessors were not blinded for curriculum-based outcomes. No information on whether data were analyzed based on a prespecified plan or if multile analyses of data were conducted and current analysis chosen based on results.

Appendix D Table 5 Quality Ratings of Treatment Randomized Controlled Trials (KQs 4 and 5)

First Author, Year | Bias Due to Randomization Process | Comment on Randomization Process | Bias Due to Deviations From Intended Interventions | Comment on Deviations From Intended Interventions | Bias Due to Missing Outcome Data | Comment on Missing Outcome Data
Thordardottir, 2015^65^ | Low | None | Some concerns | None | Some concerns | None
McLeod, 2020^63^ | Low | None | Some concerns | None | High | None
Roberts, 2015^86–88^ | Low | None | Low | None | High | None
Roberts, 2014^89^ | Some concerns | None | Low | None | High | None
Peredo, 2022^66^ | Low | None | Low | None | Low | None
Acosta-Rodríguez, 2022^67^ | Low | None | Some concerns | None | Low | None
Namasivayam, 2021^68^ | Some concerns | None | Low | None | Some concerns | None
Delgado-Cruz, 2022^90^ | Some concerns | Groups were statistically similar based on age and randomization was adjusted for sex. There are no remarks in the article about the similarity of baseline outcome measures. | Some concerns | No blinding; unclear if there were deviations from the intended intervention due to the trial context. | High | Authors note that 32 participants were excluded for not completing the tests due to repeated absences or lack of cooperation, but it is unclear whether the exclusions occurred before or after randomization. Those who could not cooperate could be at higher risk for speech/language problems.
Madsen, 2022^91^ | High | Intervention was delivered at the level of the classroombut not all classrooms were randomized; some teachers in the treatment arm had been involved in a previous trial and their classrooms continued in the treatment group. Qualitatively meaningful baseline differences were present; treatment children were more likely to be non-Hispanic, Black/African American, speak English at home, live in households earning >$50,000 a year, and have parents with a bachelor's degree than control group children. There was also a small, nonsignificant difference in pre-intervention word scores. | Low | None | Low | None
Parra-López, 2022^92^ | Some concerns | No detail reported about use of allocation concealment. No detail about distribution of age, sex, or other relevant baseline characteristics between groups. | Some concerns | Data were excluded for participants who were excluded post-randomization due to “abandoning” school mid-study or having articulation difficulties caused by organic difficulties. Overall attrition was minimal (5.5%), and therefore, exclusion of missing data would not have introduced problematic amount of bias. | Low | None
Chen, 2022^93^ | Some concerns | No detail reported about allocation concealment. No rational provided for why sample size was nearly twice as high in the intervention vs. control arm (34 vs. 15), including whether this was purposeful or if there were post-randomization exclusions or differential attrition (and authors focused on completers only), or other reasons. | Some concerns | No detail about whether attrition occurred or whether ITT or a similar analytic approach was used; authors note that fidelity measures were implemented, but these were not described. | Some concerns | Unclear whether there was attrition/missing data, or if analysis focuses only on children who completed the study.

Abbreviations: ITT=intention to treat.

Appendix D Table 6 Quality Ratings of Treatment Randomized, Controlled Trials (KQs 4 and 5)

First Author, Year | Bias Due to Measurement of the Outcome | Comment on Measurement of the Outcome | Bias Due to Selection of the Reported Result | Comment on Selection of the Reported Result | Overall Bias | Comment for Overall Bias
Thordardottir, 2015^65^ | Low | None | Some concerns | None | Some concerns | Of those randomized, 15% (n=5) did not complete the study and were not included in the analysis. In addition, one participant initially randomized to the intervention was reassigned to the control group for logistical reasons. Analysis was modified ITT. Unclear if attrition depended on child’s language ability or scores. Authors note factors that could influence child development as reasons for attrition: parental difficulty traveling to intervention site, parental lack of motivation, and other family situations that caused difficulty participating.
McLeod, 2020^63^ | Low | None | Low | None | Some concerns | None
Roberts, 2015^86–88^ | Some concerns | None | Some concerns | None | High | None
Roberts, 2014^89^ | Some concerns | None | Some concerns | None | High | None
Peredo, 2022^66^ | Low | None | Low | None | Low | 20% overall attrition and 17% differential attrition in this small sample would suggest potential for attrition bias, but sensitivity analyses comparing ITT with complete case data suggest this risk is minimal and not enough to affect the results.
Acosta-Rodríguez, 2022^67^ | Low | None | Some concerns | None | Some concerns | Unclear if allocation concealment was used during randomization. No reporting of treatment fidelity or how it might have been measured. No information reported about which analyses were prespecified or how closely applied analyses fit the analytic plan laid out by the protocol.
Namasivayam, 2021^68^ | Low | None | Low | None | Some concerns | More patients in wait-list arm (82.6% vs. 65.0%) had a history of speech and language intervention prior to the study. Followup data were missing for 10% to 18% of participants depending on outcome. Unclear if missing data affected the results (or how) and whether the absence of data was related to severity of children’s SLD.
Delgado-Cruz, 2022^90^ | Some concerns | Unclear if outcome assessors evaluating narrative performance were aware of children's group assignments. | Some concerns | Unclear if analysis was done according to prespecified analysis plan. | High | Authors note that 32 participants were excluded for not completing the tests due to repeated absences or lack of cooperation, but it is unclear whether the exclusions occurred before or after randomization. Children who could not cooperate could be at higher risk for speech/language problems. Unclear whether groups were similar at baseline in terms of speech and language outcomes.
Madsen, 2022^91^ | Low | None | Low | None | High | Intervention was delivered at the level of the classroom and was not completely randomized; some teachers in the treatment arm had been involved in a previous trial and their classrooms continued in the treatment group. Qualitatively meaningful baseline differences were present; treatment children were more likely to be non-Hispanic, Black/African American, speak English at home, live in households earning >$50,000 a year, and have parents with a bachelor's degree. There was also a small, nonsignificant difference in pre-intervention word scores.
Parra-López, 2022^92^ | High | Primary outcome measure was administered in the speech therapy classroom, presumably by the teachers administering the intervention or control lesson plans. Unclear to what extent this introduced outcome assessment bias. | Low | None | High | Most concerning issue was the potential for outcome assessment bias because the primary outcome measure was administered in the speech therapy classroom, presumably by the teachers administering intervention or control lesson plans. No detail was reported about the use of allocation concealment. No statistical evaluation was reported for distribution of age, sex, or other relevant baseline characteristics between groups. Analysis did not include participants who were excluded post-randomization due to “abandoning” school mid-study or having articulation problems caused by organic difficulties. Overall attrition was minimal (5.5%), and therefore, exclusion of missing data would not have introduced a problematic amount of bias.
Chen, 2022^93^ | Some concerns | Method for measuring speech discrimination task may not be appropriate—there are other potential reasons children may score low (e.g., poor attention, ADHD). Vocabulary definition production task is appropriate. | Low | None | High | No detail reported about allocation concealment, including rational for why sample size was nearly twice as large in the intervention vs. the control arm (34 vs. 15), Unclear whether there was attrition/missing data, or if the analysis focused only on children who completed the study. Method for measuring speech discrimination task may not be appropriate—there are other potential reasons children may score low (e.g., poor attention, ADHD).

Abbreviations: ADHD=attention deficit hyperactivity disorder; ITT=intention to treat; SLD=speech language disorder.