# Appendix C Excluded Articles

- X1: Non-English Publication
- X2: Ineligible Population
- X3: Ineligible/No Screening
- X4: Ineligible/No Treatment
- X5: Ineligible/No Comparison
- X6: Ineligible/No Outcome
- X7: Ineligible Setting
- X8: Ineligible Study Design
- X9: Ineligible Country
- X10: Abstract Only
- X11: Poor Quality

1 Cl Orellana, Wada R Gillam RB. The use of dynamic assessment for the diagnosis of language disorders in bilingual children: a meta-analysis. Am J Speech Lang Pathol. 2019 Aug 9;28(3): 1298–317. doi: 10.1044/2019_AJSLP-18-0202. PMID: 31194570. Exclusion Code: X8.31194570
2 Pawlowska M. Evaluation of three proposed markers for language impairment in English: a meta-analysis of diagnostic accuracy studies. J Speech Lang Hear Res. 2014 Dec;57(6):2261–73. doi: 10.1044/2014_JSLHR-L-13-0189. PMID: 25198731. Exclusion Code: X8.25198731
3 Mackay MT, Chua ZK, Lee M, Stroke and nonstroke brain attacks in children. Neurology. 2014 Apr 22;82(16): 1434–40. doi: 10.1212/WNL.0000000000000343. PMID: 24658929. Exclusion Code: X2.24658929
4 Haghish EF, Vach W, Hojen A, Estimating measurement error in child language assessments administered by daycare educators in large scale intervention studies. PLoSOne. 2021;16(11):e0255414. doi: 10.1371/journal.pone.0255414. PMID: 34797825. Exclusion Code: X6.34797825
5 Yeh LL, Liu CC. Comparing the informativeness of single-word samples and connected speech samples in assessing speech sound disorders. J Speech Lang Hear Res. 2021 Nov 8;64(11):4071–84. doi: 10.1044/2021_JSLHR-20-00172. PMID: 34618552. Exclusion Code: X3.34618552
6 Sjostrand A, Kefalianos E, Hofslundsengen H, Non-pharmacological interventions for stuttering in children six years and younger. Cochrane Database Syst Rev. 2021 Sep 9;9(9):CD013489. doi: 10.1002/14651858.CD013489.pub2. PMID: 34499348. Exclusion Code: X8.34499348
7 Taha J, Stojanovik V, Pagnamenta E. Nonword repetition performance of Arabic-speaking children with and without developmental language disorder: a study on diagnostic accuracy. J Speech Lang Hear Res. 2021 Jul 16;64(7):2750–65. doi: 10.1044/2021_JSLHR-20-00556. PMID: 34232699. Exclusion Code: X2.34232699
8 Parsons AA, Ollberding NJ, Copeland KA, Factors associated with residential relocation and effects on early childhood development in a low-income home visitation population. J Prim Prev. 2021 Apr;42(2):125–41. doi: 10.1007/s10935-021-00625-4. PMID: 33651259. Exclusion Code: X4.33651259
9 Euler HA, Merkel A, Hente K, Speech restructuring group treatment for 6-to-9-year-old children who stutter: a therapeutic trial. J Commun Disord. 2021 Jan-Feb;89:106073. doi: 10.1016/j.jcomdis.2020.106073. PMID: 33444874. Exclusion Code: X2.33444874
10 McGill N, McLeod S, Ivory N, Randomised controlled trial evaluating active versus passive waiting for speech-language pathology. Folia Phoniatr Logop. 2021;73(4):335–54. doi: 10.1159/000508830. PMID: 32756053. Exclusion Code: X4.32756053
11 Rakhlin NV, Li N, Aljughaiman A, Narrative language markers of Arabic language development and impairment. J Speech Lang Hear Res. 2020 Oct 16;63(10):3472–87. doi: 10.1044/2020_JSLHR-20-00082. PMID: 32916078. Exclusion Code: X3.32916078
12 Kan PF, Fluang S, Winicour E, Vocabulary growth: dual language learners at risk for language impairment. Am J Speech Lang Pathol. 2020 Aug 4;29(3): 1178–95. doi: 10.1044/2020_AJSLP-19-00160. PMID: 32750277. Exclusion Code: X2.32750277
13 Willadsen E, Persson C, Patrick K, Assessment of prelinguistic vocalizations in real time: a comparison with phonetic transcription and assessment of inter-coderreliability. Clin Linguist Phon. 2020 Jul 2;34(7):593–616. doi: 10.1080/02699206.2019.1681516. PMID: 31711312. Exclusion Code: X6.31711312
14 Celik P, Ayranci Sucakli I, Yakut EH. Which Bayley-III cut-off values should be used in different developmental levels? Turk J Med Sci. 2020 Jun 23;50(4):764–70. doi: 10.3906/sag-1910-69. PMID: 31905494. Exclusion Code: X2.31905494
15 Faldt A, Fabian FI, Thunberg G, The study design of ComAlong Toddler: a randomised controlled trial of an early communication intervention. Scand J Public Health. 2020 Jun;48(4):391–9. doi: 10.1177/1403494819834755. PMID: 31068096. Exclusion Code: X8.31068096
16 Alt M, Mettler FI M, Erikson JA, Exploring input parameters in an expressive vocabulary treatment with late talkers. J Speech Lang Hear Res. 2020 Jan 22;63(1):216–33. doi: 10.1044/2019_JSLHR-19-00219. PMID: 31944869. Exclusion Code: X5.31944869
17 Barker RM, Romski M, Sevcik RA, Intervention focus moderates the association between initial receptive language and language outcomes for toddlers with developmental delay. Augment Altern Commun. 2019 Dec;35(4):263–73. doi: 10.1080/07434618.2019.1686770. PMID: 31868037. Exclusion Code: X5.31868037
18 Li'el N, Williams C, Kane R. Identifying developmental language disorder in bilingual children from diverse linguistic backgrounds. Int J Speech Lang Pathol. 2019 Dec;21(6):613–22. doi: 10.1080/17549507.2018.1513073. PMID: 30253708. Exclusion Code: X3.30253708
19 Koushik S, Hewat S, Onslow M, Three Lidcombe program clinic visit options: a phase II trial. J Commun Disord. 2019 Nov-Dec;82:105919. doi: 10.1016/j.jcomdis.2019.105919. PMID: 31351345. Exclusion Code: X5.31351345
20 Johnson S, Bountziouka V, Brocklehurst P, Standardisation of the Parent Report of Children's Abilities-Revised (PARCA-R): a norm-referenced assessment of cognitive and language development at age 2 years. Lancet Child Adolesc Health. 2019 Oct;3(10):705–12. doi: 10.1016/S2352-4642(19)30189-0. PMID: 31402196. Exclusion Code: X5.31402196
21 Kapa LL, Erikson JA. Variability of executive function performance in preschoolers with developmental language disorder. Semin Speech Lang. 2019 Aug;40(4):243–55. doi: 10.1055/s-0039-1692723. PMID: 31311051. Exclusion Code: X4.31311051
22 Lavelli M, Barachetti C, Majorano M, Impacts of a shared book-reading intervention for Italian-speaking children with developmental language disorder. Int J Lang Commun Disord. 2019 Jul;54(4):565–79. doi: 10.1111/1460-6984.12460. PMID: 30729644. Exclusion Code: X5.30729644
23 Rudolph JM, Dollaghan CA, Crotteau S. The finite verb morphology composite: values from a community sample. J Speech Lang Hear Res. 2019 Jun 19;62(6):1813–22. doi: 10.1044/2019_JSLHR-L-18-0437. PMID: 31112435. Exclusion Code: X2.31112435
24 Korat O, Graister T, Altman C. Contribution of reading an e-book with a dictionary to word learning: comparison between kindergarteners with and without SLI. J Commun Disord. 2019 May-Jun;79:90–102. doi: 10.1016/j.jcomdis.2019.03.004. PMID: 30974294. Exclusion Code: X5.30974294
25 Kruythoff-Broekman A, Wiefferink C, Rieffe C, Parent-implemented early language intervention programme for late talkers: parental communicative behaviour change and child language outcomes at 3 and 4 years of age. Int J Lang Commun Disord. 2019 May;54(3):451–64. doi: 10.1111/1460-6984.12451. PMID: 30680870. Exclusion Code: X8.30680870
26 Landry SH, Assel MA, Carlo MS, The effect of the Preparing Pequenos smallgroup cognitive instruction program on academic and concurrent social and behavioral outcomes in young Spanishspeaking dual-language learners. J Sch Psychol. 2019 Apr;73:1–20. doi: 10.1016/j.jsp.2019.01.001. PMID: 30961875. Exclusion Code: X2.30961875
27 Goycoolea MV, Levy R, Bustamante MP, Chances of reversibility in early sensory deprivation of the Homo vulnerabilis: a 5year (and ongoing) prospective study. Acta Otolaryngol. 2019 Apr;139(4):357–60. doi: 10.1080/00016489.2018.1538566. PMID: 30734637. Exclusion Code: X2.30734637
28 Faldt A, Nordlund H, Holmqvist U, Nurses' experiences of screening for communication difficulties at 18 months of age. Acta Paediatr. 2019 Apr;108(4):662–9. doi: 10.1111/apa.14557. PMID: 30153364. Exclusion Code: X6.30153364
29 Syadar SF, Zarifian T, Modarresi Y, Kurdish Speech Test: a validation study for children aged 3–5years. Int J Pediatr Otorhinolarymgol. 2019 Feb;117:61–6. doi: 10.1016/j.ijporl.2018.10.009. PMID: 30579091. Exclusion Code: X3.30579091
30 McLeod S, Masso S. Screening children's speech: the impact of imitated elicitation and word position. Lang Speech Hear Serv Sch. 2019 Jan 28;50(1):71–82. doi: 10.1044/2018_LSHSS-17-0141. PMID: 30383182. Exclusion Code: X2.30383182
31 Wu SY, Huang RJ, Tsai IF. The applicability of D, MTLD, and MATTR in Mandarin-speaking children. J Commun Disord. 2019 Jan-Feb;77:71–9. doi: 10.1016/j.jcomdis.2018.10.002. PMID: 30686328. Exclusion Code: X3.30686328
32 Oetting JB. Prologue: toward accurate identification of developmental language disorder within linguistically diverse schools. Lang Speech Hear Serv Sch. 2018 Apr 5;49(2):213–7. doi: 10.1044/2018_LSHSS-CLSLD-17-0156. PMID: 29621801. Exclusion Code: X8.29621801
33 Fabiano-Smith L, Hoffman K. Diagnostic accuracy of traditional measures of phonological ability for bilingual preschoolers and kindergarteners. Lang Speech Hear Serv Sch. 2018 Jan 9;49(1):121–34. doi: 10.1044/2017_LSHSS-17-0043. PMID: 29121152. Exclusion Code: X2.29121152
34 Imeson J, Lowe R, Onslow M, The Lidcombe Program and child language development: long-term assessment. Clin Linguist Phon. 2018;32(9):860–75. doi: 10.1080/02699206.2018.1448897. PMID: 29543506. Exclusion Code: X5.29543506
35 Auza BA, Harmon MT, Murata C. Retelling stories: grammatical and lexical measures for identifying monolingual Spanish speaking children with specific language impairment (SLI). J Commun Disord. 2018 Jan-Feb;71:52–60. doi: 10.1016/j.jcomdis.2017.12.001. PMID: 29274509. Exclusion Code: X6.29274509
36 Norbury CF, Vamvakas G, Gooch D, Language growth in children with heterogeneous language disorders: a population study. J Child Psychol Psychiatry. 2017 Oct;58(10):1092–105. doi: 10.1111/jcpp.12793. PMID: 28921543. Exclusion Code: X4.28921543
37 Fricke S, Burgoyne K, Bowyer-Crane C, The efficacy of early language intervention in mainstream school settings: a randomized controlled trial. J Child Psychol Psychiatry. 2017 Oct;58(10):1141–51. doi: 10.1111/jcpp.12737. PMID: 28524257. Exclusion Code: X2.28524257
38 Willinger U, Schmoeger M, Deckert M, Screening for specific language impairment in preschool children: evaluating a screening procedure including the Token Test. J Psycholinguist Res. 2017 Oct;46(5):1237–47. doi: 10.1007/s10936-017-9493-z. PMID: 28474204. Exclusion Code: X6.28474204
39 le Clercq CMP, van der Schroeff MP, Rispens JE, Shortened nonword repetition task (NWR-S): a simple, quick, and less expensive outcome to identify children with combined specific language and reading impairment. J Speech Lang Hear Res. 2017 Aug 16;60(8):2241–8. doi: 10.1044/2017_JSLHR-L-16-0060. PMID: 28702677. Exclusion Code: X3.28702677
40 Pua EP K, Lee ML C, Rickard Liow SJ. Screening bilingual preschoolers for language difficulties: utility of teacher and parent reports. J Speech Lang Hear Res. 2017 Apr 14;60(4):950–68. doi: 10.1044/2016_JSLHR-L-16-0122. PMID: 28297001. Exclusion Code: X5.28297001
41 Liu XL, de Villiers J, Ning C, Research to establish the validity, reliability, and clinical utility of a comprehensive language assessment of Mandarin. J Speech Lang Hear Res. 2017 Mar 1;60(3):592–606. doi: 10.1044/2016_JSLHR-L-15-0334. PMID: 28253384. Exclusion Code: X3.28253384
42 Kazemi Y, Saeednia S. The clinical examination of non-word repetition tasks in identifying Persian-speaking children with primary language impairment. Int J Pediatr Otorhinolaryngol. 2017 Feb;93:7–12. doi: 10.1016/j.ijporl.2016.11.028. PMID: 28109501. Exclusion Code: X3.28109501
43 Fey ME, Leonard LB, Bredin-Oja SL, A clinical evaluation of the competing sources of input hypothesis. J Speech Lang Hear Res. 2017 Jan 1;60(1):104–20. doi: 10.1044/2016_JSLHR-L-15-0448. PMID: 28114610. Exclusion Code: X5.28114610
44 Storkel HL, Voelmle K, Fierro V, Interactive book reading to accelerate word learning by kindergarten children with specific language impairment: identifying an adequate intensity and variation in treatment response. Lang Speech Hear Serv Sch. 2017 Jan 1;48(1):16–30. doi: 10.1044/2016_LSHSS-16-0014. PMID: 28036410. Exclusion Code: X5.28036410
45 Haley A, Hulme C, Bowyer-Crane C, Oral language skills intervention in preschool-a cautionary tale. Int J Lang Commun Disord. 2017 Jan;52(1):71–9. doi: 10.1111/1460-6984.12257. PMID: 27296626. Exclusion Code: X2.27296626
46 Murphy KA, Justice LM, O'Connell AA, Understanding risk for reading difficulties in children with language impairment. J Speech Lang Hear Res. 2016 Dec 1;59(6):1436–47. doi: 10.1044/2016_JSLHR-L-15-0110. PMID: 27959975. Exclusion Code: X4.27959975
47 Schutte U. Culturally sensitive adaptation of the concept of relational communication therapy as a support to language development: an exploratory study in collaboration with a Tanzanian orphanage. S Afr J Commun Disord. 2016 Nov 7;63(1):e1–e13. doi: 10.4102/sajcd.v63i1.166. PMID: 28155305. Exclusion Code: X2.28155305
48 Bagner DM, Garcia D, Hill R. Direct and indirect effects of behavioral parent training on infant language production. Behav Ther. 2016 Mar;47(2):184–97. doi: 10.1016/j.beth.2015.11.001. PMID: 26956651. Exclusion Code: X2.26956651
49 Oetting JB, McDonald JL, Seidel CM, Sentence recall by children with SLI across two nonmainstream dialects of English. J Speech Lang Hear Res. 2016 Feb;59(1):183–94. doi: 10.1044/2015_JSLHR-L-15-0036. PMID: 26501934. Exclusion Code: X3.26501934
50 Yilmaz D, Bayar-Muluk N, Bayoglu B, Screening 5 and 6 year-old children starting primary school for development and language. Turk J Pediatr. 2016;58(2):136–44. doi: 10.24953/turkjped.2016.02.003. PMID: 27976553. Exclusion Code: X5.27976553
51 Ciccia AH, Roizen N, Garvey M, Identification of neurodevelopmental disabilities in underserved children using telehealth (INvesT): clinical trial study design. Contemp Clin Trials. 2015 Nov;45(Pt B):226–32. doi: 10.1016/j.cct.2015.10.004. PMID: 26475663. Exclusion Code: X6.26475663
52 Rvachew S, Brosseau-Lapre F. A randomized trial of 12-week interventions for the treatment of developmental phonological disorder in Francophone children. Am J Speech Lang Pathol. 2015 Nov;24(4):637–58. doi: 10.1044/2015_AJSLP-14-0056. PMID: 26381229. Exclusion Code: X5.26381229
53 Spencer TD, Petersen DB, Adams JL. Tier 2 language intervention for diverse preschoolers: an early-stage randomized control group study following an analysis of response to intervention. Am J Speech Lang Pathol. 2015 Nov;24(4):619–36. doi: 10.1044/2015_AJSLP-14-0101. PMID: 26125951. Exclusion Code: X2.26125951
54 Pratt AS, Justice LM, Perez A, Impacts of parent-implemented early-literacy intervention for Spanish-speaking children with language impairment. Int J Lang Commun Disord. 2015 Sep-Oct;50(5):569 79. doi: 10.1111/1460-6984.12140. PMID: 26176703. Exclusion Code: X4.26176703
55 Chuthapisith J, Wantanakorn P, Roongpraiwan R. Ramathibodi Language Development Questionnaire: a newly developed screening tool for detection of delayed language development in children aged 18–30 months. J Med Assoc Thai. 2015 Aug;98(8):748–55. PMID: 26437531. Exclusion Code: X3.26437531
56 Wallace IF, Berkman ND, Watson LR, Screening for speech and language delay in children 5 years old and younger: a systematic review. Pediatrics. 2015 Aug;136(2):e448–62. doi: 10.1542/peds.2014-3889. PMID: 26152671. Exclusion Code: X8.26152671
57 de Sonneville-Koedoot C, Stolk E, Rietveld T, Direct versus indirect treatment for preschool children who stutter: the RESTART randomized trial. PLoS One. 2015;10(7):e0133758. doi: 10.1371/journal.pone.0133758. PMID: 26218228. Exclusion Code: X5.26218228
58 Tresoldi M, Ambrogi F, Favero E, Reliability, validity and normative data of a quick repetition test for Italian children. Int J Pediatr Otorhinolaryngol. 2015 Jun;79(6):888–94. doi: 10.1016/j.ijporl.2015.03.025. PMID: 25912630. Exclusion Code: X5.25912630
59 Murray E, McCabe P, Ballard KJ. A randomized controlled trial for children with childhood apraxia of speech comparing rapid syllable transition treatment and the Nuffield Dyspraxia Programme-Third Edition. J Speech Lang Hear Res. 2015 Jun;58(3):669–86. doi: 10.1044/2015_JSLHR-S-13-0179. PMID: 25807891. Exclusion Code: X5.25807891
60 Matta TR, Befi-Lopes DM. Brazilian Portuguese adaptation of Dyslexia Early Screening Test - Second edition: preliminary findings. Codas. 2015 May-Jun;27(3):301–3. doi: 10.1590/2317-1782/20152014191. PMID: 26222949. Exclusion Code: X3.26222949
61 Roberts MY, Kaiser AP. Early intervention for toddlers with language delays: a randomized controlled trial. Pediatrics. 2015 Apr;135(4):686–93. doi: 10.1542/peds.2014-2134. PMID: 25733749. Exclusion Code: X11.25733749
62 Lee AS, Gibbon FE. Non-speech oral motor treatment for children with developmental speech sound disorders. Cochrane Database Syst Rev. 2015 Mar 25;2015(3):CD009383. doi: 10.1002/14651858.CD009383.pub2. PMID: 25805060. Exclusion Code: X8.25805060
63 Lin CS, Chang SH, Cheng SF, The preliminary analysis of the reliability and validity of the Chinese Edition of the CSBS DP. Res Dev Disabil. 2015 Mar;38:309–18. doi: 10.1016/j.ridd.2014.12.023. PMID: 25577181. Exclusion Code: X3.25577181
64 Bosshardt HG, Packman A, Blomgren M, Measuring stuttering in preschool-aged children across different languages: an international study. Folia Phoniatr Logop. 2015;67(5):221–30. doi: 10.1159/000440720. PMID: 26845773. Exclusion Code: X3.26845773
65 Hudson S, Levickis P, Down K, Maternal responsiveness predicts child language at ages 3 and 4 in a community-based sample of slow-to-talk toddlers. Int J Lang Commun Disord. 2015 Jan-Feb;50(1):136–42. doi: 10.1111/1460-6984.12129. PMID: 25208649. Exclusion Code: X3.25208649
66 Pham G, Ebert KD, Kohnert K. Bilingual children with primary language impairment: 3 months after treatment. Int J Lang Commun Disord. 2015 Jan-Feb;50(1):94–105. doi: 10.1111/1460-6984.12123. PMID: 25134887. Exclusion Code: X5.25134887
67 Lindau TA, Rossi NF, Giacheti CM. Cross-cultural adaptation of Preschool Language Assessment Instrument: Second Edition. Codas. 2014 Nov-Dec;26(6):428–33. doi: 10.1590/2317-1782/20142014116. PMID: 25590902. Exclusion Code: X6.25590902
68 Murphy SM, Faulkner DM, Reynolds LR. A randomised controlled trial of a computerised intervention for children with social communication difficulties to support peer collaboration. Res Dev Disabil. 2014 Nov;35(11):2821–39. doi: 10.1016/j.ridd.2014.07.026. PMID: 25104223. Exclusion Code: X2.25104223
69 Arnott S, Onslow M, O'Brian S, Group Lidcombe Program treatment for early stuttering: a randomized controlled trial. J Speech Lang Hear Res. 2014 Oct;57(5):1606–18. doi: 10.1044/2014_JSLHR-S-13-0090. PMID: 24824991. Exclusion Code: X5.24824991
70 Hodge MM, Gotzke CL. Construct-related validity of the TOCS measures: comparison of intelligibility and speaking rate scores in children with and without speech disorders. J Commun Disord. 2014 Sep-Oct;51:51–63. doi: 10.1016/j.jcomdis.2014.06.007. PMID: 25069811. Exclusion Code: X2.25069811
71 Lousada M, Jesus LM, Hall A, Intelligibility as a clinical outcome measure following intervention with children with phonologically based speech-sound disorders. Int J Lang Commun Disord. 2014 Sep-Oct;49(5):584–601. doi: 10.1111/1460-6984.12095. PMID: 24861159. Exclusion Code: X5.24861159
72 Square PA, Namasivayam AK, Bose A, Multi-sensory treatment for children with developmental motor speech disorders. Int J Lang Commun Disord. 2014 Sep-Oct;49(5):527–42. doi: 10.1111/1460-6984.12083. PMID: 24617702. Exclusion Code: X5.24617702
73 Smolik F, Vavru P. Sentence imitation as a marker of SLI in Czech: disproportionate impairment of verbs and clitics. J Speech Lang Hear Res. 2014 Jun 1;57(3):837–49. doi: 10.1044/2014_JSLHR-L-12-0384. PMID: 24763390. Exclusion Code: X3.24763390
74 Ng KY, To CK, McLeod S. Validation of the Intelligibility in Context Scale as a screening tool for preschoolers in Hong Kong. Clin Linguist Phon. 2014 May;28(5):316–28. doi: 10.3109/02699206.2013.865789. PMID: 24456479. Exclusion Code: X2.24456479
75 Lagerberg TB, Asberg J, Hartelius L, Assessment of intelligibility using children's spontaneous speech: methodological aspects. Int J Lang Commun Disord. 2014 Mar-Apr;49(2):228–39. doi: 10.1111/1460-6984.12067. PMID: 24304870. Exclusion Code: X5.24304870
76 Petinou K, Spanoudis G. Early language delay phenotypes and correlation with later linguistic abilities. Folia Phoniatr Logop. 2014;66(1–2):67–76. doi: 10.1159/000365848. PMID: 25472794. Exclusion Code: X6.25472794
77 Torras-Mana M, Guillamon-Valenzuela M, Ramirez-Mallafre A, Usefulness of the Bayley scales of infant and toddler development, third edition, in the early diagnosis of language disorder. Psicothema. 2014;26(3):349–56. doi: 10.7334/psicothema2014.29. PMID: 25069554. Exclusion Code: X3.25069554
78 Munoz J, Carballo G, Fresneda MD, Grammatical comprehension in Spanish-speaking children with specific language impairment (SLI). Span J Psychol. 2014;17:E45. doi: 10.1017/sjp.2014.47. PMID: 25011956. Exclusion Code: X2.25011956
79 Vugs B, Hendriks M, Cuperus J, Working memory performance and executive function behaviors in young children with SLI. Res Dev Disabil. 2014 Jan;35(1):62–74. doi: 10.1016/j.ridd.2013.10.022. PMID: 24240018. Exclusion Code: X4.24240018
80 de Mendonca Filho EJ, Silva MAD, Koziol NA, Validation of the short version of the dimensional inventory for child development assessment. J Pediatr (Rio J). 2021 Nov-Dec;97(6):603–9. doi: 10.1016/j.jped.2021.01.005. PMID: 33639090. Exclusion Code: X5.33639090
81 Smolik F, Bytesnikova I. Validity of the SDDS: a 40-item vocabulary screening tool for 18- to 42-month olds in Czech. J Commun Disord. 2021 Sep-Oct;93:106146. doi: 10.1016/j.jcomdis.2021.106146. PMID: 34399132. Exclusion Code: X5.34399132
82 Castilla-Earls A, Perez-Leroux AT, Fulcher-Rood K, Morphological errors in Spanish-speaking bilingual children with and without developmental language disorders. Lang Speech Hear Serv Sch. 2021 Apr 20;52(2):497–511. doi: 10.1044/2020_LSHSS-20-00017. PMID: 33524269. Exclusion Code: X3.33524269
83 Borovsky A, Thal D, Leonard LB. Moving towards accurate and early prediction of language delay with network science and machine learning approaches. Sci Rep. 2021 Apr 14;11(1):8136. doi: 10.1038/s41598-021-85982-0. PMID: 33854086. Exclusion Code: X3.33854086
84 Visser-Bochane M, Luinge M, Dieleman L, The Dutch well child language screening protocol for 2-year-old children was valid for detecting current and later language problems. Acta Paediatr. 2021 Feb;110(2):556–62. doi: 10.1111/apa.15447. PMID: 32585043. Exclusion Code: X11.32585043
85 Leon M, Washington KN, Fritz KA, Intelligibility in Context Scale: sensitivity and specificity in the Jamaican context. Clin Linguist Phon. 2021 Feb 1;35(2):154–71. doi: 10.1080/02699206.2020.1766574. PMID: 32462946. Exclusion Code: X5.32462946
86 Wallis KE, Davis Rivera LB, Guthrie W, Provider responses to positive developmental screening: disparities in referral practices? J Dev Behav Pediatr. 2021 Jan 1;42(1):23–31. doi: 10.1097/DBP.0000000000000855. PMID: 32909974. Exclusion Code: X6.32909974
87 Faruk T, King C, Muhit M, Screening tools for early identification of children with developmental delay in low- and middle-income countries: a systematic review. BMJ Open. 2020 Nov 23;10(11):e038182. doi: 10.1136/bmjopen-2020-038182. PMID: 33234622. Exclusion Code: X8.33234622
88 Bravo N, Lazaro M, Mariscal S. A sentence repetition task for early language assessment in Spanish. Span J Psychol. 2020 Oct 15;23:e39. doi: 10.1017/SJP.2020.43. PMID: 33054889. Exclusion Code: X3.33054889
89 Winters KL, Byrd CT. Pediatrician referral practices for children who stutter. Am J Speech Lang Pathol. 2020 Aug 4;29(3):1404–22. doi: 10.1044/2020_AJSLP-19-00058. PMID: 32464074. Exclusion Code: X3.32464074
90 Puglisi ML, Blasi HF, Snowling MJ. Screening for the identification of oral language difficulties in Brazilian preschoolers: a validation study. Lang Speech Hear Serv Sch. 2020 Jul 15;51(3):852–65. doi: 10.1044/2020_LSHSS-19-00083. PMID: 32496867. Exclusion Code: X2.32496867
91 Sharma G, Prasad D, Umapathy K, Screening and analysis of specific language impairment in young children by analyzing the textures of speech signal. Annu Int Conf IEEE Eng Med Biol Soc. 2020 Jul;2020:964–7. doi: 10.1109/EMBC44109.2020.9176056. PMID: 33018145. Exclusion Code: X5.33018145
92 Wiefferink K, van Beugen C, Wegener Sleeswijk B, Children with language delay referred to Dutch speech and hearing centres: caseload characteristics. Int J Lang Commun Disord. 2020 Jul;55(4):573–82. doi: 10.1111/1460-6984.12540. PMID: 32459389. Exclusion Code: X4.32459389
93 Dias DC, Rondon-Melo S, Molini-Avejonas DR. Sensitivity and specificity of a low-cost screening protocol for identifying children at risk for language disorders. Clinics (Sao Paulo). 2020;75:e1426. doi: 10.6061/clinics/2020/e1426. PMID: 32294668. Exclusion Code: X9.32294668
94 Oryadi-Zanjani MM. Development of the Childhood Nonverbal Communication Scale. J Autism Dev Disord. 2020 Apr;50(4):1238–48. doi: 10.1007/s10803-019-04356-8. PMID: 31902055. Exclusion Code: X3.31902055
95 Sugden E, Baker E, Williams AL, Evaluation of parent- and speech-language pathologist-delivered multiple oppositions intervention for children with phonological impairment: a multiple-baseline design study. Am J Speech Lang Pathol. 2020 Feb 7;29(1):111–26. doi: 10.1044/2019_AJSLP-18-0248. PMID: 31765232. Exclusion Code: X8.31765232
96 Gibson TA. The influence of native- versus foreign-accented speech on Spanish-English bilingual children's Spanish receptive vocabulary performance: a pilot study. Lang Speech Hear Serv Sch. 2019 Oct 10;50(4):710–6. doi: 10.1044/2019_LSHSS-18-0136. PMID: 31437099. Exclusion Code: X5.31437099
97 Eisenberg S, Victorino K, Murray S. Concurrent validity of the Fluharty Preschool Speech and Language Screening Test-Second Edition at age 3: comparison with four diagnostic measures. Lang Speech Hear Serv Sch. 2019 Oct 10;50(4):673–82. doi: 10.1044/2019_LSHSS-18-0099. PMID: 31419169. Exclusion Code: X5.31419169
98 Hall-Mills S. A Comparison of the prevalence rates of language impairment before and after response-to-intervention implementation. Lang Speech Hear Serv Sch. 2019 Oct 10;50(4):703–9. doi: 10.1044/2019_LSHSS-18-0144. PMID: 31340133. Exclusion Code: X5.31340133
99 Gerdes M, Garcia-Espana JF, Webb D, Psychometric properties of two developmental screening instruments for Hispanic children in the Philadelphia region. Acad Pediatr. 2019 Aug;19(6):638–45. doi: 10.1016/j.acap.2018.10.002. PMID: 30315947. Exclusion Code: X6.30315947
100 Lee Y. Validation of the Intelligibility in Context Scale for Korean-speaking preschool children. Int J Speech Lang Pathol. 2019 Aug;21(4):395–403. doi: 10.1080/17549507.2018.1485740. PMID: 30246562. Exclusion Code: X2.30246562
101 Pavelko SL, Owens RE Jr. Diagnostic accuracy of the Sampling Utterances and Grammatical Analysis Revised (SUGAR) measures for identifying children with language impairment. Lang Speech Hear Serv Sch. 2019 Apr 23;50(2):211–23. doi: 10.1044/2018_LSHSS-18-0050. PMID: 31017859. Exclusion Code: X3.31017859
102 McManus BM, Richardson Z, Schenkman M, Timing and intensity of early intervention service use and outcomes among a safety-net population of children. JAMA Netw Open. 2019 Jan 4;2(1):e187529. doi: 10.1001/jamanetworkopen.2018.7529. PMID: 30681716. Exclusion Code: X3.30681716
103 Acosta V, Hernandez S, Ramirez G. Effectiveness of a working memory intervention program in children with language disorders. Appl Neuropsychol Child. 2019 Jan-Mar;8(1):15–23. doi: 10.1080/21622965.2017.1374866. PMID: 28956632. Exclusion Code: X2.28956632
104 Henderson DE, Restrepo MA, Aiken LS. Dynamic assessment of narratives among Navajo preschoolers. J Speech Lang Hear Res. 2018 Oct 26;61(10):2547–60. doi: 10.1044/2018_JSLHR-L-17-0313. PMID: 30304364. Exclusion Code: X5.30304364
105 Tuller L, Hamann C, Chilla S, Identifying language impairment in bilingual children in France and in Germany. Int J Lang Commun Disord. 2018 Jul;53(4):888–904. doi: 10.1111/1460-6984.12397. PMID: 29790243. Exclusion Code: X2.29790243
106 Matov J, Mensah F, Cook F, Investigation of the language tasks to include in a short-language measure for children in the early school years. Int J Lang Commun Disord. 2018 Jul;53(4):735–47. doi: 10.1111/1460-6984.12378. PMID: 29457324. Exclusion Code: X3.29457324
107 Gibson TA, Pena ED, Bedore LM. The receptive-expressive gap in English narratives of Spanish-English bilingual children with and without language impairment. J Speech Lang Hear Res. 2018 Jun 19;61(6):1381–92. doi: 10.1044/2018_JSLHR-L-16-0432. PMID: 29800961. Exclusion Code: X5.29800961
108 Shimada M, Toyomura A, Fujii T, Children who stutter at 3 years of age: a community-based study. J Fluency Disord. 2018 Jun;56:45–54. doi: 10.1016/j.jfludis.2018.02.002. PMID: 29602051. Exclusion Code: X5.29602051
109 Eisenberg SL, Guo LY, Mucchetti E. Eliciting the language sample for developmental sentence scoring: a comparison of play with toys and elicited picture description. Am J Speech Lang Pathol. 2018 May 3;27(2):633–46. doi: 10.1044/2017_AJSLP-16-0161. PMID: 29392298. Exclusion Code: X3.29392298
110 Lavesson A, Lovden M, Hansson K. Development of a language screening instrument for Swedish 4-year-olds. Int J Lang Commun Disord. 2018 May;53(3):605–14. doi: 10.1111/1460-6984.12374. PMID: 29411470. Exclusion Code: X3.29411470
111 Gregory KD, Oetting JB. Classification accuracy of teacher ratings when screening nonmainstream English-speaking kindergartners for language impairment in the rural South. Lang Speech Hear Serv Sch. 2018 Apr 5;49(2):218–31. doi: 10.1044/2017_LSHSS-17-0045. PMID: 29621802. Exclusion Code: X5.29621802
112 Barragan B, Castilla-Earls A, Martinez-Nieto L, Performance of low-income dual language learners attending English-only schools on the Clinical Evaluation of Language Fundamentals-Fourth Edition, Spanish. Lang Speech Hear Serv Sch. 2018 Apr 5;49(2):292–305. doi: 10.1044/2017_LSHSS-17-0013. PMID: 29330555. Exclusion Code: X2.29330555
113 Bello A, Onofrio D, Remi L, Prediction and persistence of late talking: a study of Italian toddlers at 29 and 34 months. Res Dev Disabil. 2018 Apr;75:40–8. doi: 10.1016/j.ridd.2018.02.006. PMID: 29482035. Exclusion Code: X6.29482035
114 Castilla-Earls A, Fulcher-Rood K. Convergent and divergent validity of the Grammaticality and Utterance Length Instrument. J Speech Lang Hear Res. 2018 Jan 22;61(1):120–9. doi: 10.1044/2017_JSLHR-L-17-0152. PMID: 29346497. Exclusion Code: X3.29346497
115 Uilenburg N, Wiefferink K, Verkerk P, Accuracy of a screening tool for early identification of language impairment. J Speech Lang Hear Res. 2018 Jan 22;61(1):104–13. doi: 10.1044/2017_JSLHR-L-16-0173. PMID: 29330554. Exclusion Code: X5.29330554
116 Anaya JB, Pena ED, Bedore LM. Conceptual scoring and classification accuracy of vocabulary testing in Bilingual children. Lang Speech Hear Serv Sch. 2018 Jan 9;49(1):85–97. doi: 10.1044/2017_LSHSS-16-0081. PMID: 29209728. Exclusion Code: X2.29209728
117 Ortega AN, McKenna RM, Langellier BA, Experiences in care according to parental citizenship and language use among Latino children in California. Acad Pediatr. 2018 Jan-Feb;18(1):20–5. doi: 10.1016/j.acap.2016.12.017. PMID: 28065799. Exclusion Code: X6.28065799
118 Rujas I, Mariscal S, Casla M, Word and nonword repetition abilities in Spanish language: longitudinal evidence from typically developing and late talking children. Span J Psychol. 2017 Dec 4;20:E72. doi: 10.1017/sjp.2017.69. PMID: 29198216. Exclusion Code: X4.29198216
119 Saraiva D, Lousada M, Hall A, Paediatric Automatic Phonological Analysis Tools (APAT). Logoped Phoniatr Vocol. 2017 Dec;42(4):153–9. doi: 10.1080/14015439.2016.1237544. PMID: 27724177. Exclusion Code: X3.27724177
120 Kapantzoglou M, Fergadiotis G, Restrepo MA. Language sample analysis and elicitation technique effects in bilingual children with and without language impairment. J Speech Lang Hear Res. 2017 Oct 17;60(10):2852–64. doi: 10.1044/2017_JSLHR-L-16-0335. PMID: 28915297. Exclusion Code: X3.28915297
121 Brownlie EB, Graham E, Bao L, Language disorder and retrospectively reported sexual abuse of girls: severity and disclosure. J Child Psychol Psychiatry. 2017 Oct;58(10):1114–21. doi: 10.1111/jcpp.12723. PMID: 28407233. Exclusion Code: X2.28407233
122 Goh SK Y, Tham EK H, Magiati I, Analysis of item-level bias in the Bayley-III Language Subscales: the validity and utility of standardized language assessment in a multilingual setting. J Speech Lang Hear Res. 2017 Sep 18;60(9):2663–71. doi: 10.1044/2017_JSLHR-L-16-0196. PMID: 28813555. Exclusion Code: X8.28813555
123 Hidecker MJ, Cunningham BJ, Thomas-Stonell N, Validity of the Communication Function Classification System for use with preschool children with communication disorders. Dev Med Child Neurol. 2017 May;59(5):526–30. doi: 10.1111/dmcn.13373. PMID: 28084630. Exclusion Code: X6.28084630
124 Shriberg LD, Strand EA, Fourakis M, A diagnostic marker to discriminate childhood apraxia of speech from speech delay: II. validity studies of the Pause Marker. J Speech Lang Hear Res. 2017 Apr 14;60(4):S1118–S34. doi: 10.1044/2016_JSLHR-S-15-0297. PMID: 28384803. Exclusion Code: X2.28384803
125 Cheng HK, Chang HT, Huang PH, The design and validation of a child developmental e-screening system. J Med Syst. 2017 Apr;41(4):67. doi: 10.1007/s10916-017-0701-z. PMID: 28283996. Exclusion Code: X5.28283996
126 Wachtlin B, Brachmaier J, Amann E, Development and evaluation of the LittlEARS((R)) Early Speech Production Questionnaire - LEESPQ. Int J Pediatr Otorhinolaryngol. 2017 Mar;94:23–9. doi: 10.1016/j.ijporl.2017.01.007. PMID: 28167006. Exclusion Code: X3.28167006
127 Schmitt MB, Justice LM, Logan JA. Intensity of language treatment: contribution to children's language outcomes. Int J Lang Commun Disord. 2017 Mar;52(2):155–67. doi: 10.1111/1460-6984.12254. PMID: 27377764. Exclusion Code: X5.27377764
128 McIntyre LL, Pelham WE, 3rd, Kim MH, A brief measure of language skills at 3 years of age and special education use in middle childhood. J Pediatr. 2017 Feb;181:189–94. doi: 10.1016/j.jpeds.2016.10.035. PMID: 27908645. Exclusion Code: X5.27908645
129 Fabus R, Berg AL, Serpanos YC, The effectiveness of parental questionnaires in the assessment of speech-language and auditory function in children. Folia Phoniatr Logop. 2017;69(5–6):261–70. doi: 10.1159/000488054. PMID: 29734179. Exclusion Code: X3.29734179
130 Maleka BK, Van Der Linde J, Glascoe FP, Developmental screening-evaluation of an m-Health version of the Parents Evaluation Developmental Status Tools. Telemed J E Health. 2016 Dec;22(12):1013–8. doi: 10.1089/tmj.2016.0007. PMID: 27286191. Exclusion Code: X2.27286191
131 Chunsuwan I, Hansakunachai T, Pornsamrit S. Parent Evaluation of Developmental Status (PEDS) in screening: the Thai experience. Pediatr Int. 2016 Dec;58(12):1277–83. doi: 10.1111/ped.13055. PMID: 27285278. Exclusion Code: X5.27285278
132 Huntington N, Horan K, Epee-Bounya A, Developmental screening with Spanish-speaking families in a primary care setting. Clin Pediatr (Phila). 2016 Apr;55(4):347–55. doi: 10.1177/0009922815591884. PMID: 26116349. Exclusion Code: X6.26116349
133 Nair MK, Harikumaran GS, George B, Language Evaluation Scale Trivandrum (LEST 3–6 years) development and validation. Indian Pediatr. 2016 Mar;53(3):257–8. PMID: 27029695. Exclusion Code: X9.27029695
134 Pena ED, Bedore LM, Kester ES. Assessment of language impairment in bilingual children using semantic tasks: two languages classify better than one. Int J Lang Commun Disord. 2016 Mar;51(2):192–202. doi: 10.1111/1460-6984.12199. PMID: 26541642. Exclusion Code: X2.26541642
135 Lousada M, Ramalho M, Marques C. Effectiveness of the Language Intervention Programme for Preschool Children. Folia Phoniatr Logop. 2016;68(2):80–5. doi: 10.1159/000448684. PMID: 27684522. Exclusion Code: X8.27684522
136 Duenser A, Ward L, Stefani A, Feasibility of technology enabled speech disorder screening. Stud Health Technol Inform. 2016;227:21–7. PMID: 27440284. Exclusion Code: X3.27440284
137 Theodorou E, Kambanaros M, Grohmann KK. Diagnosing bilectal children with SLI: determination of identification accuracy. Clin Linguist Phon. 2016;30(12):925–43. doi: 10.1080/02699206.2016.1182591. PMID: 27315368. Exclusion Code: X3.27315368
138 Boerma T, Chiat S, Leseman P, A quasi-universal nonword repetition task as a diagnostic tool for bilingual children learning Dutch as a second language. J Speech Lang Hear Res. 2015 Dec;58(6):1747–60. doi: 10.1044/2015_JSLHR-L-15-0058. PMID: 26444988. Exclusion Code: X3.26444988
139 Sim F, Haig C, O'Dowd J, Development of a triage tool for neurodevelopmental risk in children aged 30 months. Res Dev Disabil. 2015 Oct-Nov;45–46:69–82. doi: 10.1016/j.ridd.2015.07.017. PMID: 26226112. Exclusion Code: X8.26226112
140 Gudmundsson E. The Toddler Language and Motor Questionnaire: a mother-report measure of language and motor development. Res Dev Disabil. 2015 Oct-Nov;45–46:21–31. doi: 10.1016/j.ridd.2015.07.007. PMID: 26209772. Exclusion Code: X6.26209772
141 Guiberson M, Rodriguez BL, Zajacova A. Accuracy of telehealth-administered measures to screen language in Spanish-speaking preschoolers. Telemed J E Health. 2015 Sep;21(9):714–20. doi: 10.1089/tmj.2014.0190. PMID: 25942401. Exclusion Code: X2.25942401
142 Lugo-Neris MJ, Pena ED, Bedore LM, Utility of a language screening measure for predicting risk for language impairment in Bilinguals. Am J Speech Lang Pathol. 2015 Aug;24(3):426–37. doi: 10.1044/2015_AJSLP-14-0061. PMID: 25885932. Exclusion Code: X2.25885932
143 McLeod S, Crowe K, Shahaeian A. Intelligibility in Context Scale: normative and validation data for English-speaking preschoolers. Lang Speech Hear Serv Sch. 2015 Jul;46(3):266–76. doi: 10.1044/2015_LSHSS-14-0120. PMID: 25934948. Exclusion Code: X6.25934948
144 Rajchanovska D, Ivanovska BZ. The impact of demographic and socio-economic conditions on the prevalence of speech disorders in preschool children in Bitola. Srp Arh Celok Lek. 2015 Mar-Apr;143(3–4):169–73. doi: 10.2298/sarh1504169r. PMID: 26012126. Exclusion Code: X3.26012126
145 Steenis LJ, Verhoeven M, Hessen DJ, Parental and professional assessment of early child development: the ASQ-3 and the Bayley-III-NL. Early Hum Dev. 2015 Mar;91(3):217–25. doi: 10.1016/j.earlhumdev.2015.01.008. PMID: 25703316. Exclusion Code: X5.25703316
146 Merritt DH, Klein S. Do early care and education services improve language development for maltreated children? evidence from a national child welfare sample. Child Abuse Negl. 2015 Jan;39:185–96. doi: 10.1016/j.chiabu.2014.10.011. PMID: 25459989. Exclusion Code: X2.25459989
147 Hwang AW, Chou YT, Hsieh CL, A developmental screening tool for toddlers with multiple domains based on Rasch analysis. J Formos Med Assoc. 2015 Jan;114(1):23–34. doi: 10.1016/j.jfma.2014.07.001. PMID: 25127503. Exclusion Code: X2.25127503
148 Lukowski AF, Phung JN, Milojevich HM. Language facilitates event memory in early childhood: child comprehension, adult-provided linguistic support and delayed recall at 16 months. Memory. 2015;23(6):848–63. doi: 10.1080/09658211.2014.931436. PMID: 24999740. Exclusion Code: X4.24999740
149 Nair MK, Harikumaran Nair GS, Beena M, CDC Kerala 16: early detection of developmental delay/disability among children below 6 y--a district model. Indian J Pediatr. 2014 Dec;81 Suppl 2:S151–5. doi: 10.1007/s12098-014-1589-y. PMID: 25297644. Exclusion Code: X5.25297644
150 Beitchman JH, Brownlie EB, Bao L. Age 31 mental health outcomes of childhood language and speech disorders. J Am Acad Child Adolesc Psychiatry. 2014 Oct;53(10):1102–10 e8. doi: 10.1016/j.jaac.2014.07.006. PMID: 25245354. Exclusion Code: X4.25245354
151 Souto SM, Leonard LB, Deevy P. Identifying risk for specific language impairment with narrow and global measures of grammar. Clin Linguist Phon. 2014 Oct;28(10):741–56. doi: 10.3109/02699206.2014.893372. PMID: 24641713. Exclusion Code: X3.24641713
152 MacLeod AA, Glaspey AM. A multidimensional view of gradient change in velar acquisition in three-year-olds receiving phonological treatment. Clin Linguist Phon. 2014 Sep;28(9):664–81. doi: 10.3109/02699206.2013.878855. PMID: 24588471. Exclusion Code: X5.24588471
153 Chinta S, Walker K, Halliday R, A comparison of the performance of healthy Australian 3-year-olds with the standardised norms of the Bayley Scales of Infant and Toddler Development (version-III). Arch Dis Child. 2014 Jul;99(7):621–4. doi: 10.1136/archdischild-2013-304834. PMID: 24504506. Exclusion Code: X5.24504506
154 Iyer SN, Sawyer MI, Germany M, Development of a 5-item parent questionnaire to screen preschool children for reading problems. Clin Pediatr (Phila). 2014 Jun;53(6):571–8. doi: 10.1177/0009922814521285. PMID: 24480812. Exclusion Code: X3.24480812
155 Martin Ruiz ML, Valero Duboy MA, Torcal Loriente C, Evaluating a web-based clinical decision support system for language disorders screening in a nursery school. J Med Internet Res. 2014 May 28;16(5):e139. doi: 10.2196/jmir.3263. PMID: 24870413. Exclusion Code: X3.24870413
156 Guo LY, Eisenberg S. The diagnostic accuracy of two tense measures for identifying 3-year-olds with language impairment. Am J Speech Lang Pathol. 2014 May;23(2):203–12. doi: 10.1044/2013_AJSLP-13-0007. PMID: 24105474. Exclusion Code: X3.24105474
157 Pearson BZ, Jackson JE, Wu H. Seeking a valid gold standard for an innovative, dialect-neutral language test. J Speech Lang Hear Res. 2014 Apr 1;57(2):495–508. doi: 10.1044/2013_JSLHR-L-12-0126. PMID: 24133298. Exclusion Code: X2.24133298
158 Eadie P, Nguyen C, Carlin J, Stability of language performance at 4 and 5 years: measurement and participant variability. Int J Lang Commun Disord. 2014 Mar-Apr;49(2):215–27. doi: 10.1111/1460-6984.12065. PMID: 24741700. Exclusion Code: X5.24741700
159 Guiberson M, Rodriguez BL. Rasch analysis of a Spanish language-screening parent survey. Res Dev Disabil. 2014 Mar;35(3):646–56. doi: 10.1016/j.ridd.2013.12.011. PMID: 24456858. Exclusion Code: X6.24456858
160 Mendes A, Lousada M, Valente AR, Validity and reliability of the European-Portuguese preschool language assessment ALPE. Folia Phoniatr Logop. 2014;66(3):89–94. doi: 10.1159/000365354. PMID: 25341699. Exclusion Code: X3.25341699
161 Lobo MA, Paul DA, Mackley A, Instability of delay classification and determination of early intervention eligibility in the first two years of life. Res Dev Disabil. 2014 Jan;35(1):117–26. doi: 10.1016/j.ridd.2013.10.017. PMID: 24176257. Exclusion Code: X5.24176257
162 Ortiz JA. Using nonword repetition to identify language impairment in bilingual children: a meta-analysis of diagnostic accuracy. Am J Speech Lang Pathol. 2021 Sep 23;30(5):2275–95. doi: 10.1044/2021_AJSLP-20-00237. PMID: 34269597. Exclusion Code: X8.34269597
163 Schwob S, Edde L, Jacquin L, Using nonword repetition to identify developmental language disorder in monolingual and bilingual children: a systematic review and meta-analysis. J Speech Lang Hear Res. 2021 Sep 14;64(9):3578–93. doi: 10.1044/2021_JSLHR-20-00552. PMID: 34407377. Exclusion Code: X8.34407377
164 Sansavini A, Favilla ME, Guasti MT, Developmental language disorder: early predictors, age for the diagnosis, and diagnostic tools. a scoping review. Brain Sci. 2021 May 17;11(5)doi: 10.3390/brainsci11050654. PMID: 34067874. Exclusion Code: X8.34067874
165 Sim F, Thompson L, Marryat L, Predictive validity of preschool screening tools for language and behavioural difficulties: a PRISMA systematic review. PLoS One. 2019;14(2):e0211409. doi: 10.1371/journal.pone.0211409. PMID: 30716083. Exclusion Code: X8.30716083
166 McKechnie J, Ahmed B, Gutierrez-Osuna R, Automated speech analysis tools for children's speech production: a systematic literature review. Int J Speech Lang Pathol. 2018 Nov;20(6):583–98. doi: 10.1080/17549507.2018.1477991. PMID: 29996691. Exclusion Code: X8.29996691
167 Shahmahmood TM, Jalaie S, Soleymani Z, A systematic review on diagnostic procedures for specific language impairment: the sensitivity and specificity issues. J Res Med Sci. 2016;21:67. doi: 10.4103/1735-1995.189648. PMID: 27904612. Exclusion Code: X8.27904612
168 O'Brian S, Smith K, Onslow M. Webcam delivery of the Lidcombe program for early stuttering: a phase I clinical trial. J Speech Lang Hear Res. 2014 Jun 1;57(3):825–30. doi: 10.1044/2014_JSLHR-S-13-0094. PMID: 24686834. Exclusion Code: X5.24686834
169 Bowe AK, Hourihane J, Staines A, The predictive value of the ages and stages questionnaire in late infancy for low average cognitive ability at age 5. Acta Paediatr. 2022 Jun;111(6):1194–200. doi: 10.1111/apa.16309. PMID: 35202483. Exclusion Code: X5.35202483
170 Vaezghasemi M, Eurenius E, Ivarsson A, The Ages and Stages Questionnaire: Social-Emotional-what is the optimal cut-off for 3-year-olds in the Swedish setting? Front Pediatr. 2022;10:756239. doi: 10.3389/fped.2022.756239. PMID: 35223687. Exclusion Code: X5.35223687
171 Schwob S, Skoruppa K. Detecting developmental language disorder in monolingual and bilingual children: comparison of language-specific and crosslinguistic nonword repetition tasks in French and Portuguese. J Speech Lang Hear Res. 2022 Mar 8;65(3):1159–65. doi: 10.1044/2021_JSLHR-21-00017. PMID: 35130088. Exclusion Code: X3.35130088
172 Qian L, Shao H, Fang H, Reliability, validity and developmental sensitivity of the Language Use Inventory (LUI) in the Chinese context. Int J Lang Commun Disord. 2022 May;57(3):497–511. doi: 10.1111/1460-6984.12693. PMID: 34984773. Exclusion Code: X6.34984773
173 Scherger AL. The role of age and timing in bilingual assessment: non-word repetition, subject-verb agreement and case marking in L1 and eL2 children with and without SLI. Clin Linguist Phon. 2022 Jan 2;36(1):54–74. doi: 10.1080/02699206.2021.1885497. PMID: 33622095. Exclusion Code: X2.33622095
174 Clausen MC, Fox-Boyer AV. Diagnostic validity, accuracy and inter-rater reliability of a phonological assessment for Danish-speaking children. J Commun Disord. 2022 Jan-Feb;95:106168. doi: 10.1016/j.jcomdis.2021.106168. PMID: 34864604. Exclusion Code: X3.34864604
175 Hashemi Hosseinabad H, Washington KN, Boyce SE, Assessment of intelligibility in children with velopharyngeal insufficiency: the relationship between intelligibility in context scale and experimental measures. Folia Phoniatr Logop. 2022;74(1):17–28. doi: 10.1159/000516537. PMID: 34107483. Exclusion Code: X2.34107483
176 Yun JH, Shin SM, Son SM. Clinical utility of repeated Urimal Test of Articulation and Phonation for patients with childhood apraxia of speech. Children (Basel). 2021 Dec 1;8(12)doi: 10.3390/children8121106. PMID: 34943301. Exclusion Code: X3.34943301
177 Garibaldi A, Venkatesh L, Bhat JS, Relationship between parental report of language skills and children's performance among 3-year-olds: implications for screening language among preschoolers. Int J Pediatr Otorhinolaryngol. 2021 Dec;151:110943. doi: 10.1016/j.ijporl.2021.110943. PMID: 34700297. Exclusion Code: X9.34700297
178 Simpson S, Eadie T, Khoo ST, The ASQ-TRAK: validating a culturally adapted developmental screening tool for Australian Aboriginal children. Early Hum Dev. 2021 Dec;163:105481. doi: 10.1016/j.earlhumdev.2021.105481. PMID: 34678586. Exclusion Code: X2.34678586
179 Altman C, Harel E, Meir N, Using a monolingual screening test for assessing bilingual children. Clin Linguist Phon. 2022 Dec 2;36(12):1132–52. doi: 10.1080/02699206.2021.2000644. PMID: 34844504. Exclusion Code: X3.34844504
180 Gatlin-Nash B, Pena ED, Bedore LM, English BESA morphosyntax performance among Spanish-English bilinguals who use African American English. J Speech Lang Hear Res. 2021 Oct 4;64(10):3826–42. doi: 10.1044/2021_JSLHR-20-00737. PMID: 34520218. Exclusion Code: X3.34520218
181 Colbert AM, Connery AK, Lamb MM, Caregiver rating of early childhood development: reliability and validity of the ASQ-3 in rural Guatemala. Early Hum Dev. 2021 Oct;161:105453. doi: 10.1016/j.earlhumdev.2021.105453. PMID: 34530320. Exclusion Code: X6.34530320
182 Jullien S. Screening for language and speech delay in children under five years. BMC Pediatr. 2021 Sep 8;21(Suppl 1):362. doi: 10.1186/s12887-021-02817-7. PMID: 34496812. Exclusion Code: X8.34496812
183 Celen Yoldas T, Karakaya J, Ozdemir G, Comparison of the parents' evaluation of Developmental Status and Ages and Stages Questionnaire developmental screening tests in a Eurasian country. J Dev Behav Pediatr. 2021 Aug 1;42(6):450–6. doi: 10.1097/DBP.0000000000000912. PMID: 33507044. Exclusion Code: X6.33507044
184 Gale R, Bird J, Wang Y, Automated scoring of tablet-administered expressive language tests. Front Psychol. 2021;12:668401. doi: 10.3389/fpsyg.2021.668401. PMID: 34366987. Exclusion Code: X2.34366987
185 Crocetti P, Fancelli S, Colpizzi I, T-PEC: a novel test for the elicited production of clitic pronouns in Italian. preliminary data. Clin Linguist Phon. 2021 Jul 3;35(7):636–62. doi: 10.1080/02699206.2020.1818129. PMID: 33021120. Exclusion Code: X3.33021120
186 Arbel Y, Fitzpatrick I, He X. Learning with and without feedback in children with developmental language disorder. J Speech Lang Hear Res. 2021 May 11;64(5):1696–711. doi: 10.1044/2021_JSLHR-20-00499. PMID: 33877883. Exclusion Code: X2.33877883
187 Faldt A, Fabian H, Dahlberg A, Infant-Toddler Checklist identifies 18-month-old children with communication difficulties in the Swedish child healthcare setting. Acta Paediatr. 2021 May;110(5):1505–12. doi: 10.1111/apa.15696. PMID: 33251672. Exclusion Code: X11.33251672
188 Kehoe M, Niederberger N, Bouchut AL. The development of a speech sound screening test for European French-speaking monolingual and bilingual children. Int J Speech Lang Pathol. 2021 Apr;23(2):135–44. doi: 10.1080/17549507.2020.1750699. PMID: 32619363. Exclusion Code: X6.32619363
189 Oetting JB, Riviere AM, Berry JR, Marking of tense and agreement in language samples by children with and without specific language impairment in African American English and Southern White English: evaluation of scoring approaches and cut scores across structures. J Speech Lang Hear Res. 2021 Feb 17;64(2):491–509. doi: 10.1044/2020_JSLHR-20-00243. PMID: 33472006. Exclusion Code: X6.33472006
190 Kan PF, Miller A, Still S. Identifying bilingual children at risk for language impairment: the implication of children's response speed in narrative contexts. Children (Basel). 2021 Jan 20;8(2)doi: 10.3390/children8020062. PMID: 33498365. Exclusion Code: X3.33498365
191 Piazzalunga S, Salerni N, Limarzi S, Can you understand your child? reliability and validity of a parent questionnaire: the intelligibility in context scale: Italian. Folia Phoniatr Logop. 2021;73(4):265–76. doi: 10.1159/000506475. PMID: 32172245. Exclusion Code: X5.32172245
192 Wang L, Shen M, Liang W, Validation of the Mandarin versions of CAP and SIR. Int J Pediatr Otorhinolaryngol. 2020 Dec;139:110413. doi: 10.1016/j.ijporl.2020.110413. PMID: 33027731. Exclusion Code: X3.33027731
193 Johansen K, Jeyaseelan D, Chan YP, Acceptability of the culturally adapted ASQ-TRAK developmental screening tool to caregivers of Aboriginal children. J Paediatr Child Health. 2020 Dec;56(12):1946–51. doi: 10.1111/jpc.15099. PMID: 32815624. Exclusion Code: X6.32815624
194 Pinheiro L, Silva APD, Hage SR V. Morphosyntactic Evaluation Protocol (MEP): validation of content. Codas. 2020;32(6):e20190148. doi: 10.1590/2317-1782/20202019148. PMID: 33237188. Exclusion Code: X8.33237188
195 Chung HJ, Yang D, Kim GH, Development of the Korean Developmental Screening Test for Infants and Children (KDST). Clin Exp Pediatr. 2020 Nov;63(11):438–46. doi: 10.3345/cep.2020.00640. PMID: 32683817. Exclusion Code: X3.32683817
196 Leonard LB, Deevy P. Retrieval practice and word learning in children with specific language impairment and their typically developing peers. J Speech Lang Hear Res. 2020 Oct 16;63(10):3252–62. doi: 10.1044/2020_JSLHR-20-00006. PMID: 33064601. Exclusion Code: X4.33064601
197 Doh JH, Kim SA, Oh K, The predictive value of language scales: Bayley Scales of Infant and Toddler Development Third Edition in correlation with Korean Sequenced Language Scale for Infant. Ann Rehabil Med. 2020 Oct;44(5):378–85. doi: 10.5535/arm.19198. PMID: 32986945. Exclusion Code: X3.32986945
198 Agaiwal PK, Xie H, Sathyapalan Rema AS, Evaluation of the Ages and Stages Questionnaire (ASQ 3) as a developmental screener at 9, 18, and 24 months. Early Hum Dev. 2020 Aug;147:105081. doi: 10.1016/j.earlhumdev.2020.105081. PMID: 32502946. Exclusion Code: X5.32502946
199 Bonifacci P, Atti E, Casamenti M, Which measures better discriminate language minority bilingual children with and without developmental language disorder? a study testing a combined protocol of first and second language assessment. J Speech Lang Hear Res. 2020 Jun 22;63(6): 1898–915. doi: 10.1044/2020_JSLHR-19-00100. PMID: 32516561. Exclusion Code: X2.32516561
200 Zhang X, Qin F, Chen Z, Fast screening for children's developmental language disorders via comprehensive speech ability evaluation-using a novel deep learning framework. Ann Transl Med. 2020 Jun;8(11):707. doi: 10.21037/atm-19-3097. PMID: 32617327. Exclusion Code: X8.32617327
201 Anis L, Letourneau N, Benzies K, Effect of the attachment and child health parent training program on parent-child interaction quality and child development. Can JNurs Res. 2020 Jun;52(2): 157–68. doi: 10.1177/0844562119899004. PMID: 32000509. Exclusion Code: X2.32000509
202 Jasso J, McMillen S, Anaya JB, The utility of an English semantics measure for identifying developmental language disorder in Spanish-English bilinguals. Am J Speech Lang Pathol. 2020 May 8;29(2):776–88. doi: 10.1044/2020_AJSLP-19-00202. PMID: 32315199. Exclusion Code: X3.32315199
203 Bedore LM, Pena ED, Fiestas C, Language and literacy together: supporting grammatical development in dual language learners with risk for language and learning difficulties. Lang Speech Hear Serv Sch. 2020 Apr 7;51(2):282–97. doi: 10.1044/2020_LSHSS-19-00055. PMID: 32255748. Exclusion Code: X5.32255748
204 Farquharson K, Tambyraja SR, Justice LM. Contributions to gain in speech sound production accuracy for children with speech sound disorders: exploring child and therapy factors. Lang Speech Hear Serv Sch. 2020 Apr 7;51(2):457–68. doi: 10.1044/2019_LSHSS-19-00079. PMID: 32160111. Exclusion Code: X5.32160111
205 Lipkin PH, Macias MM, Baer Chen B, Trends in pediatricians' developmental screening: 2002–2016. Pediatrics. 2020 Apr;145(4)doi: 10.1542/peds.2019-0851. PMID: 32123018. Exclusion Code: X2.32123018
206 Ebert KD, Ochoa-Lubinoff C, Holmes MP. Screening school-age children for developmental language disorder in primary care. Int J Speech Lang Pathol. 2020 Apr;22(2):152–62. doi: 10.1080/17549507.2019.1632931. PMID: 31262202. Exclusion Code: X2.31262202
207 Lee NR, Chung SH, Song MK, A comparative analysis of clinical screening test and language specific test in language delay children. Chonnam Med J. 2020 Jan;56(1):44–9. doi: 10.4068/cmj.2020.56.1.44. PMID: 32021841. Exclusion Code: X2.32021841
208 D'Aprano A, Johnston H, Jarman R, Practitioners' perceptions of the ASQ-TRAK developmental screening tool for use in Aboriginal children: a preliminary survey. J Paediatr Child Health. 2020 Jan;56(1):94–101. doi: 10.1111/jpc.14502. PMID: 31132192. Exclusion Code: X8.31132192
209 Mezawa H, Aoki S, Nakayama SF, Psychometric profile of the Ages and Stages Questionnaires, Japanese translation. Pediatr Int. 2019 Nov;61(11):1086–95. doi: 10.1111/ped.13990. PMID: 31419360. Exclusion Code: X5.31419360
210 Valla L, Slinning K, Wentzel-Larsen T. Parent satisfaction before and after implementing of a developmental screening tool in nine well-baby clinics in Norway. Acta Paediatr. 2019 Oct;108(10):1811–6. doi: 10.1111/apa.14802. PMID: 30924970. Exclusion Code: X6.30924970
211 Yue A, Jiang Q, Wang B, Concurrent validity of the Ages and Stages Questionnaire and the Bayley Scales of Infant Development III in China. PLoS One. 2019;14(9):e0221675. doi: 10.1371/journal.pone.0221675. PMID: 31487302. Exclusion Code: X5.31487302
212 Nozadi SS, Li L, Clifford J, Use of Ages and Stages Questionnaires (ASQ) in a Navajo population: comparison with the U.S. normative dataset. Child Care Health Dev. 2019 Sep;45(5):709–18. doi: 10.1111/cch.12704. PMID: 31276599. Exclusion Code: X5.31276599
213 Trajkovski N, O'Brian S, Onslow M, A three-arm randomized controlled trial of Lidcombe Program and Westmead Program early stuttering interventions. J Fluency Disord. 2019 Sep;61:105708. doi: 10.1016/j.jfludis.2019.105708. PMID: 31121476. Exclusion Code: X5.31121476
214 Jang CH, Kim SW, Jeon HR, Clinical usefulness of the Korean Developmental Screening Test (K-DST) for developmental delays. Ann Rehabil Med. 2019 Aug;43(4):490–6. doi: 10.5535/arm.2019.43.4.490. PMID: 31499603. Exclusion Code: X6.31499603
215 Redmond SM, Ash AC, Christopulos TT, Diagnostic accuracy of sentence recall and past tense measures for identifying children's language impairments. J Speech Lang Hear Res. 2019 Jul 15;62(7):2438–54. doi: 10.1044/2019_JSLHR-L-18-0388. PMID: 31220421. Exclusion Code: X2.31220421
216 Bialecka-Pikul M, Filip A, Stepien-Nycz M, Ratunku! or just tunku! evidence for the reliability and concurrent validity of the Language Use Inventory-Polish. J Speech Lang Hear Res. 2019 Jul 15;62(7):2317–31. doi: 10.1044/2019_JSLHR-L-18-0230. PMID: 31260375. Exclusion Code: X3.31260375
217 Hendricks AE, Adlof SM, Alonzo CN, Identifying children at risk for developmental language disorder using a brief, whole-classroom screen. J Speech Lang Hear Res. 2019 Apr 15;62(4):896–908. doi: 10.1044/2018_JSLHR-L-18-0093. PMID: 30986146. Exclusion Code: X2.30986146
218 Combiths PN, Barlow JA, Sanchez E. Quantifying phonological knowledge in children with phonological disorder. Clin Linguist Phon. 2019;33(10–11):885–98. doi: 10.1080/02699206.2019.1584247. PMID: 31379215. Exclusion Code: X3.31379215
219 Shafiei B, Faramarzi S, Abedi A, Effects of the Lidcombe Program and parent-child interaction therapy on stuttering reduction in preschool children. Folia Phoniatr Logop. 2019;71(1):29–41. doi: 10.1159/000493915. PMID: 30541009. Exclusion Code: X5.30541009
220 Keilmann A, Neumann K, Zoller D, Clinical trial of the D.E.L.P.H.I.N. speech treatment for children and adolescents who stutter. Logoped Phoniatr Vocol. 2018 Dec;43(4):155–68. doi: 10.1080/14015439.2018.1498917. PMID: 30204526. Exclusion Code: X2.30204526
221 Kirby S, Lyle D, Jones D, Design and delivery of an innovative speech pathology service-learning program for primary school children in Far West NSW, Australia. Public Health Res Pract. 2018 Sep 27;28(3)doi: 10.17061/phrp28231806. PMID: 30406259. Exclusion Code: X5.30406259
222 Furlong L, Morris M, Serry T, Mobile apps for treatment of speech disorders in children: an evidence-based analysis of quality and efficacy. PLoS One. 2018;13(8):e0201513. doi: 10.1371/journal.pone.0201513. PMID: 30092095. Exclusion Code: X8.30092095
223 Onslow M, Jones M, O'Brian S, Comparison of percentage of syllables stuttered with parent-reported severity ratings as a primary outcome measure in clinical trials of early stuttering treatment. J Speech Lang Hear Res. 2018 Apr 17;61(4):811–9. doi: 10.1044/2017_JSLHR-S-16-0448. PMID: 29554191. Exclusion Code: X5.29554191
224 Weiler B, Schuele CM, Feldman JI, A multiyear population-based study of kindergarten language screening failure rates using the Rice Wexler Test of Early Grammatical Impairment. Lang Speech Hear Serv Sch. 2018 Apr 5;49(2):248–59. doi: 10.1044/2017_LSHSS-17-0071. PMID: 29621804. Exclusion Code: X5.29621804
225 Lamsal R, Dutton DJ, Zwicker JD. Using the Ages and Stages Questionnaire in the general population as a measure for identifying children not at risk of a neurodevelopmental disorder. BMC Pediatr. 2018 Apr 3;18(1):122. doi: 10.1186/s12887-018-1105-z. PMID: 29614989. Exclusion Code: X6.29614989
226 Yi YG, Sung IY, Yuk JS. Comparison of Second and Third Editions of the Bayley Scales in children with suspected developmental delay. Ann Rehabil Med. 2018 Apr;42(2):313–20. doi: 10.5535/arm.2018.42.2.313. PMID: 29765885. Exclusion Code: X2.29765885
227 Vehkavuori SM, Stolt S. Screening language skills at 2;0. Infant Behav Dev. 2018 Feb;50:174–9. doi: 10.1016/j.infbeh.2018.01.001. PMID: 29407426. Exclusion Code: X11.29407426
228 Romero Otalvaro AM, Granana N, Gaeto N, ASQ-3: Validation of the Ages and Stages Questionnaire for the detection of neurodevelopmental disorders in Argentine children. Arch Argent Pediatr. 2018 Feb 1;116(1):7–13. doi: 10.5546/aap.2018.eng.7. PMID: 29333806. Exclusion Code: X5.29333806
229 Leonard LB, Haebig E, Deevy P, Tracking the growth of tense and agreement in children with specific language impairment: differences between measures of accuracy, diversity, and productivity. J Speech Lang Hear Res. 2017 Dec 20;60(12):3590–600. doi: 10.1044/2017_JSLHR-L-16-0427. PMID: 29188270. Exclusion Code: X5.29188270
230 Theodorou E, Kambanaros M, Grohmann KK. Sentence repetition as a tool for screening morphosyntactic abilities of bilectal children with SLI. Front Psychol. 2017;8:2104. doi: 10.3389/fpsyg.2017.02104. PMID: 29270140. Exclusion Code: X2.29270140
231 McKelvey LM, Conners Edge NA, Fitzgerald S, Adverse childhood experiences: screening and health in children from birth to age 5. Fam Syst Health. 2017 Dec;35(4):420–9. doi: 10.1037/fsh0000301. PMID: 29283610. Exclusion Code: X3.29283610
232 Yim CH, Kim GH, Eun BL. Usefulness of the Korean Developmental Screening Test for infants and children for the evaluation of developmental delay in Korean infants and children: a single-center study. Korean J Pediatr. 2017 Oct;60(10):312–9. doi: 10.3345/kjp.2017.60.10.312. PMID: 29158765. Exclusion Code: X2.29158765
233 Iyer SN, Dawson MZ, Sawyer MI, Added value of early literacy screening in preschool children. Clin Pediatr (Phila). 2017 Sep;56(10):959–63. doi: 10.1177/0009922817702937. PMID: 28420261. Exclusion Code: X6.28420261
234 Hendricks AE, Adlof SM. Language assessment with children who speak nonmainstream dialects: examining the effects of scoring modifications in norm-referenced assessment. Lang Speech Hear Serv Sch. 2017 Jul 26;48(3):168–82. doi: 10.1044/2017_LSHSS-16-0060. PMID: 28715549. Exclusion Code: X2.28715549
235 McAllister Byun T. Efficacy of visual-acoustic biofeedback intervention for residual rhotic errors: a single-subject randomization study. J Speech Lang Hear Res. 2017 May 24;60(5):1175–93. doi: 10.1044/2016_JSLHR-S-16-0038. PMID: 28389677. Exclusion Code: X2.28389677
236 Petersen DB, Chanthongthip H, Ukrainetz TA, Dynamic assessment of narratives: efficient, accurate identification of language impairment in bilingual students. J Speech Lang Hear Res. 2017 Apr 14;60(4):983–98. doi: 10.1044/2016_JSLHR-L-15-0426. PMID: 28350892. Exclusion Code: X3.28350892
237 Charkaluk ML, Rousseau J, Calderon J, Ages and Stages Questionnaire at 3 years for predicting IQ at 5–6 years. Pediatrics. 2017 Apr;139(4)doi: 10.1542/peds.2016-2798. PMID: 28360034. Exclusion Code: X5.28360034
238 Cunningham BJ, Washington KN, Binns A, Current methods of evaluating speech-language outcomes for preschoolers with communication disorders: a scoping review using the ICF-CY. J Speech Lang Hear Res. 2017 Feb 1;60(2):447–64. doi: 10.1044/2016_JSLHR-L-15-0329. PMID: 28219081. Exclusion Code: X8.28219081
239 Anderson PJ, Burnett A. Assessing developmental delay in early childhood concerns with the Bayley-III scales. Clin Neuropsychol. 2017 Feb;31(2):371–81. doi: 10.1080/13854046.2016.1216518. PMID: 27687612. Exclusion Code: X8.27687612
240 Singh A, Yeh CJ, Boone Blanchard S. Ages and Stages Questionnaire: a global screening scale. Bol Med Hosp Infant Mex. 2017 Jan-Feb;74(1):5–12. doi: 10.1016/j.bmhimx.2016.07.008. PMID: 29364814. Exclusion Code: X8.29364814
241 Hsiao C, Richter L, Makusha T, Use of the ages and stages questionnaire adapted for South Africa and Zambia. Child Care Health Dev. 2017 Jan;43(1):59–66. doi: 10.1111/cch.12413. PMID: 27709653. Exclusion Code: X5.27709653
242 Cleland J, Scobbie JM, Heyde C, Covert contrast and covert errors in persistent velar fronting. Clin Linguist Phon. 2017;31(1):35–55. doi: 10.1080/02699206.2016.1209788. PMID: 27610938. Exclusion Code: X4.27610938
243 Preston JL, Leece MC, Maas E. Motor-based treatment with and without ultrasound feedback for residual speech-sound errors. Int J Lang Commun Disord. 2017 Jan;52(1):80–94. doi: 10.1111/1460-6984.12259. PMID: 27296780. Exclusion Code: X2.27296780
244 Sutherland R, Trembath D, Hodge A, Telehealth language assessments using consumer grade equipment in rural and urban settings: feasible, reliable and well tolerated. J Telemed Telecare. 2017 Jan;23(1):106–15. doi: 10.1177/1357633X15623921. PMID: 26768598. Exclusion Code: X2.26768598
245 Kim SW, Kim JY, Lee SY, The comparison of M-B CDI-K Short Form and K-ASQ as screening test for language development. Ann Rehabil Med. 2016 Dec;40(6):1108–13. doi: 10.5535/arm.2016.40.6.1108. PMID: 28119842. Exclusion Code: X2.28119842
246 Simpson S, D'Aprano A, Tayler C, Validation of a culturally adapted developmental screening tool for Australian Aboriginal children: early findings and next steps. Early Hum Dev. 2016 Dec;103:91–5. doi: 10.1016/j.earlhumdev.2016.08.005. PMID: 27544061. Exclusion Code: X3.27544061
247 Thomas DC, McCabe P, Ballard KJ, Telehealth delivery of Rapid Syllable Transitions (ReST) treatment for childhood apraxia of speech. Int J Lang Commun Disord. 2016 Nov;51(6):654–71. doi: 10.1111/1460-6984.12238. PMID: 27161038. Exclusion Code: X2.27161038
248 Armon-Lotem S, Meir N. Diagnostic accuracy of repetition tasks for the identification of specific language impairment (SLI) in bilingual children: evidence from Russian and Hebrew. Int J Lang Commun Disord. 2016 Nov;51(6):715–31. doi: 10.1111/1460-6984.12242. PMID: 26990037. Exclusion Code: X2.26990037
249 Visser M, Nel M, Bronkhorst C, Childhood disability population-based surveillance: assessment of the Ages and Stages Questionnaire Third Edition and Washington Group on Disability Statistics/UNICEF module on child functioning in a rural setting in South Africa. Afr J Disabil. 2016;5(1):265. doi: 10.4102/ajod.v5i1.265. PMID: 28730058. Exclusion Code: X5.28730058
250 Salim SS, Mustafa MB, Asemi A, A speech pronunciation practice system for speech-impaired children: a study to measure its success. Res Dev Disabil. 2016 Sep;56:41–59. doi: 10.1016/j.ridd.2016.05.013. PMID: 27262125. Exclusion Code: X5.27262125
251 Mailend ML, Plante E, Anderson MA, Reliability of the Test of Integrated Language and Literacy Skills (TILLS). Int J Lang Commun Disord. 2016 Jul;51(4):447–59. doi: 10.1111/1460-6984.12222. PMID: 27018642. Exclusion Code: X3.27018642
252 Goldstein H, Kelley E, Greenwood C, Embedded instruction improves vocabulary learning during automated storybook reading among high-risk preschoolers. J Speech Lang Hear Res. 2016 Jun 1;59(3):484–500. doi: 10.1044/2015_JSLHR-L-15-0227. PMID: 27123881. Exclusion Code: X2.27123881
253 van der Linde J, Swanepoel W, Hanekom L, Early detection of communication delays with the PEDS tools in at-risk South African infants. Afr J Disabil. 2016;5(1):223. doi: 10.4102/ajod.v5i1.223. PMID: 28730050. Exclusion Code: X9.28730050
254 Kim JH, Ballard E, McCann CM. Parent-rated measures of bilingual children's speech accuracy: implications for a universal speech screen. Int J Speech Lang Pathol. 2016 Apr;18(2):202–11. doi: 10.3109/17549507.2015.1081284. PMID: 27172854. Exclusion Code: X6.27172854
255 Guo LY, Schneider P. Differentiating school-aged children with and without language impairment using tense and grammaticality measures from a narrative task. J Speech Lang Hear Res. 2016 Apr 1;59(2):317–29. doi: 10.1044/2015_JSLHR-L-15-0066. PMID: 27088899. Exclusion Code: X2.27088899
256 D'Aprano A, Silburn S, Johnston V, Adaptation of the Ages and Stages Questionnaire for remote Aboriginal Australia. Qual Health Res. 2016 Apr;26(5):613–25. doi: 10.1177/1049732314562891. PMID: 25488936. Exclusion Code: X6.25488936
257 Lousada M, Valente ARS, Mendes A. Validation of a pediatric speech and language screening (RALF). Folia Phoniatr Logop. 2016;68(6):247–51. doi: 10.1159/000479928. PMID: 29176312. Exclusion Code: X8.29176312
258 Mirawdeli A, Howell P. Is it necessary to assess fluent symptoms, duration of dysfluent events, and physical concomitants when identifying children who have speech difficulties? Clin Linguist Phon. 2016;30(9):696–719. doi: 10.1080/02699206.2016.1179345. PMID: 27315282. Exclusion Code: X5.27315282
259 Armijo I, Schonhaut L, Cordero M. Validation of the Chilean version of the Ages and Stages Questionnaire (ASQ-CL) in community health settings. Early Hum Dev. 2015 Dec;91(12):671–6. doi: 10.1016/j.earlhumdev.2015.10.001. PMID: 26513627. Exclusion Code: X5.26513627
260 Siu AL U.S. Preventive Services Task Force. Screening for speech and language delay and disorders in children aged 5 years or younger: U.S. Preventive Services Task Force recommendation statement. Pediatrics. 2015 Aug;136(2):e474–81. doi: 10.1542/peds.2015-1711. PMID: 26152670. Exclusion Code: X8.26152670
261 El-Behadli AF, Neger EN, Perrin EC, Translations of developmental screening instruments: an evidence map of available research. J Dev Behav Pediatr. 2015 Jul-Aug;36(6):471–83. doi: 10.1097/DBP.0000000000000193. PMID: 26154718. Exclusion Code: X8.26154718
262 Hunter LR, Myszkowski MR, Johnson SK, Comparing the clinical utility of the Infant Developmental Inventory with the Ages and Stages Questionnaire at 9-month well-child visits. J Prim Care Community Health. 2015 Jul;6(3):193–8. doi: 10.1177/2150131914560228. PMID: 25424742. Exclusion Code: X5.25424742
263 Park J, Miller CA, Mainela-Arnold E. Processing speed measures as clinical markers for children with language impairment. J Speech Lang Hear Res. 2015 Jun;58(3):954–60. doi: 10.1044/2015_JSLHR-L-14-0092. PMID: 25682521. Exclusion Code: X5.25682521
264 Freed J, McBean K, Adams C, Performance of children with social communication disorder on the Happe Strange Stories: physical and mental state responses and relationship to language ability. J Commun Disord. 2015 May-Jun;55:1–14. doi: 10.1016/j.jcomdis.2015.03.002. PMID: 25935076. Exclusion Code: X2.25935076
265 Kwun Y, Park HW, Kim MJ, Validity of the Ages and Stages Questionnaires in Korean compared to Bayley Scales of Infant Development-II for screening preterm infants at corrected age of 18–24 months for neurodevelopmental delay. J Korean Med Sci. 2015 Apr;30(4):450–5. doi: 10.3346/jkms.2015.30.4.450. PMID: 25829813. Exclusion Code: X2.25829813
266 Kazemi Y, Klee T, Stringer H. Diagnostic accuracy of language sample measures with Persian-speaking preschool children. Clin Linguist Phon. 2015 Apr;29(4):304–18. doi: 10.3109/02699206.2014.1003097. PMID: 25606693. Exclusion Code: X3.25606693
267 Lagerberg TB, Hartelius L, Johnels JA, Swedish Test of Intelligibility for Children (STI-CH)--validity and reliability of a computer-mediated single word intelligibility test for children. Clin Linguist Phon. 2015 Mar;29(3):201–15. doi: 10.3109/02699206.2014.987925. PMID: 25489674. Exclusion Code: X5.25489674
268 Veldhuizen S, Clinton J, Rodriguez C, Concurrent validity of the Ages And Stages Questionnaires and Bayley Developmental Scales in a general population sample. Acad Pediatr. 2015 Mar-Apr;15(2):231–7. doi: 10.1016/j.acap.2014.08.002. PMID: 25224137. Exclusion Code: X5.25224137
269 De-Andres-Beltran B, Rodriguez-Fernandez AL, Gueita-Rodriguez J, Evaluation of the psychometric properties of the Spanish version of the Denver Developmental Screening Test II. Eur J Pediatr. 2015 Mar;174(3):325–9. doi: 10.1007/s00431-014-2410-7. PMID: 25164064. Exclusion Code: X3.25164064
270 Preston JL, McCabe P, Rivera-Campos A, Ultrasound visual feedback treatment and practice variability for residual speech sound errors. J Speech Lang Hear Res. 2014 Dec;57(6):2102–15. doi: 10.1044/2014_JSLHR-S-14-0031. PMID: 25087938. Exclusion Code: X2.25087938
271 McKnight S. Implementing the Ages and Stages Questionnaire in health visiting practice. Community Pract. 2014 Nov;87(11):28–32. PMID: 25612412. Exclusion Code: X6.25612412
272 Taylor OD, Armfield NR, Dodrill P, A review of the efficacy and effectiveness of using telehealth for pediatric speech and language assessment. J Telemed Telecare. 2014 Oct;20(7):405–12. doi: 10.1177/1357633X14552388. PMID: 25400002. Exclusion Code: X8.25400002
273 Damico JS, Nettleton SK, Damico HL, Discriminant validity with a direct observational assessment system: research with previously identified groups. Clin Linguist Phon. 2014 Jul-Aug;28(7–8):617–26. doi: 10.3109/02699206.2014.926999. PMID: 25000382. Exclusion Code: X2.25000382
274 Topbas S, Kacar-Kutukcu D, Kopkalli-Yavuz H. Performance of children on the Turkish Nonword Repetition Test: effect of word similarity, word length, and scoring. Clin Linguist Phon. 2014 Jul-Aug;28(7–8):602–16. doi: 10.3109/02699206.2014.927003. PMID: 25000381. Exclusion Code: X2.25000381
275 Srinithiwat B, Ularntinon S. Concurrent validity of the Ages & Stages Questionnaires, Third Edition, Thai-version (ASQ-3 Thai) with the Denver Developmental Screening Test II (DDST-II) in developmental screening of 18, 24, and 30 months old children at Queen Sirikit National Institute of Child Health. J Med Assoc Thai. 2014 Jun;97 Suppl 6:S6–13. PMID: 25391166. Exclusion Code: X5.25391166
276 Kim SW, Jeon HR, Park EJ, The usefulness of M-B CDI-K Short Form as screening test in children with language developmental delay. Ann Rehabil Med. 2014 Jun;38(3):376–80. doi: 10.5535/arm.2014.38.3.376. PMID: 25024962. Exclusion Code: X2.25024962
277 Mononen R, Aunio P, Koponen T. A pilot study of the effects of RightStart instruction on early numeracy skills of children with specific language impairment. Res Dev Disabil. 2014 May;35(5):999–1014. doi: 10.1016/j.ridd.2014.02.004. PMID: 24629543. Exclusion Code: X2.24629543
278 Crowe K, Cuervo S, Guiberson M, A systematic review of interventions for multilingual preschoolers with speech and language difficulties. J Speech Lang Hear Res. 2021 Nov 8;64(11):4413–38. doi: 10.1044/2021_JSLHR-21-00073. PMID: 34554866. Exclusion Code: X8.34554866
279 Towson JA, Akemoglu Y, Watkins L, Shared interactive book reading interventions for young children with disabilities: a systematic review. Am J Speech Lang Pathol. 2021 Nov 4;30(6):2700–15. doi: 10.1044/2021_AJSLP-20-00401. PMID: 34586887. Exclusion Code: X8.34586887
280 Zhang Z, Xu Q, Joshi RM. A meta-analysis on the effectiveness of intervention in children with primary speech and language delays/disorders: focusing on China and the United States. Clin Psychol Psychother. 2021 May;28(3):585–605. doi: 10.1002/cpp.2522. PMID: 33068068. Exclusion Code: X8.33068068
281 Dubois P, St-Pierre MC, Desmarais C, Young adults with developmental language disorder: a systematic review of education, employment, and independent living outcomes. J Speech Lang Hear Res. 2020 Nov 13;63(11):3786–800. doi: 10.1044/2020_JSLHR-20-00127. PMID: 33022192. Exclusion Code: X2.33022192
282 Stanford E, Durrleman S, Delage H. The effect of working memory training on a clinical marker of French-speaking children with developmental language disorder. Am J Speech Lang Pathol. 2019 Nov 19;28(4):1388–410. doi: 10.1044/2019_AJSLP-18-0238. PMID: 31419156. Exclusion Code: X2.31419156
283 Biggs EE, Carter EW, Gilson CB. Systematic review of interventions involving aided AAC modeling for children with complex communication needs. Am J Intellect Dev Disabil. 2018 Sep;123(5):443–73. doi: 10.1352/1944-7558-123.5.443. PMID: 30198767. Exclusion Code: X8.30198767
284 O'Neill T, Light J, Pope L. Effects of Interventions that include aided augmentative and alternative communication input on the communication of individuals with complex communication needs: a meta-analysis. J Speech Lang Hear Res. 2018 Jul 13;61(7):1743–65. doi: 10.1044/2018_JSLHR-L-17-0132. PMID: 29931287. Exclusion Code: X8.29931287
285 Denman D, Speyer R, Munro N, Psychometric properties of language assessments for children aged 4–12 years: a systematic review. Front Psychol. 2017;8:1515. doi: 10.3389/fpsyg.2017.01515. PMID: 28936189. Exclusion Code: X8.28936189
286 Wales D, Skinner L, Hayman M. The efficacy of telehealth-delivered speech and language intervention for primary school-age children: a systematic review. Int J Telerehabil. 2017 Spring;9(1):55–70. doi: 10.5195/ijt.2017.6219. PMID: 28814995. Exclusion Code: X8.28814995
287 Tosh R, Arnott W, Scarinci N. Parent-implemented home therapy programmes for speech and language: a systematic review. Int J Lang Commun Disord. 2017 May;52(3):253–69. doi: 10.1111/1460-6984.12280. PMID: 27943521. Exclusion Code: X8.27943521
288 Chorna O, Hamm E, Cummings C, Speech and language interventions for infants aged 0 to 2 years at high risk for cerebral palsy: a systematic review. Dev Med Child Neurol. 2017 Apr;59(4):355–60. doi: 10.1111/dmcn.13342. PMID: 27897320. Exclusion Code: X2.27897320
289 Duran LK, Hartzheim D, Lund EM, Bilingual and home language interventions with young dual language learners: a research synthesis. Lang Speech Hear Serv Sch. 2016 Oct 1;47(4):347–71. doi: 10.1044/2016_LSHSS-15-0030. PMID: 27679851. Exclusion Code: X8.27679851
290 Baxter S, Johnson M, Blank L, Nonpharmacological treatments for stuttering in children and adults: a systematic review and evaluation of clinical effectiveness, and exploration of barriers to successful outcomes. Health Technol Assess. 2016 Jan;20(2):1–302, v-vi. doi: 10.3310/hta20020. PMID: 26767317. Exclusion Code: X8.26767317
291 Cleave PL, Becker SD, Curran MK, The efficacy of recasts in language intervention: a systematic review and metaanalysis. Am J Speech Lang Pathol. 2015 May;24(2):237–55. doi: 10.1044/2015_AJSLP-14-0105. PMID: 25654306. Exclusion Code: X8.25654306
292 Biele G, Lekhal R, Overgaard KR, The effect of special educational assistance in early childhood education and care on psycho-social difficulties in elementary school children. Child Adolesc Psychiatry Ment Health. 2022 Feb 24;16(1):14. doi: 10.1186/s13034-022-00442-5. PMID: 35209931. Exclusion Code: X8.35209931
293 Keung AY, Ho VF, Shum KK. Early cognitive intervention using mediated learning for preschoolers with developmental delay: a randomized controlled trial. Br J Educ Psychol. 2022 Sep;92(3):1109–32. doi: 10.1111/bjep.12490. PMID: 35195914. Exclusion Code: X2.35195914
294 Rezaeerezvan S, Kareshki H, Pakdaman M. The effect of cognitive-behavioral play therapy on improvements in expressive linguistic disorders of bilingual children. Front Psychol. 2021;12:626422. doi: 10.3389/fpsyg.2021.626422. PMID: 35069301. Exclusion Code: X9.35069301
295 Petersen DB, Staskowski M, Spencer TD, The effects of a multitiered system of language support on kindergarten oral and written language: a large-scale randomized controlled trial. Lang Speech Hear Serv Sch. 2022 Jan 5;53(1):44–68. doi: 10.1044/2021_LSHSS-20-00162. PMID: 34860575. Exclusion Code: X2.34860575
296 West G, Snowling MJ, Lervag A, Early language screening and intervention can be delivered successfully at scale: evidence from a cluster randomized controlled trial. J Child Psychol Psychiatry. 2021 Dec;62(12):1425–34. doi: 10.1111/jcpp.13415. PMID: 33783013. Exclusion Code: X2.33783013
297 Brignell A, Krahe M, Downes M, Interventions for children and adolescents who stutter: a systematic review, metaanalysis, and evidence map. J Fluency Disord. 2021 Dec;70:105843. doi: 10.1016/j.jfludis.2021.105843. PMID: 33743406. Exclusion Code: X8.33743406
298 Kueser JB, Leonard LB, Deevy P, Word-learning trajectories influence long-term recall in children with developmental language disorder and typical development. J Commun Disord. 2021 Nov-Dec;94:106160. doi: 10.1016/j.jcomdis.2021.106160. PMID: 34768092. Exclusion Code: X3.34768092
299 Calder SD, Claessen M, Leitao S, Evaluating two different dose frequencies and cumulative intervention intensities to improve past tense production for early school-aged children with developmental language disorder. Int J Lang Commun Disord. 2021 Nov;56(6):1278–95. doi: 10.1111/1460-6984.12667. PMID: 34431174. Exclusion Code: X8.34431174
300 Frizelle P, Tolonen AK, Tulip J, The impact of intervention dose form on oral language outcomes for children with developmental language disorder. J Speech Lang Hear Res. 2021 Aug 9;64(8):3253–88. doi: 10.1044/2021_JSLHR-20-00734. PMID: 34213951. Exclusion Code: X8.34213951
301 Senent-Capuz N, Baixauli-Fortea I, Moret-Tatay C. Parent-implemented Hanen program It Takes Two to Talk((R)): an exploratory study in Spain. Int J Environ Res Public Health. 2021 Aug 3;18(15)doi: 10.3390/ijerph18158214. PMID: 34360506. Exclusion Code: X5.34360506
302 Hodgins H, Harrison GL. Improving phonological awareness with Talking Tables in at-risk kindergarten readers. Res Dev Disabil. 2021 Aug;115:103996. doi: 10.1016/j.ridd.2021.103996. PMID: 34116299. Exclusion Code: X2.34116299
303 de la Torre Carril A, Duran-Bouza M, Perez-Pereira M. Capacity of the CCC-2 to discriminate ASD from other neurodevelopmental disorders. Children (Basel). 2021 Jul 27;8(8)doi: 10.3390/children8080640. PMID: 34438530. Exclusion Code: X2.34438530
304 Walters C, Sevcik RA, Romski M. Spoken vocabulary outcomes of toddlers with developmental delay after parent-implemented augmented language intervention. Am J Speech Lang Pathol. 2021 May 18;30(3):1023–37. doi: 10.1044/2020_AJSLP-20-00093. PMID: 33789437. Exclusion Code: X2.33789437
305 Rehfeld DM, Sulak TN. Service delivery schedule effects on speech sound production outcomes. Lang Speech Hear Serv Sch. 2021 Apr 20;52(2):728–37. doi: 10.1044/2021_LSHSS-20-00068. PMID: 33822654. Exclusion Code: X5.33822654
306 Byers BA, Bellon-Harn ML, Allen M, A comparison of intervention intensity and service delivery models with school-age children with speech sound disorders in a school setting. Lang Speech Hear Serv Sch. 2021 Apr 20;52(2):529–41. doi: 10.1044/2020_LSHSS-20-00057. PMID: 33497584. Exclusion Code: X2.33497584
307 Frizelle P, Tolonen AK, Tulip J, The influence of quantitative intervention dosage on oral language outcomes for children with developmental language disorder: a systematic review and narrative synthesis. Lang Speech Hear Serv Sch. 2021 Apr 20;52(2):738–54. doi: 10.1044/2020_LSHSS-20-00058. PMID: 33465314. Exclusion Code: X8.33465314
308 Rinaldi S, Caselli MC, Cofelice V, Efficacy of the treatment of developmental language disorder: a systematic review. Brain Sci. 2021 Mar 23;11(3)doi: 10.3390/brainsci11030407. PMID: 33806938. Exclusion Code: X8.33806938
309 Rowe A, Titterington J, Holmes J, A classroom intervention targeting working memory, attention and language skills: a cluster randomised feasibility trial. Pilot Feasibility Stud. 2021 Feb 6;7(1):45. doi: 10.1186/s40814-021-00771-w. PMID: 33549138. Exclusion Code: X6.33549138
310 Calder SD, Claessen M, Ebbels S, The efficacy of an explicit intervention approach to improve past tense marking for early school-age children with developmental language disorder. J Speech Lang Hear Res. 2021 Jan 14;64(1):91–104. doi: 10.1044/2020_JSLHR-20-00132. PMID: 33332157. Exclusion Code: X2.33332157
311 Donaghy M, O'Brian S, Onslow M, Verbal contingencies in the Lidcombe Program: a noninferiority trial. J Speech Lang Hear Res. 2020 Oct 16;63(10):3419–31. doi: 10.1044/2020_JSLHR-20-00155. PMID: 32956008. Exclusion Code: X5.32956008
312 Forrest CL, Gibson JL, Halligan SL, A cross-lagged analysis of emotion regulation, peer problems, and emotional problems in children with and without early language difficulties: evidence from the Millennium Cohort Study. J Speech Lang Hear Res. 2020 Apr 27;63(4):1227–39. doi: 10.1044/2020_JSLHR-19-00188. PMID: 32315250. Exclusion Code: X4.32315250
313 Jesus LMT, Martinez J, Santos J, Comparing traditional and tablet-based intervention for children with speech sound disorders: a randomized controlled trial. J Speech Lang Hear Res. 2019 Nov 22;62(11):4045–61. doi: 10.1044/2019_JSLHR-S-18-0301. PMID: 31644381. Exclusion Code: X5.31644381
314 Lewis BA, Freebairn L, Tag J, Differential long-term outcomes for individuals with histories of preschool speech sound disorders. Am J Speech Lang Pathol. 2019 Nov 19;28(4):1582–96. doi: 10.1044/2019_AJSLP-18-0247. PMID: 31604025. Exclusion Code: X2.31604025
315 Rvachew S, Matthews T. An N-of-1 randomized controlled trial of interventions for children with inconsistent speech sound errors. J Speech Lang Hear Res. 2019 Sep 20;62(9):3183–203. doi: 10.1044/2019_JSLHR-S-18-0288. PMID: 31479383. Exclusion Code: X5.31479383
316 Crowe K, Guiberson M. Evidence-based interventions for learners who are deaf and/or multilingual: a systematic quality review. Am J Speech Lang Pathol. 2019 Aug 9;28(3):964–83. doi: 10.1044/2019_AJSLP-IDLL-19-0003. PMID: 31398302. Exclusion Code: X2.31398302
317 Plante E, Mettler HM, Tucci A, Maximizing treatment efficiency in developmental language disorder: positive effects in half the time. Am J Speech Lang Pathol. 2019 Aug 9;28(3):1233–47. doi: 10.1044/2019_AJSLP-18-0285. PMID: 31343897. Exclusion Code: X5.31343897
318 Majnemer A, O'Donnell M, Ogourtsova T, BRIGHT Coaching: a randomized controlled trial on the effectiveness of a developmental coach system to empower families of children with emerging developmental delay. Front Pediatr. 2019;7:332. doi: 10.3389/fped.2019.00332. PMID: 31440489. Exclusion Code: X2.31440489
319 Cornacchio D, Furr JM, Sanchez AL, Intensive group behavioral treatment (IGBT) for children with selective mutism: a preliminary randomized clinical trial. J Consult Clin Psychol. 2019 Aug;87(8):720–33. doi: 10.1037/ccp0000422. PMID: 31294589. Exclusion Code: X2.31294589
320 Roberts MY, Curtis PR, Sone BJ, Association of parent training with child language development: a systematic review and meta-analysis. JAMA Pediatr. 2019 Jul 1;173(7):671–80. doi: 10.1001/jamapediatrics.2019.1197. PMID: 31107508. Exclusion Code: X8.31107508
321 Silva D, Menezes PL, Almeida GF, Influence of speech-language therapy on P300 outcome in patients with language disorders: a meta-analysis. Braz J Otorhinolaryngol. 2019 Jul-Aug;85(4):510–9. doi: 10.1016/j.bjorl.2019.01.012. PMID: 30902588. Exclusion Code: X6.30902588
322 Hattar-Pollara M. Barriers to education of Syrian refugee girls in Jordan: gender-based threats and challenges. J Nurs Scholarsh. 2019 May;51(3):241–51. doi: 10.1111/jnu.12480. PMID: 30977586. Exclusion Code: X8.30977586
323 Esmaili SK, Mehraban AH, Shafaroodi N, Participation in peer-play activities among children with specific learning disability: a randomized controlled trial. Am J Occup Ther. 2019 Mar/Apr;73(2):7302205110p1–p9. doi: 10.5014/ajot.2018.028613. PMID: 30915972. Exclusion Code: X2.30915972
324 Druker KC, Mazzucchelli TG, Beilby JM. An evaluation of an integrated fluency and resilience program for early developmental stuttering disorders. J Commun Disord. 2019 Mar-Apr;78:69–83. doi: 10.1016/j.jcomdis.2019.02.002. PMID: 30798143. Exclusion Code: X5.30798143
325 Curtis PR, Kaiser AP, Estabrook R, The longitudinal effects of early language intervention on children's problem behaviors. Child Dev. 2019 Mar;90(2):576–92. doi: 10.1111/cdev.12942. PMID: 28872672. Exclusion Code: X11.28872672
326 Szymaszek A, Dacewicz A, Urban P, Training in temporal information processing ameliorates phonetic identification. Front Hum Neurosci. 2018;12:213. doi: 10.3389/fnhum.2018.00213. PMID: 29928195. Exclusion Code: X3.29928195
327 Winstanley M, Webb RT, Conti-Ramsden G. More or less likely to offend? Young adults with a history of identified developmental language disorders. Int J Lang Commun Disord. 2018 Mar;53(2):256–70. doi: 10.1111/1460-6984.12339. PMID: 29159847. Exclusion Code: X2.29159847
328 Kelley E, Leary E, Goldstein H. Predicting response to treatment in a Tier 2 supplemental vocabulary intervention. J Speech Lang Hear Res. 2018 Jan 22;61(1):94–103. doi: 10.1044/2017_JSLHR-L-16-0399. PMID: 29242893. Exclusion Code: X5.29242893
329 Hampton LH, Kaiser AP, Roberts MY. One-year language outcomes in toddlers with language delays: an RCT follow-up. Pediatrics. 2017 Nov;140(5)doi: 10.1542/peds.2016-3646. PMID: 29054980. Exclusion Code: X11.29054980
330 Hagen AM, Melby-Lervag M, Lervag A. Improving language comprehension in preschool children with language difficulties: a cluster randomized trial. J Child Psychol Psychiatry. 2017 Oct;58(10):1132–40. doi: 10.1111/jcpp.12762. PMID: 28671266. Exclusion Code: X2.28671266
331 Rodriguez CD, Cumming TM. Employing mobile technology to improve language skills of young students with language-based disabilities. Assist Technol. 2017 Fall;29(3):161–9. doi: 10.1080/10400435.2016.1171810. PMID: 27064791. Exclusion Code: X2.27064791
332 Armstrong R, Arnott W, Copland DA, Change in receptive vocabulary from childhood to adulthood: associated mental health, education and employment outcomes. Int J Lang Commun Disord. 2017 Sep;52(5):561–72. doi: 10.1111/1460-6984.12301. PMID: 28032409. Exclusion Code: X2.28032409
333 Abdoola F, Flack PS, Karrim SB. Facilitating pragmatic skills through role-play in learners with language learning disability. S Afr J Commun Disord. 2017 Jul 26;64(1):e1–e12. doi: 10.4102/sajcd.v64i1.187. PMID: 28828866. Exclusion Code: X2.28828866
334 McCormack J, Baker E, Masso S, Implementation fidelity of a computer-assisted intervention for children with speech sound disorders. Int J Speech Lang Pathol. 2017 Jun;19(3):265–76. doi: 10.1080/17549507.2017.1293160. PMID: 28351159. Exclusion Code: X6.28351159
335 Tamm L, Denton CA, Epstein JN, Comparing treatments for children with ADHD and word reading difficulties: a randomized clinical trial. J Consult Clin Psychol. 2017 May;85(5):434–46. doi: 10.1037/ccp0000170. PMID: 28333510. Exclusion Code: X2.28333510
336 Bernard K, Lee AH, Dozier M. Effects of the ABC Intervention on foster children's receptive vocabulary: follow-up results from a randomized clinical trial. Child Maltreat. 2017 May;22(2):174–9. doi: 10.1177/1077559517691126. PMID: 28152611. Exclusion Code: X2.28152611
337 Christodoulou JA, Cyr A, Murtagh J, Impact of intensive summer reading intervention for children with reading disabilities and difficulties in early elementary school. J Learn Disabil. 2017 Mar/Apr;50(2):115–27. doi: 10.1177/0022219415617163. PMID: 26712799. Exclusion Code: X2.26712799
338 Goldstein H, Olszewski A, Haring C, Efficacy of a supplemental phonemic awareness curriculum to instruct preschoolers with delays in early literacy development. J Speech Lang Hear Res. 2017 Jan 1;60(1):89–103. doi: 10.1044/2016_JSLHR-L-15-0451. PMID: 28056468. Exclusion Code: X5.28056468
339 Kaipa R, Peterson AM. A systematic review of treatment intensity in speech disorders. Int J Speech Lang Pathol. 2016 Dec;18(6):507–20. doi: 10.3109/17549507.2015.1126640. PMID: 27063688. Exclusion Code: X7.27063688
340 Buil-Legaz L, Aguilar-Mediavilla E, Adrover-Roig D. Longitudinal trajectories of the representation and access to phonological information in bilingual children with specific language impairment. Int J Speech Lang Pathol. 2016 Oct;18(5):473–82. doi: 10.3109/17549507.2015.1126638. PMID: 27153201. Exclusion Code: X5.27153201
341 Kay-Raining Bird E, Genesee F, Verhoeven L. Bilingualism in children with developmental disorders: a narrative review. J Commun Disord. 2016 Sep-Oct;63:1–14. doi: 10.1016/j.jcomdis.2016.07.003. PMID: 27461977. Exclusion Code: X6.27461977
342 Leung C, Chan S, Lam T, The effect of parent education program for preschool children with developmental disabilities: a randomized controlled trial. Res Dev Disabil. 2016 Sep;56:18–28. doi: 10.1016/j.ridd.2016.05.015. PMID: 27258925. Exclusion Code: X2.27258925
343 Pennington L, Parker NK, Kelly H, Speech therapy for children with dysarthria acquired before three years of age. Cochrane Database Syst Rev. 2016 Jul 18;7(7):CD006937. doi: 10.1002/14651858.CD006937.pub3. PMID: 27428115. Exclusion Code: X2.27428115
344 Skelton SL, Richard JT. Application of a motor learning treatment for speech sound disorders in small groups. Percept Mot Skills. 2016 Jun;122(3):840–54. doi: 10.1177/0031512516647693. PMID: 27160738. Exclusion Code: X2.27160738
345 Porta ME, Carrada MA, Ison MS. Phonological awareness intervention and attention efficiency in children at risk: evidence of effectiveness on visual attention. Codas. 2016 May 31;28(3):314–8. doi: 10.1590/2317-1782/20162015277. PMID: 27253226. Exclusion Code: X2.27253226
346 Lewis BA, Patton E, Freebairn L, Psychosocial co-morbidities in adolescents and adults with histories of communication disorders. J Commun Disord. 2016 May-Jun;61:60–70. doi: 10.1016/j.jcomdis.2016.03.004. PMID: 27032038. Exclusion Code: X2.27032038
347 Warren R, Kenny M, Bennett T, Screening for developmental delay among children aged 1–4 years: a systematic review. CMAJ Open. 2016 Jan-Mar;4(1):E20–7. doi: 10.9778/cmajo.20140121. PMID: 27226967. Exclusion Code: X8.27226967
348 Suggate SP. A meta-analysis of the long-term effects of phonemic awareness, phonics, fluency, and reading comprehension interventions. J Learn Disabil. 2016 Jan-Feb;49(1):77–96. doi: 10.1177/0022219414528540. PMID: 24704662. Exclusion Code: X8.24704662
349 Justice LM, Logan JR, Damschroder L. Designing caregiver-implemented shared-reading interventions to overcome implementation barriers. J Speech Lang Hear Res. 2015 Dec;58(6):S1851–63. doi: 10.1044/2015_JSLHR-L-14-0344. PMID: 26262941. Exclusion Code: X8.26262941
350 de Sonneville-Koedoot C, Bouwmans C, Franken MC, Economic evaluation of stuttering treatment in preschool children: the RESTART-study. J Commun Disord. 2015 Nov-Dec;58:106–18. doi: 10.1016/j.jcomdis.2015.10.006. PMID: 26524414. Exclusion Code: X5.26524414
351 Lonigan CJ, Phillips BM, Clancy JL, Impacts of a comprehensive school readiness curriculum for preschool children at risk for educational difficulties. Child Dev. 2015 Nov-Dec;86(6):1773–93. doi: 10.1111/cdev.12460. PMID: 26510099. Exclusion Code: X2.26510099
352 DeThorne L, Aparicio Betancourt M, Karahalios K, Visualizing syllables: real-time computerized feedback within a speech-language intervention. J Autism Dev Disord. 2015 Nov;45(11):3756–63. doi: 10.1007/s10803-014-2274-8. PMID: 25344794. Exclusion Code: X5.25344794
353 Smith-Lock KM, Leitao S, Prior P, The effectiveness of two grammar treatment procedures for children with SLI: a randomized clinical trial. Lang Speech Hear Serv Sch. 2015 Oct;46(4):312–24. doi: 10.1044/2015_LSHSS-14-0041. PMID: 26110982. Exclusion Code: X5.26110982
354 Lugo-Neris MJ, Bedore LM, Pena ED. Dual language intervention for bilinguals at risk for language impairment. Semin Speech Lang. 2015 May;36(2):133–42. doi: 10.1055/s-0035-1549108. PMID: 25922998. Exclusion Code: X2.25922998
355 Kruse LG, Spencer TD, Olszewski A, Small groups, big gains: efficacy of a tier 2 phonological awareness intervention with preschoolers with early literacy deficits. Am J Speech Lang Pathol. 2015 May;24(2):189–205. doi: 10.1044/2015_AJSLP-14-0035. PMID: 25835770. Exclusion Code: X5.25835770
356 Ebert KD, Kohnert K, Pham G, Three treatments for bilingual children with primary language impairment: examining cross-linguistic and cross-domain effects. J Speech Lang Hear Res. 2014 Feb;57(1):172–86. doi: 10.1044/1092-4388(2013/12-0388). PMID: 23900032. Exclusion Code: X5.23900032
357 Frederico M, Jackson AL, Black CM, Small talk: identifying communication problems in maltreated children. Child Abuse Negl. 2018 Jan;75:139–48. doi: 10.1016/j.chiabu.2017.06.009. PMID: 28633958. Exclusion Code: X2.28633958
358 Mazer B, Majnemer A, Thordardottir E, Free papers. Developmental Medicine & Child Neurology. 2014;56(s5):39–112. doi: 10.1111/dmcn.12540. PMID: CN-01049813. Exclusion Code: X10.
359 Kumar P, Singh NK, Hussain RO. Efficacy of computer-based noise desensitization training in children with speech-in-noise deficits. Am J Audiol. 2021 Jun 14;30(2):325–40. doi: 10.1044/2021_AJA-20-00153. PMID: 33974448. Exclusion Code: X2.33974448
360 Storkel HL, Komesidou R, Pezold MJ, The impact of dose and dose frequency on word learning by kindergarten children with developmental language disorder during interactive book reading. Lang Speech Hear Serv Sch. 2019 Oct 10;50(4):518–39. doi: 10.1044/2019_LSHSS-VOIA-18-0131. PMID: 31600474. Exclusion Code: X5.31600474
361 Dawes E, Leitão S, Claessen M, A randomized controlled trial of an oral inferential comprehension intervention for young children with developmental language disorder. Child Language Teaching and Therapy. 2018;35(1):39–54. doi: 10.1177/0265659018815736. PMID: CN-02116290. Exclusion Code: X5.
362 Petersen DB, Thompsen B, Guiberson MM, Cross-linguistic interactions from second language to first language as the result of individualized narrative language intervention with children with and without language impairment. Applied Psycholinguistics. 2015;37(3):703–24. doi: 10.1017/s0142716415000211. PMID: CN-02197797. Exclusion Code: X2.
363 Lee W, Pring T. Supporting language in schools: evaluating an intervention for children with delayed language in the early school years. Child Language Teaching and Therapy. 2015;32(2):135–46. doi: 10.1177/0265659015590426. PMID: CN-02110580. Exclusion Code: X2.
364 Reeves L, Hartshorne M, Black R, Early talk boost: a targeted intervention for three year old children with delayed language development. Child Language Teaching and Therapy. 2018;34(1):53–62. doi: 10.1177/0265659018755526. PMID: CN-02114019. Exclusion Code: X5.
365 Jolley E, Bechange S, Mankhwazi M, Measuring the impact of a training intervention for early childhood centre staff on child development outcomes: findings from a cluster randomized control field trial in rural Malawi. Child Care Health Dev. 2022 Sep;48(5):736–43. doi: 10.1111/cch.12981. PMID: 35112380. Exclusion Code: X2.35112380
366 Colmar SH. A parent-based book-reading intervention for disadvantaged children with language difficulties. Child Language Teaching and Therapy. 2013;30(1):79–90. doi: 10.1177/0265659013507296. PMID: 2014-04085-005. Exclusion Code: X8.
367 Leonard LB, Deevy P, Karpicke JD, Adjective learning in young typically developing children and children with developmental language disorder: a retrieval-based approach. J Speech Lang Hear Res. 2019 Dec 18;62(12):4433–49. doi: 10.1044/2019_JSLHR-L-19-0221. PMID: 31805241. Exclusion Code: X2.31805241
368 Boerma T, Blom E. Assessment of bilingual children: what if testing both languages is not possible? J Commun Disord. 2017 Mar;66:65–76. doi: 10.1016/j.jcomdis.2017.04.001. PMID: 28448800. Exclusion Code: X3.28448800
369 Roden I, Fruchtenicht K, Kreutz G, Auditory stimulation training with technically manipulated musical material in preschool children with specific language impairments: an explorative study. Front Psychol. 2019;10:2026. doi: 10.3389/fpsyg.2019.02026. PMID: 31551875. Exclusion Code: X5.31551875
370 Simon-Cereijido G, Gutiérrez-Clellen VF. Bilingual education for all: Latino dual language learners with language disabilities. International Journal of Bilingual Education and Bilingualism. 2013;17(2):235–54. doi: 10.1080/13670050.2013.866630. PMID: 2014-02468-007. Exclusion Code: X8.
371 Machová K, Kejdanová P, Bajtlerová I, Canine-assisted speech therapy for children with communication impairments: a randomized controlled trial. Anthrozoös. 2018;31(5):587–98. doi: 10.1080/08927936.2018.1505339. PMID: 2018-47209-006. Exclusion Code: X5.
372 McHenry MS, Oyungu E, Yang Z, Cultural adaptation of the Bayley Scales of Infant and Toddler Development, 3rd Edition for use in Kenyan children aged 18–36 months: a psychometric study. Res Dev Disabil. 2021 Mar;110:103837. doi: 10.1016/j.ridd.2020.103837. PMID: 33453695. Exclusion Code: X3.33453695
373 Helland T, Jones LØ, Helland W. Detecting preschool language impairment and risk of developmental dyslexia. Journal of Research in Childhood Education. 2017;31(2):295–311. doi: 10.1080/02568543.2016.1274928. PMID: 2017-15300-010. Exclusion Code: X2.
374 Haresabadi F, Ghasisin L, Schindler A, Developing and examining the psychometrics of single-word quick repetition test for speech sound production in Persian-speaking children. Iranian Rehabilitation Journal. 2020;18(4):465–74. doi: 10.32598/irj.18.4.1085.2. PMID: 2021-75784-006. Exclusion Code: X5.
375 Maleki ShahMahmood T, Ghayoumi-Anaraki Z, Ebadi A, Diagnostic accuracy of the Photographic Expressive Persian Grammar Test to identify 4–6 years old children with developmental language disorder. Iranian Rehabilitation Journal. 2020;18(3):345–54. doi: 10.32598/irj.18.3.1085.1. PMID: 2021-40399-013. Exclusion Code: X5.
376 Henderson DE. Dynamic assessment of narratives among Navajo Head Start children: ProQuest Information & Learning; 2018. Exclusion Code: X8.
377 Unhjem A, Eklund K, Nergård-Nilssen T. Early markers of language delay in children with and without family risk for dyslexia. First Language. 2015;35(3):254–71. doi: 10.1177/0142723715596122. PMID: 2015-36638-005. Exclusion Code: X6.
378 Tzuriel D, Isman EB, Klung T, Effects of teaching classification on classification, verbal conceptualization, and analogical reasoning in children with developmental language delays. Journal of Cognitive Education and Psychology. 2017;16(1):107–24. doi: 10.1891/1945-8959.16.1.107. PMID: 2017-08492-008. Exclusion Code: X2.
379 Schmoeger M, Deckert M, Eisenwort B, Evaluating Part V of the German version of the Token Test as a screening of specific language impairment in preschoolers. Applied Psycholinguistics. 2019;41(1):237–58. doi: 10.1017/s0142716419000493. PMID: 2020-05367-012. Exclusion Code: X6.
380 Gesture Guiberson M., play, and language development of Spanish-speaking toddlers with developmental language disorders. Communication Disorders Quarterly. 2015;37(2):88–99. doi: 10.1177/1525740114565816. PMID: 2015-57095-003. Exclusion Code: X4.
381 Visser L, Ruiter SA, Van der Meulen BF, Low verbal assessment with the Bayley-III. Res Dev Disabil. 2015 Jan;36C:230–43. doi: 10.1016/j.ridd.2014.09.014. PMID: 25462484. Exclusion Code: X3.25462484
382 Schiff R, Nuri Ben-Shushan Y, Ben-Artzi E. Metacognitive strategies. J Learn Disabil. 2017 Mar/Apr;50(2):143–57. doi: 10.1177/0022219415589847. PMID: 26054726. Exclusion Code: X4.26054726
383 Rescorla L, Turner HL. Morphology and syntax in late talkers at age 5. J Speech Lang Hear Res. 2015 Apr;58(2):434–44. doi: 10.1044/2015_JSLHR-L-14-0042. PMID: 25631704. Exclusion Code: X4.25631704
384 Gregg DE, Hart KC, Vaquerano S, Multidisciplinary early intervention for preschoolers with externalizing behavior problems and language impairment: results from an open trial. Journal of Psychopathology and Behavioral Assessment. 2021;43(3):506–17. doi: 10.1007/s10862-020-09865-w. PMID: 2021-23342-001. Exclusion Code: X5.
385 Keske-Soares M, Uberti LB, Gubiani MB, Performance of children with speech sound disorders in the dynamic evaluation of motor speech skills. Codas. 2018;30(2):e20170037. doi: 10.1590/2317-1782/20182017037. PMID: 29791618. Exclusion Code: X5.29791618
386 Davis E, Hodge M. Reliability and validity of TOCS-30 for young children with severe speech and expressive language delay. Canadian Journal of Speech-Language Pathology and Audiology. 2017;41(1):92–104. PMID: 2017-35464-005. Exclusion Code: X3.
387 Simón-Cereijido G. Sentence repetition in typical and atypical Spanish-speaking preschoolers who are English language learners. In: Benavides AA, Schwartz RG, eds. Language Development and Disorders in Spanish-speaking Children. Cham: Springer International Publishing; 2017:205–15. Exclusion Code: X3.
388 Blaži D, Balažinec M, Obučina H. Slušno procesiranje kod djece s jezičnim teškoćama = auditory processing in children with language impairment. Hrvatska Revija Za Rehabilitacijska Istraživanja. 2014;50(2):80–8. PMID: 2015-00127-006. Exclusion Code: X1.
389 Buiza JJ, Rodriguez-Parra MJ, Gonzalez-Sanchez M, Specific language impairment: evaluation and detection of differential psycholinguistic markers in phonology and morphosyntax in Spanish-speaking children. Res Dev Disabil. 2016 Nov;58:65–82. doi: 10.1016/j.ridd.2016.08.008. PMID: 27596962. Exclusion Code: X6.27596962
390 Ebert KD, Pham G. Synthesizing information from language samples and standardized tests in school-age bilingual assessment. Lang Speech Hear Serv Sch. 2017 Jan 1;48(1):42–55. doi: 10.1044/2016_LSHSS-16-0007. PMID: 28055056. Exclusion Code: X2.28055056
391 Rossi JC. The development and evaluation of a program of stimulation for preschool children with delayed motor or language development: ProQuest Information & Learning; 2022. Exclusion Code: X2.
392 Laasonen M, Smolander S, Lahti-Nuuttila P, Understanding developmental language disorder - the Helsinki longitudinal SLI study (HelSLI): a study protocol. BMC Psychol. 2018 May 21;6(1):24. doi: 10.1186/s40359-018-0222-7. PMID: 29784061. Exclusion Code: X8.29784061
393 Buzhardt J, Greenwood CR, Walker D, Web-based support for data-based decision making: effect of intervention implementation on infant–toddler communication. Journal of Early Intervention. 2018;40(3):246–67. doi: 10.1177/1053815118788059. PMID: 2018-40216-004. Exclusion Code: X2.
394 Dodd JL, Hagge DK. AAC camp as an alternative school-based service delivery model. Communication Disorders Quarterly. 2014;35(3):123–32. doi: 10.1177/1525740113512670. PMID: 2014-11285-001. Exclusion Code: X2.
395 Levy ES, Moya-Gale G, Chang YM, Effects of speech cues in French-speaking children with dysarthria. Int J Lang Commun Disord. 2020 May;55(3):401–16. doi: 10.1111/1460-6984.12526. PMID: 32077196. Exclusion Code: X2.32077196
396 Meyers CN. Investigation of treatment dose schedule for children with specific language impairment: ProQuest Information & Learning; 2016. Exclusion Code: X5.
397 McKean C, Law J, Mensah F, Predicting meaningful differences in school-entry language skills from child and family factors measured at 12 months of age. International Journal of Early Childhood. 2016;48(3):329–51. doi: 10.1007/s13158-016-0174-0. PMID: 2016-46215-001. Exclusion Code: X6.
398 Rowe ML, Leech KA. A parent intervention with a growth mindset approach improves children's early gesture and vocabulary development. Dev Sci. 2019 Jul;22(4):e12792. doi: 10.1111/desc.12792. PMID: 30570813. Exclusion Code: X2.30570813
399 Pooch A, Natale R, Hidalgo T. Ages and Stages Questionnaire: Social–Emotional as a teacher-report measure. Journal of Early Intervention. 2018;41(1):3–12. doi: 10.1177/1053815118795843. PMID: 2019-04297-001. Exclusion Code: X3.
400 Abel AD, Schuele CM, Arndt KB, Another look at the influence of maternal education on preschoolers’ performance on two norm-referenced measures. Communication Disorders Quarterly. 2016;38(4):231–41. doi: 10.1177/1525740116679886. PMID: 2017-31208-004. Exclusion Code: X5.
401 de Villiers J, Iglesias A, Golinkoff R, Assessing dual language learners of Spanish and English: development of the QUILS: ES. Revista de Logopedia, Foniatría y Audiología. 2021;41(4):183–96. doi: 10.1016/j.rlfa.2020.11.001. PMID: 2021-99405-004. Exclusion Code: X3.
402 Paul M. Can a short parent questionnaire be helpful for correctly identifying children with and without specific language impairment?: ProQuest Information & Learning; 2021. Exclusion Code: X6.
403 Yazejian N, Bryant DM, Hans S, Child and parenting outcomes after 1 year of Educare. Child Dev. 2017 Sep;88(5):1671–88. doi: 10.1111/cdev.12688. PMID: 28176302. Exclusion Code: X2.28176302
404 Rowley BA. Child behavioral rating scale kindergarten assessment: analysis of the Child Behavioral Rating Scale (CBRS): ProQuest Information & Learning; 2016. Exclusion Code: X3.
405 Trent E, Zamora I, Tyree A, Clinical considerations in the psychological assessment of bilingual young children. Professional Psychology: Research and Practice. 2018;49(3):234–46. doi: 10.1037/pro0000195. PMID: 2018-28691-007. Exclusion Code: X6.
406 Besner AC. Comparison of placement decisions based on picture naming 10 and picture naming 20: ProQuest Information & Learning; 2015. Exclusion Code: X3.
407 Greenwood CR, Buzhardt J, Walker D, Criterion validity of the early communication indicator for infants and toddlers. Assessment for Effective Intervention. 2019;45(4):298–310. doi: 10.1177/1534508418824154. PMID: 2020-60289-006. Exclusion Code: X6.
408 Felimban HS. Developmental and risk status of toddlers from Arab American families: what we know about families today: ProQuest Information & Learning; 2020. Exclusion Code: X4.
409 San Antonio MC, Fenick AM, Shabanova V, Developmental screening using the Ages and Stages Questionnaire. Infants & Young Children. 2014;27(2):111–9. doi: 10.1097/iyc.0000000000000005. PMID: 2014-10475-003. Exclusion Code: X6.
410 Staal II, van Stel HF, Hermanns JM, Early detection of parenting and developmental problems in young children: non-randomized comparison of visits to the well-baby clinic with or without a validated interview. Int J Nurs Stud. 2016 Oct;62:1–10. doi: 10.1016/j.ijnurstu.2016.07.001. PMID: 27423790. Exclusion Code: X6.27423790
411 Hansen BD, Wadsworth JP, Roberts MR, Effects of naturalistic instruction on phonological awareness skills of children with intellectual and developmental disabilities. Res Dev Disabil. 2014 Nov;35(11):2790–801. doi: 10.1016/j.ridd.2014.07.011. PMID: 25086428. Exclusion Code: X2.25086428
412 Roberts MY, Kaiser AP, Wolfe CE, Effects of the teach-model-coach-review instructional approach on caregiver use of language support strategies and children's expressive language skills. J Speech Lang Hear Res. 2014 Oct;57(5):1851–69. doi: 10.1044/2014_JSLHR-L-13-0113. PMID: 24950492. Exclusion Code: X5.24950492
413 Murray E, Fernandes M, Newton CR J, Evaluation of the INTERGROWTH-21st Neurodevelopment Assessment (INTER-NDA) in 2 year-old children. PLoS One. 2018;13(2):e0193406. doi: 10.1371/journal.pone.0193406. PMID: 29489865. Exclusion Code: X5.29489865
414 Marshall J, Raffaele Mendez LM. Following up on community-based developmental screening. Infants & Young Children. 2014;27(4):276–91. doi: 10.1097/iyc.0000000000000019. PMID: 2014-37315-002. Exclusion Code: X6.
415 Silver RB, Newland RP, Hartz K, Integrating early childhood screening in pediatrics: a longitudinal qualitative study of barriers and facilitators. Clinical Practice in Pediatric Psychology. 2017;5(4):426–40. doi: 10.1037/cpp0000214 10.1037/cpp0000214.supp (Supplemental). PMID: 2017-55264-012. Exclusion Code: X8.
416 Paul MJ, Thordardottir ET. Investigation of the psychometric properties of the milestones en Français du Québec, a new language screener for French-speaking children between 12 and 71 months. Canadian Journal of Speech-Language Pathology and Audiology. 2019;43(2):133–52. PMID: 2019-65932-005. Exclusion Code: X6.
417 Gilkerson J, Richards JA, Greenwood CR, Language assessment in a snap: monitoring progress up to 36 months. Child Language Teaching and Therapy. 2016;33(2):99–115. doi: 10.1177/0265659016660599. PMID: 2017-25677-002. Exclusion Code: X5.
418 Gardner-Neblett N, DeCoster J, Hamre BK. Linking preschool language and sustained attention with adolescent achievement through classroom self-reliance. Journal of Applied Developmental Psychology. 2014;35(6):457–67. doi: 10.1016/j.appdev.2014.09.003. PMID: 2014-54686-001. Exclusion Code: X3.
419 Sprunt B, Marella M. Measurement accuracy: enabling human rights for Fijian students with speech difficulties. Int J Speech Lang Pathol. 2018 Feb;20(1):89–97. doi: 10.1080/17549507.2018.1428685. PMID: 29466096. Exclusion Code: X3.29466096
420 Karaaslan O, Mahoney G. Mediational analyses of the effects of responsive teaching on the developmental functioning of preschool children with disabilities. Journal of Early Intervention. 2015;37(4):286–99. doi: 10.1177/1053815115617294. PMID: 2015-57205-003. Exclusion Code: X2.
421 Rubio-Codina M, Grantham-McGregor S. Predictive validity in middle childhood of short tests of early childhood development used in large scale studies compared to the Bayley-III, the Family Care Indicators, height-for-age, and stunting: a longitudinal study in Bogota, Colombia. PLoS One. 2020;15(4):e0231317. doi: 10.1371/journal.pone.0231317. PMID: 32348359. Exclusion Code: X5.32348359
422 Hungerford GM, Garcia D, Bagner DM. Psychometric evaluation of the Brief Infant-Toddler Social and Emotional Assessment (BITSEA) in a predominately Hispanic, low-income sample. J Psychopathol Behav Assess. 2015 Sep;37(3):493–503. doi: 10.1007/s10862-015-9478-x. PMID: 26379368. Exclusion Code: X3.26379368
423 Thomas RE, Spragins W, Mazloum G, Rates of detection of developmental problems at the 18-month well-baby visit by family physicians' using four evidence-based screening tools compared to usual care: a randomized controlled trial. Child Care Health Dev. 2016 May;42(3):382–93. doi: 10.1111/cch.12333. PMID: 27061302. Exclusion Code: X5.27061302
424 Bonifacci P, Mari R, Gabbianelli L, Sequential bilingualism and specific language impairment: the Italian version of ALDeQ Parental Questionnaire. Applied Psychology Bulletin. 2016;275(64):50–63. PMID: 2016-22117-005. Exclusion Code: X5.
425 Forbush Romero M, Petersen DB, Long A, The accuracy of a Spanish dynamic assessment of narrative language in identifying developmental language disorder: a cross validation study. Revista de Logopedia, Foniatría y Audiología. 2021;41(4):172–82. doi: 10.1016/j.rlfa.2021.05.008. PMID: 2021-99405-003. Exclusion Code: X2.
426 Ching TY C, Saetre-Turner M, Harkus S, The Hearing and Talking Scale (HATS): development and validation with young Aboriginal and Torres Strait Islander children in urban and remote settings in Australia. Deafness & Education International. 2020;22(4):305–24. doi: 10.1080/14643154.2020.1830241. PMID: 2020-83124-005. Exclusion Code: X3.
427 Girbau D. The non-word repetition task as a clinical marker of specific language impairment in Spanish-speaking children. First Language. 2016;36(1):30–49. doi: 10.1177/0142723715626069. PMID: 2016-18080-002. Exclusion Code: X2.
428 Nag S, Snowling MJ, MirkoviĆ J. The role of language production mechanisms in children's sentence repetition: evidence from an inflectionally rich language. Applied Psycholinguistics. 2017;39(2):303–25. doi: 10.1017/s0142716417000200. PMID: 2017-31303-001. Exclusion Code: X2.
429 Barnes EM, Dickinson DK, Grifenhagen JF. The role of teachers’ comments during book reading in children's vocabulary growth. The Journal of Educational Research. 2016;110(5):515–27. doi: 10.1080/00220671.2015.1134422. PMID: 2017-22116-007. Exclusion Code: X4.
430 Auza Benavides A, Kapantzoglou M, Murata C. Two grammatical tasks for screening language abilities in Spanish-speaking children. Am J Speech Lang Pathol. 2018 May 3;27(2):690–705. doi: 10.1044/2017_AJSLP-17-0052. PMID: 29554217. Exclusion Code: X2.29554217
431 Springer PE, Kalk E, Pretorius C, Value of the Goodenough Drawing Test as a research tool to detect developmental delay in South African preschool children. South African Journal of Psychology. 2019;50(1):81–91. doi: 10.1177/0081246319850683. PMID: 2020-20055-009. Exclusion Code: X3.
432 DeVeney SL, Hagaman JL, Bjornsen AL. Parent-implemented versus clinician-directed interventions for late-talking toddlers: a systematic review of the literature. Communication Disorders Quarterly. 2017;39(1):293–302. doi: 10.1177/1525740117705116. PMID: 2017-45517-005. Exclusion Code: X8.
433 Loudermill C, Greenwell T, Brosseau-Lapre F. A comprehensive treatment approach to address speech production and literacy skills in school-age children with speech sound disorders. Semin Speech Lang. 2021 Mar;42(2):136–46. doi: 10.1055/s-0041-1723840. PMID: 33725731. Exclusion Code: X8.33725731
434 Gibbard D, Smith C. A transagency approach to enabling access to parent-based intervention for language delay in areas of social disadvantage: a service evaluation. Child Language Teaching and Therapy. 2015;32(1):19–33. doi: 10.1177/0265659014567785. PMID: 2016-03016-003. Exclusion Code: X5.
435 Schmitt MB. Active ingredients of speech-language therapy in the public schools for children with language impairment: ProQuest Information & Learning; 2015. Exclusion Code: X8.
436 Guiberson M. Alternatives to traditional language sample measures with emergent bilingual preschoolers. Top Lang Disord. 2020 Apr-Jun;40(2):E1–E6. doi: 10.1097/tld.0000000000000208. PMID: 33446944. Exclusion Code: X6.33446944
437 Scheidnes M, Tuller L. Assessing successive bilinguals in two languages: a longitudinal look at English-speaking children in France. J Commun Disord. 2016 Nov-Dec;64:45–61. doi: 10.1016/j.jcomdis.2016.10.001. PMID: 27973321. Exclusion Code: X2.27973321
438 Pena ED, Gillam RB, Bedore LM. Dynamic assessment of narrative ability in English accurately identifies language impairment in English language learners. J Speech Lang Hear Res. 2014 Dec;57(6):2208–20. doi: 10.1044/2014_JSLHR-L-13-0151. PMID: 25075793. Exclusion Code: X2.25075793
439 Lourenco I, Rocha J, Peixoto V, Effects of the Narrative Intervention Program for preschool Portuguese children. Folia Phoniatr Logop. 2020;72(3):211–7. doi: 10.1159/000496793. PMID: 30999303. Exclusion Code: X8.30999303
440 Vugs B, Knoors H, Cuperus J, Executive function training in children with SLI: a pilot study. Child Language Teaching and Therapy. 2016;33(1):47–66. doi: 10.1177/0265659016667772. PMID: 2017-06811-005. Exclusion Code: X2.
441 Bruinsma G, Wijnen F, Gerrits E. Focused stimulation intervention in 4- and 5-year-old children with developmental language disorder: exploring implementation in clinical practice. Lang Speech Hear Serv Sch. 2020 Apr 7;51(2):247–69. doi: 10.1044/2020_LSHSS-19-00069. PMID: 32255743. Exclusion Code: X5.32255743
442 Matić A, Kraljević JK, Belić LK, Group-based direct and indirect approaches to language therapy for children with developmental language disorder: A pre-experimental study. Klinička Psihologija. 2018;Vo 11(1–2):21–38. PMID: 2019-35774-002. Exclusion Code: X5.
443 Hubert-Dibon G, Bru M, Gras Le Guen C, Health-related quality of life for children and adolescents with specific language impairment: a cohort study by a learning disabilities reference center. PLoS One. 2016;11(11):e0166541. doi: 10.1371/journal.pone.0166541. PMID: 27851795. Exclusion Code: X2.27851795
444 Lazewnik R. Identifiers of bilingual Spanish-English speaking children with language impairment: ProQuest Information & Learning; 2014. Exclusion Code: X5.
445 Lazewnik R, Creaghead NA, Smith AB, Identifiers of language impairment for Spanish-English dual language learners. Lang Speech Hear Serv Sch. 2019 Jan 28;50(1):126–37. doi: 10.1044/2018_LSHSS-17-0046. PMID: 30521665. Exclusion Code: X5.30521665
446 Hadley PA, Rispoli M, Holt JK. Input subject diversity accelerates the growth of tense and agreement: indirect benefits from a parent-implemented intervention. J Speech Lang Hear Res. 2017 Sep 18;60(9):2619–35. doi: 10.1044/2017_JSLHR-L-17-0008. PMID: 28892819. Exclusion Code: X2.28892819
447 Kalashnikova IV, Gontar OB, Zhirov VK, Integrated animal-assisted and plant-assisted ecotherapy for preschool children with speech disturbances: a program for the Arctic. Ecopsychology. 2016;8(2):79–88. doi: 10.1089/eco.2016.0002. PMID: 2016-32061-002. Exclusion Code: X8.
448 Fierro V. Interactive book reading to accelerate word learning in bilingual children with specific language impairment: ProQuest Information & Learning; 2018. Exclusion Code: X5.
449 Acosta-Rodriguez VM, Ramirez-Santana GM, Hernandez Exposito S, Intervention in syntactic skills in pupils with developmental language disorder. Psicothema. 2020 Nov;32(4):541–8. doi: 10.7334/psicothema2020.160. PMID: 33073760. Exclusion Code: X8.33073760
450 Justice LM, Logan J, Kaderavek JN. Longitudinal impacts of print-focused read-alouds for children with language impairment. Am J Speech Lang Pathol. 2017 May 17;26(2):383–96. doi: 10.1044/2016_AJSLP-15-0200. PMID: 28389676. Exclusion Code: X5.28389676
451 Buschmann A, Multhauf B, Hasselhorn M, Long-term effects of a parent-based language intervention on language outcomes and working memory for late-talking toddlers. Journal of Early Intervention. 2015;37(3):175–89. doi: 10.1177/1053815115609384. PMID: 2015-51440-001. Exclusion Code: X8.
452 Chong WH, Moore DW, Nonis KP, Mission I'm Possible. Infants & Young Children. 2014;27(1):60–73. doi: 10.1097/IYC.0b013e3182a60281. PMID: 2013-44789-005. Exclusion Code: X2.
453 Vogt S, Kauschke C. Observing iconic gestures enhances word learning in typically developing children and children with specific language impairment. J Child Lang. 2017 Nov;44(6):1458–84. doi: 10.1017/S0305000916000647. PMID: 28112055. Exclusion Code: X4.28112055
454 Washington KN, Thomas-Stonell N, McLeod S, Outcomes and predictors in preschoolers with speech-language and/or developmental mobility impairments. Child Language Teaching and Therapy. 2014;31(2):141–57. doi: 10.1177/0265659014539689. PMID: 2015-24868-002. Exclusion Code: X5.
455 Te Kaat‐van den Os DJA, Jongmans MJ, Volman MJM, Parent-implemented language interventions for children with a developmental delay: a systematic review. Journal of Policy and Practice in Intellectual Disabilities. 2017;14(2):129–37. doi: 10.1111/jppi.12181. PMID: 2017-25505-001. Exclusion Code: X8.
456 Simon-Cereijido G. Preschool language interventions for Latino dual language learners with language disorders: what, in what language, and how. Semin Speech Lang. 2015 May;36(2):154–64. doi: 10.1055/s-0035-1549110. PMID: 25923000. Exclusion Code: X8.25923000
457 Sugden E, Baker E, Munro N, Service delivery and intervention intensity for phonology-based speech sound disorders. Int J Lang Commun Disord. 2018 Jul;53(4):718–34. doi: 10.1111/1460-6984.12399. PMID: 29900638. Exclusion Code: X8.29900638
458 Dockrell J, Lindsay G, Roulstone S, Supporting children with speech, language and communication needs: an overview of the results of the Better Communication Research Programme. Int J Lang Commun Disord. 2014 Sep-Oct;49(5):543–57. doi: 10.1111/1460-6984.12089. PMID: 24961589. Exclusion Code: X8.24961589
459 Szelag E, Dacewicz A, Szymaszek A, The application of timing in therapy of children and adults with language disorders. Front Psychol. 2015;6:1714. doi: 10.3389/fpsyg.2015.01714. PMID: 26617547. Exclusion Code: X8.26617547
460 Heikkilä J, Lonka E, Meronen A, The effect of audiovisual speech training on the phonological skills of children with specific language impairment (SLI). Child Language Teaching and Therapy. 2018;34(3):269–87. doi: 10.1177/0265659018793697. PMID: 2018-61720-005. Exclusion Code: X2.
461 Abdul Aziz S, Fletcher J, Bayliss DM. The effectiveness of self-regulatory speech training for planning and problem solving in children with specific language impairment. J Abnorm Child Psychol. 2016 Aug;44(6):1045–59. doi: 10.1007/s10802-015-0115-7. PMID: 26678398. Exclusion Code: X5.26678398
462 Heidlage JK, Cunningham JE, Kaiser AP, The effects of parent-implemented language interventions on child linguistic outcomes: a meta-analysis. Early Childhood Research Quarterly. 2020;50(Part 1):6–23. doi: 10.1016/j.ecresq.2018.12.006. PMID: 2019-28196-001. Exclusion Code: X8.
463 Gridley N, Hutchings J, Baker-Henningham H. The Incredible Years Parent-Toddler Programme and parental language: a randomised controlled trial. Child Care Health Dev. 2015 Jan;41(1):103–11. doi: 10.1111/cch.12153. PMID: 24841947. Exclusion Code: X2.24841947
464 Manz PH, Bracaliello CB, Pressimone VJ, Toddlers' expressive vocabulary outcomes after one year of Parent–Child Home Program services. Early Child Development and Care. 2015;186(2):229–48. doi: 10.1080/03004430.2015.1025228. PMID: 2016-04585-002. Exclusion Code: X2.
465 Riccelli-Sherman A. Using a core vocabulary intervention to improve communication of students who use augmentative and alternative communication (AAC): ProQuest Information & Learning; 2018. Exclusion Code: X5.
466 Roberts MY. Using empirical benchmarks to assess the effects of a parent-implemented language intervention for children with language impairments: ProQuest Information & Learning; 2014. Exclusion Code: X11.
467 Sedgwick A, Stothard J. A systematic review of school-based, mainstream, oral language interventions for key stage 1 children. Support Learn. 2018 11/01/;33(4):360–87. PMID: EJ1203685. Exclusion Code: X8.
468 Saad MA E. Are phonological awareness intervention programs effective for children with disabilities? a systematic review. IJPES. 2017 12/01/;6(3):11–20. PMID: EJ1254629. Exclusion Code: X8.
469 Licandro U, Pearson. Bilingual vocabulary support for dual language learners: a systematic review. EBP Briefs. Volume 12, Issue 6 EBP Briefs (Evidence-based Practice Briefs). 2018. Exclusion Code: X8.
470 Weil LW, Schuele CM, Pearson. Complex syntax interventions for young children with language impairments. EBP Briefs. Volume 13, Issue 5 EBP Briefs (Evidence-based Practice Briefs). 2019. Exclusion Code: X8.
471 Roepke E, Greenwell T, Brosseau-Lapré F, Service delivery for children with speech sound disorders: evidence for the Quick Articulation! Model. EBP Briefs. Volume 14, Issue 2 EBP Briefs (Evidence-based Practice Briefs). 2019. Exclusion Code: X8.
472 Harvey H, Allaway H, Jones S. The effectiveness of therapies for dual language children with developmental language disorder: a systematic review of interventional studies. Int J Biling Educ Biling. 2021 01/01/;24(7):1043–64. PMID: EJ1306848. Exclusion Code: X8.
473 Ullrich D, Marten M. Aspects concerning "play" for the promotion of preschool children with severe speech- and language impairment. Education Sciences. 2016 01/01/;6PMID: EJ1116875. Exclusion Code: X2.
474 Motsch H-J, Marks D-K. Efficacy of the Lexicon Pirate strategy therapy for improving lexical learning in school-age children: a randomized controlled trial. Child Lang Teach Ther. 2015 06/01/;31(2):237–55. PMID: EJ1063517. Exclusion Code: X2.
475 Brassart E, Schelstraete M-A. Enhancing the communication abilities of preschoolers at risk for behavior problems: effectiveness of a parent-implemented language intervention. Infants Young Child. 2015 01/01/;28(4):337–54. PMID: EJ1074045. Exclusion Code: X2.
476 Glisson L, Leitão S, Claessen M. Evaluating the efficacy of a small-group oral narrative intervention programme for pre-primary children with narrative difficulties in a mainstream school setting. Aust. J Learn Difficulties. 2019 01/01/;24(1):1–20. PMID: EJ1216912. Exclusion Code: X5.
477 Gillon G, McNeill B, Denston A, Evidence-based class literacy instruction for children with speech and language difficulties. Top Lang Disord. 2020 01/01/;40(4):357–74. PMID: EJ1283683. Exclusion Code: X2.
478 Kim Y-SG, Phillips B. Five minutes a day to improve comprehension monitoring in oral language contexts: an exploratory intervention study with prekindergartners from low-income families. Top Lang Disord. 2016 01/01/;36(4):356–67. PMID: ED575735. Exclusion Code: X2.
479 Fabiano-Smith L, Privette C, An L. Phonological measures for bilingual Spanish-English-speaking preschoolers: the language combination effect. J Speech Lang Hear Res. 2021 Oct 4;64(10):3942–68. doi: 10.1044/2021_JSLHR-21-00008. PMID: 34546768. Exclusion Code: X3.34546768
480 Thurston A, Education Endowment F, Queen's University Belfast CfEE. Talk of the town: evaluation report and executive summary Education Endowment Foundation. 2016. Exclusion Code: X2.
481 Buzhardt J, Greenwood CR, Jia F, Technology to guide data-driven intervention decisions: effects on language growth of young children at risk for language delay. Except Child. 2020 10/01/;87(1):74–91. PMID: EJ1273994. Exclusion Code: X5.
482 Lowe R, O'Brian S, Onslow M. Review of telehealth stuttering management. Folia Phoniatr Logop. 2013 Jul 2014 2018-10-06;65(5):223–38. doi: 10.1159/000357708. PMID: 24504075. Exclusion Code: X8.24504075
483 Guiberson M, Rodriguez BL. Measurement properties and classification accuracy of two Spanish parent surveys of language development for preschool-age children. Am J Speech Lang Pathol. 2010 Aug;19(3):225–37. doi: 10.1044/1058-0360(2010/09-0058). PMID: 20484705. Exclusion Code: X2.20484705
484 Guiberson M, Rodriguez BL, Dale PS. Classification accuracy of brief parent report measures of language development in Spanish-speaking toddlers. Lang Speech Hear Serv Sch. 2011 Oct;42(4):536–49. doi: 10.1044/0161-1461(2011/10-0076). PMID: 21844403. Exclusion Code: X2.21844403
485 Heilmann J, Ellis Weismer S, Evans J, Utility of the MacArthur-Bates communicative development inventory in identifying language abilities of late-talking and typically developing toddlers. Am J Speech Lang Pathol. 2005 Feb;14(1):40–51. doi: 10.1044/1058-0360(2005/006). PMID: 15966111. Exclusion Code: X2.15966111
486 Rigby MJ, Chesham I. A trial speech screening test for school entrants. Br Med J (Clin Res Ed). 1981 Feb 7;282(6262):449–51. doi: 10.1136/bmj.282.6262.449. PMID: 6780069. Exclusion Code: X5.6780069
487 Westerlund M, Berglund E, Eriksson M. Can severely language delayed 3-year-olds be identified at 18 months? Evaluation of a screening version of the MacArthur-Bates Communicative Development Inventories. J Speech Lang Hear Res. 2006 Apr;49(2):237–47. doi: 10.1044/1092-4388(2006/020). PMID: 16671841. Exclusion Code: X5.16671841
488 Borowitz KC, Glascoe FP. Sensitivity of the Denver Developmental Screening Test in speech and language screening. Pediatrics. 1986 Dec;78(6):1075–8. PMID: 3786032. Exclusion Code: X2.3786032
489 Burden V, Stott CM, Forge J, The Cambridge Language and Speech Project (CLASP). I. Detection of language difficulties at 36 to 39 months. Dev Med Child Neurol. 1996 Jul;38(7):613–31. doi: 10.1111/j.1469-8749.1996.tb12126.x. PMID: 8674912. Exclusion Code: X2.8674912
490 Rescorla L. The Language Development Survey: a screening tool for delayed language in toddlers. J Speech Hear Disord. 1989 Nov;54(4):587–99. doi: 10.1044/jshd.5404.587. PMID: 2811339. Exclusion Code: X2.2811339
491 Rescorla L, Alley A. Validation of the language development survey (LDS): a parent report tool for identifying language delay in toddlers. J Speech Lang Hear Res. 2001 Apr;44(2):434–45. doi: 10.1044/1092-4388(2001/035). PMID: 11324663. Exclusion Code: X5.11324663
492 Ward S. Detecting abnormal auditory behaviours in infancy: the relationship between such behaviours and linguistic development. Br J Disord Commun. 1984 Dec;19(3):237–51. doi: 10.3109/13682828409029839. PMID: 6508994. Exclusion Code: X3.6508994
493 Fricke S, Bowyer-Crane C, Haley AJ, Efficacy of language intervention in the early years. J Child Psychol Psychiatry. 2013 Mar;54(3):280–90. doi: 10.1111/jcpp.12010. PMID: 23176547. Exclusion Code: X2.23176547
494 Morgan AT, Vogel AP. A Cochrane review of treatment for childhood apraxia of speech. Eur J Phys Rehabil Med. 2009 Mar;45(1):103–10. PMID: 19156019. Exclusion Code: X8.19156019
495 Shelton RL, Johnson AF, Ruscello DM, Assessment of parent-administered listening training for preschool children with articulation deficits. J Speech Hear Disord. 1978 May;43(2):242–54. doi: 10.1044/jshd.4302.242. PMID: 661262. Exclusion Code: X4.661262
496 Yoder P, Camarata S, Gardner E. Treatment effects on speech intelligibility and length of utterance in children with specific language and intelligibility impairments. Journal of Early Intervention. 2005;28(1):34–49. doi: 10.1177/105381510502800105. Exclusion Code: X5.
497 So KK H, To CK S. Systematic review and meta-analysis of screening tools for language disorder. Front Pediatr. 2022;10:801220. doi: 10.3389/fped.2022.801220. PMID: 35281230. Exclusion Code: X8.35281230
498 Ramos MN, Collins P, Peña ED. Sharpening our tools: a systematic review to identify diagnostically accurate language sample measures. J Speech Lang Hear Res. 2022 Oct 17;65(10):3890–907. doi: 10.1044/2022_JSLHR-22-00121. PMID: 36174208. Exclusion Code: X8.36174208
499 Lorio CM, Carta JJ, Stephens N. Exploring language development support for foster children: a scoping review of interventions for foster care families. Am J Speech Lang Pathol. 2023 Jan 11;32(1):358–76. doi: 10.1044/2022_AJSLP-22-00082. PMID: 36538503. Exclusion Code: X8.36538503
500 Ávila N, Juste F, Costa JB, Treatment clinical trial - three types - for children with fluency disorders and stuttering. Codas. 2021;34(2):e20200264. doi: 10.1590/2317-1782/20212020264. PMID: 34705998. Exclusion Code: X5.34705998
501 Taha J, Stojanovik V, Pagnamenta E. Sentence repetition as a clinical marker of developmental language disorder: evidence from Arabic. J Speech Lang Hear Res. 2021 Dec 13;64(12):4876–99. doi: 10.1044/2021_JSLHR-21-00244. PMID: 34780284. Exclusion Code: X5.34780284
502 Davidson R, Randhawa G. The Sign 4 Big Feelings intervention to improve early years outcomes in preschool children: outcome evaluation. JMIR Pediatr Parent. 2022 May 20;5(2):e25086. doi: 10.2196/25086. PMID: 35594062. Exclusion Code: X2.35594062
503 Jensen de López KM, Kraljević JK, Struntze EL B. Efficacy, model of delivery, intensity and targets of pragmatic interventions for children with developmental language disorder: a systematic review. Int J Lang Commun Disord. 2022 Jul;57(4):764–81. doi: 10.1111/1460-6984.12716. PMID: 35445482. Exclusion Code: X8.35445482
504 Schmitt MB, Tambyraja S, Siddiqui S. Peer effects in language therapy for preschoolers with developmental language disorder: a pilot study. Am J Speech Lang Pathol. 2022 Jul 12;31(4):1854–67. doi: 10.1044/2022_AJSLP-21-00313. PMID: 35452261. Exclusion Code: X5.35452261
505 Navarro-Zambrana AN, Sheets LR. Ethnic and national differences in congenital adrenal hyperplasia incidence: a systematic review and meta-analysis. Horm Res Paediatr. 2023 Aug 16;96(3):249–58. doi: 10.1159/000526401. PMID: 35973409. Exclusion Code: X2.35973409
506 Finestack LH, Elmquist M, Kuchler K, Caregiver-implemented communication interventions for children identified as having language impairment 0 through 48 months of age: a scoping review. J Speech Lang Hear Res. 2022 Aug 17;65(8):3004–55. doi: 10.1044/2022_JSLHR-21-00543. PMID: 35858263. Exclusion Code: X8.35858263
507 Yi A, Chen Z, Ling W, Effectiveness of cloud-based rehabilitation in children with developmental language disorder during the COVID-19 pandemic: a prospective cohort study. Medicine (Baltimore). 2022 Aug 19;101(33):e30056. doi: 10.1097/MD.0000000000030056. PMID: 35984120. Exclusion Code: X5.35984120
508 Alolama FM, Mohammad HM, Alhmid IH, Designing and validating the Dubai Tool for Developmental Screening (DTDS). Front Pediatr. 2022;10:924017. doi: 10.3389/fped.2022.924017. PMID: 36071880. Exclusion Code: X5.36071880
509 Tribushinina E, Niemann G, Meuwissen J, Teaching foreign language grammar to primary-school children with developmental language disorder: a classroom-based intervention study. J Commun Disord. 2022 Nov-Dec;100:106269. doi: 10.1016/j.jcomdis.2022.106269. PMID: 36191574. Exclusion Code: X2.36191574
510 Pomper R, McGregor KK, Arbisi-Kelm T, Direct instruction improves word learning for children with developmental language disorder. J Speech Lang Hear Res. 2022 Nov 17;65(11):4228–49. doi: 10.1044/2022_JSLHR-22-00300. PMID: 36342854. Exclusion Code: X5.36342854
511 Esfandbod A, Rokhi Z, Meghdari AF, Utilizing an emotional robot capable of lip-syncing in robot-assisted speech therapy sessions for children with language disorders. Int J Soc Robot. 2023 Nov 23;15(2):165–83. doi: 10.1007/s12369-022-00946-2. PMID: 36467283. Exclusion Code: X9.36467283
512 Kas B, Jakab Z, Lőrik J. Development and norming of the Hungarian CDI-III: a screening tool for language delay. Int J Lang Commun Disord. 2022 Mar;57(2):252–73. doi: 10.1111/1460-6984.12686. PMID: 34997807. Exclusion Code: X5.34997807
513 Holzinger D, Weber C, Jezek M. Identifying language disorder within a migration context: development and performance of a pre-school screening tool for children with German as a second language. Front Pediatr. 2022;10:814415. doi: 10.3389/fped.2022.814415. PMID: 35345610. Exclusion Code: X3.35345610
514 Prentza A, Tafiadis D, Chondrogianni V, Validation of a Greek sentence repetition task with typically developing monolingual and bilingual children. J Psycholinguist Res. 2022 Apr;51(2):373–95. doi: 10.1007/s10936-022-09853-z. PMID: 35286538. Exclusion Code: X2.35286538
515 Qian L, Shao H, Fang H, Reliability, validity and developmental sensitivity of the Language Use Inventory (LUI) in the Chinese context. Int J Lang Commun Disord. 2022 May;57(3):497–511. doi: 10.1111/1460-6984.12693. PMID: 34984773. Exclusion Code: X2.34984773
516 Eikerling MR, Bloder TS, Lorusso ML. A nonword repetition task discriminates typically developing Italian-German bilingual children from bilingual children with developmental language disorder: the role of language-specific and language-nonspecific nonwords. Front Psychol. 2022;13:826540. doi: 10.3389/fpsyg.2022.826540. PMID: 35719570. Exclusion Code: X3.35719570
517 Capodieci A, Romano M, Castro E, Executive functions and rapid automatized naming: a new tele-rehabilitation approach in children with language and learning disorders. Children (Basel). 2022 Jun 2;9(6)doi: 10.3390/children9060822. PMID: 35740759. Exclusion Code: X2.35740759
518 Holzinger D, Weber C, Diendorfer B. Development and validation of a language screening for implementation in pre-school settings. Front Public Health. 2022;10:866598. doi: 10.3389/fpubh.2022.866598. PMID: 35812510. Exclusion Code: X3.35812510
519 Grasso M, Lazzaro G, Demaria F, The Strengths and Difficulties Questionnaire as a valuable screening tool for identifying core symptoms and behavioural and emotional problems in children with neuropsychiatric disorders. Int J Environ Res Public Health. 2022 Jun 23;19(13)doi: 10.3390/ijerph19137731. PMID: 35805390. Exclusion Code: X2.35805390
520 Giangiacomo E, Visaggi MC, Aceti F, Early neuro-psychomotor therapy intervention for theory of mind and emotion recognition in neurodevelopmental disorders: a pilot study. Children (Basel). 2022 Jul 29;9(8)doi: 10.3390/children9081142. PMID: 36010032. Exclusion Code: X2.36010032
521 Lieberman M, Sand A, Lohmander A, Asking parents about babbling at 10 months produced valid answers but did not predict language screening result 2 years later. Acta Paediatr. 2022 Oct;111(10):1914–20. doi: 10.1111/apa.16486. PMID: 35837842. Exclusion Code: X3.35837842
522 Fernandes M, Bassani D, Albernaz E, Construction and validation of the Oxford Neurodevelopment Assessment (OX-NDA) in 1-year-old Brazilian children. BMC Pediatr. 2022 Dec 23;22(1):733. doi: 10.1186/s12887-022-03794-1. PMID: 36564728. Exclusion Code: X5.36564728
523 Rah SS, Jung M, Lee K, Systematic review and meta-analysis: real-world accuracy of children's developmental screening tests. J Am Acad Child Adolesc Psychiatry. 2023 Oct;62(10):1095–109. doi: 10.1016/j.jaac.2022.12.014. PMID: 36592715. Exclusion Code: X8.36592715
524 Wang D, Zheng L, Lin Y, Sentence repetition as a clinical marker for Mandarin-speaking preschoolers with developmental language disorder. J Speech Lang Hear Res. 2022 Apr 4;65(4):1543–60. doi: 10.1044/2021_JSLHR-21-00401. PMID: 35320679. Exclusion Code: X9.35320679
525 Rose K, Armon-Lotem S, Altman C. Profiling bilingual children: using monolingual assessment to inform diagnosis. Lang Speech Hear Serv Sch. 2022 Apr 11;53(2):494–510. doi: 10.1044/2021_LSHSS-21-00099. PMID: 35167343. Exclusion Code: X3.35167343
526 Dockrell JE, Forrest CL, Law J, Screening for language difficulties in disadvantaged populations on entry to early years education: challenges and opportunities. Front Pediatr. 2022;10:833603. doi: 10.3389/fped.2022.833603. PMID: 35601421. Exclusion Code: X3.35601421
527 Borkhoff CM, Atalla M, Bayoumi I, Predictive validity of the Infant Toddler Checklist in primary care at the 18-month visit and developmental diagnosis at 3–5 years: a prospective cohort study. BMJ Paediatr Open. 2022 Jun;6(1)doi: 10.1136/bmjpo-2022-001524. PMID: 36053584. Exclusion Code: X2.36053584
528 Eriksson M. Insufficient evidence for the validity of the Language Development Survey and the MacArthur-Bates Communicative Development Inventories as screening tools: a critical review. Int J Lang Commun Disord. 2023 Mar;58(2):555–75. doi: 10.1111/1460-6984.12800. PMID: 36370048. Exclusion Code: X8.36370048
529 Altman C, Harel E, Meir N, Using a monolingual screening test for assessing bilingual children. Clin Linguist Phon. 2022 Dec 2;36(12):1132–52. doi: 10.1080/02699206.2021.2000644. PMID: 34844504. Exclusion Code: X3.34844504
530 Subasi M, Van Borsel J, Van Eerdenbrugh S. The Lidcombe Program for early stuttering in non-English-speaking countries: a systematic review. Folia Phoniatr Logop. 2022;74(2):89–102. doi: 10.1159/000517650. PMID: 34289470. Exclusion Code: X8.34289470
531 van Tellingen M, Hurkmans J, Terband H, Music and musical elements in the treatment of childhood speech sound disorders: a systematic review of the literature. Int J Speech Lang Pathol. 2023 Aug;25(4):549–65. doi: 10.1080/17549507.2022.2097310. PMID: 35900281. Exclusion Code: X8.35900281
532 Laiho A, Elovaara H, Kaisamatti K, Stuttering interventions for children, adolescents, and adults: a systematic review as a part of clinical guidelines. J Commun Disord. 2022 Sep-Oct;99:106242. doi: 10.1016/j.jcomdis.2022.106242. PMID: 35751980. Exclusion Code: X8.35751980
533 Carson L, Baker E, Munro N. A systematic review of interventions for late talkers: intervention approaches, elements, and vocabulary outcomes. Am J Speech Lang Pathol. 2022 Nov 16;31(6):2861–74. doi: 10.1044/2022_AJSLP-21-00168. PMID: 36251872. Exclusion Code: X8.36251872
534 Kk Nair V, Clark GT, Siyambalapitiya S, Language intervention in bilingual children with developmental language disorder: a systematic review. Int J Lang Commun Disord. 2023 Mar;58(2):576–600. doi: 10.1111/1460-6984.12803. PMID: 36428270. Exclusion Code: X8.36428270
535 Attwell GA, Bennin KE, Tekinerdogan B. A systematic review of online speech therapy systems for intervention in childhood speech communication disorders. Sensors (Basel). 2022 Dec 11;22(24)doi: 10.3390/s22249713. PMID: 36560082. Exclusion Code: X8.36560082
536 Dodge-Chin C, Shigetomi-Toyama S, Quinn ED. Teaching parents read, ask, answer, prompt strategies via telepractice: effects on parent strategy use and child communication. Lang Speech Hear Serv Sch. 2022 Apr 11;53(2):237–55. doi: 10.1044/2021_LSHSS-21-00075. PMID: 35050723. Exclusion Code: X2.35050723
537 Parra-López P, Olmos-Soria M, Valero-García AV. Nonverbal oro-motor exercises: do they really work for phonoarticulatory difficulties? Int J Environ Res Public Health. 2022 Apr 29;19(9)doi: 10.3390/ijerph19095459. PMID: 35564854. Exclusion Code: X11.35564854
538 Van Herck S, Vanden Bempt F, Economou M, Ahead of maturation: enhanced speech envelope training boosts rise time discrimination in pre-readers at cognitive risk for dyslexia. Dev Sci. 2022 May;25(3):e13186. doi: 10.1111/desc.13186. PMID: 34743382. Exclusion Code: X2.34743382
539 Keung AY, Ho VF, Shum KK. Early cognitive intervention using mediated learning for preschoolers with developmental delay: a randomized controlled trial. Br J Educ Psychol. 2022 Sep;92(3):1109–32. doi: 10.1111/bjep.12490. PMID: 35195914. Exclusion Code: X2.35195914
540 O'Brian S, Hayhow R, Jones M, Lidcombe Program translation to community clinics in Australia and England. Int J Lang Commun Disord. 2023 Mar;58(2):295–309. doi: 10.1111/1460-6984.12785. PMID: 36114801. Exclusion Code: X5.36114801
541 Fan S, Ma B, Song X, Effect of language therapy alone for developmental language disorder in children: a metaanalysis. Front Psychol. 2022;13:922866. doi: 10.3389/fpsyg.2022.922866. PMID: 36262431. Exclusion Code: X8.36262431
542 Finestack LH, Potter N, VanDam M, Feasibility of a proactive parent-implemented communication intervention delivered via telepractice for children with classic galactosemia. Am J Speech Lang Pathol. 2022 Nov 16;31(6):2527–38. doi: 10.1044/2022_AJSLP-22-00107. PMID: 36251874. Exclusion Code: X2.36251874
543 Lau DK, Tang TP, Wong CC, Systematic language input improved productions of elaborated verb phrases of Cantonese-speaking children with language difficulties. Clin Linguist Phon. 2023 Jun 3;37(4–6):473–90. doi: 10.1080/02699206.2022.2157330. PMID: 36592049. Exclusion Code: X2.36592049
544 Chen Y, Lin W-J. Efficacy of an integrated intervention with vocabulary and phonetic training for Mandarin-speaking children with developmental language disorders. Child Language Teaching and Therapy. 2022;38(3):288–302. doi: 10.1177/02656590221101180. PMID: CN-02494332. Exclusion Code: X11.
545 Walters C, Sevcik RA, Romski M. Spoken vocabulary outcomes of toddlers with developmental delay after parent-implemented augmented language intervention. Am J Speech Lang Pathol. 2021 May 18;30(3):1023–37. doi: 10.1044/2020_AJSLP-20-00093. PMID: 33789437. Exclusion Code: X2.33789437
546 Gregory KD. Evaluation of teacher ratings to improve child language screenings in speech-language pathology: ProQuest Information & Learning; 2022. Exclusion Code: X8.
547 Meaux AB. Addressing the higher level language skills for the common core state standards in kindergarten: ProQuest Information & Learning; 2022. Exclusion Code: X8.
548 Delgado-Cruz A, Ramírez-Santana GM, Acosta-Rodríguez VM. Intervention in the cohesion of narrative discourse in pupils with developmental language disorder. Psicología Educativa. 2022;28(2):135–40. doi: 10.5093/psed2021a21. PMID: 2023-06592-006. Exclusion Code: X11.
549 Thao SK, Lee SAS. Treatment intensity of speech intervention via telepractice for children with speech sound disorders: a systematic review. EBP Briefs. Volume 15, Issue 3 EBP Briefs (Evidence-based Practice Briefs). 2022. Exclusion Code: X8.
550 Taylor AL, Calder SD, Pogorzelski S, A preliminary evaluation of a manualised intervention to improve early literacy skills in children with developmental language disorder. Child Lang Teach Ther. 2021 06/01/;37(3):321–36. PMID: EJ1320424. Exclusion Code: X8.
551 Lim HA, Ellis EM, Sonnenschein D. Effect of Sing and Speak 4 Kids: an online music-based speech and language learning game for children in early intervention. Child Lang Teach Ther. 2022 06/01/;38(2):180–96. PMID: EJ1342818. Exclusion Code: X5.
552 Madsen KM, Peters-Sanders LA, Kelley ES, Optimizing vocabulary instruction for preschool children. Journal of Early Intervention. 2022;45(3):227–49. doi: 10.1177/10538151221116596. Exclusion Code: X11.
553 Rivera Pérez JF, Creaghead NA, Washington K, The relationship between perceived assertiveness/shyness and emergent bilinguals' vocabulary intervention outcomes: a preliminary investigation. Commun Disord Q. 2022 11/01/;44(1):14–22. PMID: EJ1353292. Exclusion Code: X2.