# Appendix B Additional Methods Information

## Appendix B1 Original Search Strategies

### PubMed, Screening, March 4, 2022

Search Number | Query | Filters | Results
1 | “Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh] | | 18,784
2 | “communication disorder*”[tiab] OR dysarthria[tw] OR “developmental language disorder*”[All Fields] OR DLD[tiab] OR “language development disorder*”[All Fields] OR “language impairment”[All Fields] OR (receptive[tiab] AND expressive[tiab] AND delay[tiab]) OR ((speech*[tiab] OR language*[tiab]) AND (disorder*[tiab] OR delay*[tiab] OR patholog*[tiab])) OR “speech impairment”[All Fields] | | 65,576
3 | #1 OR #2 | | 77,181
4 | “Diagnostic Techniques and Procedures”[Mesh] OR “Language Tests”[Mesh] OR “Mass Screening”[Mesh] OR “Psychological Tests”[Mesh] OR “case finding”[tiab] OR casefinding[tiab] OR instrument[tiab] OR inventory[tiab] OR questionnaire[tw] OR scale[tiab] OR screening[tiab] OR screened[tiab] OR screens[tiab] OR screen*[tiab] OR Surveillance[tw] OR Survey[tw] OR Test[tiab] OR tests[tiab] OR testing[tiab] OR Ages and Stages Questionnaire[Title/Abstract] OR Battelle Developmental Inventory Screening Test[Title/Abstract] OR Clinical Adaptive Test[Title/Abstract] OR “Clinical Linguistic and Auditory Milestone Scale”[All Fields] OR Denver Developmental Screening Test[Title/Abstract] OR Early Language Milestone Scale[Title/Abstract] OR Fluharty Preschool Speech[Title/Abstract] OR Infant-Toddler Checklist[Title/Abstract] OR Language Development Survey[Title/Abstract] OR McArthur-Bates Communicative Development Inventory[Title/Abstract] OR WILSTAAR[Title/Abstract] OR Preschool Language Scale[title/abstract] OR “Brigance Preschool Screen”[All Fields] OR “Denver Articulation Screening Exam”[All Fields] OR “Early Screening Profiles”[All Fields] OR “Northwestern Syntax Screening Test”[All Fields] OR “Sure Start Language Measure”[All Fields] | | 11,206,743
5 | #3 AND #4 | | 43,411
6 | #3 AND #4 | English | 39,535
7 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR ("Animals”[Mesh] NOT "Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 11,854,622
8 | #6 NOT #7 | | 29,174
9 | #6 NOT #7 | Infant: 1–23 months | 2,379
10 | #6 NOT #7 | Infant: 1–23 months, Preschool Child: 2–5 years | 6,543
11 | #9 AND (boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR “first grade”[tw] OR girls[tw] OR infant*[tw] OR Kindergarten*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR Prekindergarten*[tw] OR Pre-kindergarten*[tw] OR Pre-k[tw] OR Preschool*[tw] OR Pre-school*[tw] OR Toddler*[tw]) | | 2,379
12 | #10 OR #11 | | 6,543
13 | #12 AND ("2014/01/01”[Date - Publication] : "3000”[Date - Publication]) | | 2,463
14 | “systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR ("systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “cochrane database syst rev”[ta] OR “Umbrella Review”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] | | 334,342
15 | #13 AND #14 | | 90
16 | randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] OR groups [tiab] | | 3,390,517
17 | #13 AND #16 | | 700
18 | (cohort[all] OR (control[all] AND study[all]) OR (control[tw] AND group*[tw]) OR epidemiologic studies[mh] OR program[tw] OR clinical trial[pt] OR comparative stud*[all] OR evaluation studies[all] OR statistics as topic[mh] OR survey*[tw] OR follow-up*[all] OR time factors[all] OR ci[tw]) NOT ((animals[mh:noexp] NOT humans[mh:noexp]) OR comment[pt] OR editorial[pt] OR review[pt] OR meta analysis[pt] OR case report[tw] OR consensus[mh] OR guideline[pt] OR history[sh]) | | 8,562,725
19 | #13 AND #18 | | 1,732
20 | #15 NOT (#17 OR #19) | | 48
21 | #20 NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 41
22 | #17 NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 545
23 | #19 NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 1,430

### PubMed, Diagnostic Accuracy, March 4, 2022

Search Number | Query | Filters | Results
1 | “Communication Disorders”[Mesh] OR “Rehabilitation of Speech and Language Disorders”[Mesh] | | 73,124
2 | “communication disorder*”[tiab] OR dysarthria[tw] OR “developmental language disorder*”[All Fields] OR DLD[tiab] OR “language development disorder*”[All Fields] OR “language impairment”[All Fields] OR (receptive[tiab] AND expressive[tiab] AND delay[tiab]) OR ((speech*[tiab] OR language*[tiab]) AND (disorder*[tiab] OR delay*[tiab] OR patholog*[tiab])) OR “speech impairment”[All Fields] | | 65,576
3 | (#1 OR #2) NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 111,701
4 | (#1 OR #2) NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | English | 98,216
5 | #4 AND (“2014/01/01”[Date - Publication] : “3000”[Date - Publication]) | | 34,689
6 | “Diagnostic Techniques and Procedures”[Mesh] OR “Language Tests”[Mesh] OR “Mass Screening”[Mesh] OR “Psychological Tests”[Mesh] OR “case finding”[tiab] OR casefinding[tiab] OR instrument[tiab] OR inventory[tiab] OR questionnaire[tw] OR scale[tiab] OR screening[tiab] OR screened[tiab] OR screens[tiab] OR screen*[tiab] OR Surveillance[tw] OR Survey[tw] OR Test[tiab] OR tests[tiab] OR testing[tiab] | | 11,206,737
7 | #5 AND #6 | | 19,259
8 | “Risk”[Mesh] | | 1,328,346
9 | #5 AND #8 | | 1,438
10 | #7 OR #9 | | 19,793
11 | “Area Under Curve”[Mesh] OR “Diagnosis, Differential”[Mesh] OR “Diagnostic Techniques and Procedures”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “Likelihood Functions”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “Reproducibility of Results”[Mesh] OR “ROC Curve”[Mesh] OR “Sensitivity and Specificity”[Mesh] OR accuracy[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw] OR “predictive value”[tw] OR reproducib*[tw] OR ROC[tw] OR sensitivity[tw] OR specificity[tw] | | 9,536,790
12 | #10 AND #11 | | 10,072
13 | #10 AND #11 | Infant: birth-23 months | 704
14 | #10 AND #11 | Infant: birth-23 months, Preschool Child: 2–5 years | 1,736
15 | #12 AND (boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR “first grade”[tw] OR girls[tw] OR infant*[tw] OR Kindergarten*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR Prekindergarten*[tw] OR Pre-kindergarten*[tw] OR Pre-k[tw] OR Preschool*[tw] OR Pre-school*[tw] OR Toddler*[tw]) | | 3,456
16 | #14 OR #15 | | 3,456
17 | Ages and Stages Questionnaire[Title/Abstract] OR Battelle Developmental Inventory Screening Test[Title/Abstract] OR Clinical Adaptive Test[Title/Abstract] OR “Clinical Linguistic and Auditory Milestone Scale”[All Fields] OR Denver Developmental Screening Test[Title/Abstract] OR Early Language Milestone Scale[Title/Abstract] OR Fluharty Preschool Speech[Title/Abstract] OR Infant-Toddler Checklist[Title/Abstract] OR Language Development Survey[Title/Abstract] OR McArthur-Bates Communicative Development Inventory[Title/Abstract] OR WILSTAAR[Title/Abstract] OR Preschool Language Scale[title/abstract] | | 1,036
18 | “Brigance Preschool Screen”[All Fields] OR “Denver Articulation Screening Exam”[All Fields] OR “Early Screening Profiles”[All Fields] OR “Northwestern Syntax Screening Test”[All Fields] OR “Sure Start Language Measure”[All Fields] | | 25
19 | #17 OR #18 | | 1,059
20 | #19 AND #11 | | 391
21 | #19 AND #11 | English | 381
22 | #19 AND #11 | English, Infant: birth-23 months | 262
23 | #19 AND #11 | English, Infant: birth-23 months, Preschool Child: 2–5 years | 331
24 | #21 AND (boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR girls[tw] OR infant*[tw] OR Kindergarten*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR Prekindergarten*[tw] OR Pre-kindergarten*[tw] OR Pre-k[tw] OR Preschool*[tw] OR Pre-school*[tw] OR Toddler*[tw]) | | 381
25 | #23 OR #24 | | 381
26 | #16 OR #25 | | 3,810
27 | #26 AND (“2014/01/01”[Date - Publication] : “3000”[Date - Publication]) | | 3,601
28 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control” OR “case report*” OR “case series” OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 11,863,695
29 | #27 NOT #28 | | 2,627
30 | “systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “cochrane database syst rev”[ta] OR “Umbrella Review”[tiab] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] | | 356,885
31 | #29 AND #30 | | 129
32 | #29 NOT #31 | | 2,498

### PubMed, Interventions and Harms of Interventions, March 4, 2022

Search Number | Query | Filters | Results
1 | “Communication Disorders”[Mesh] OR “Rehabilitation of Speech and Language Disorders”[Mesh] | | 73,124
2 | “communication disorder*”[tiab] OR dysarthria[tw] OR “developmental language disorder*”[All Fields] OR DLD[tiab] OR “language development disorder*”[All Fields] OR “language impairment”[All Fields] OR (receptive[tiab] AND expressive[tiab] AND delay[tiab]) OR ((speech*[tiab] OR language*[tiab]) AND (disorder*[tiab] OR delay*[tiab] OR patholog*[tiab])) OR “speech impairment”[All Fields] | | 65,576
3 | (#1 OR #2) NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 111,701
4 | “Communication Aids for Disabled”[Mesh] OR “Comparative Study” [Publication Type] OR “Early Medical Intervention”[Mesh] OR “Evaluation Studies” [Publication Type] OR “Evaluation Studies as Topic”[Mesh] OR “Epidemiologic Studies”[Mesh] OR Gestures[Mesh] OR Multilingualism[Mesh] OR “Outcome and Process Assessment, Health Care”[Mesh] OR “Rehabilitation of Speech and Language Disorders”[Mesh] OR “Therapy, Computer-Assisted”[Mesh] OR therapeutics[Mesh] OR therapy[subheading] OR treatment[sh] OR “intervention*”[tiab] OR “language facilitation”[tiab] OR “speech therapy”[tiab] | | 12,933,833
5 | #3 AND #4 | | 61,268
6 | #3 AND #4 | English | 54,517
7 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 11,854,622
8 | #6 NOT #7 | | 39,161
9 | #6 NOT #7 | Infant: birth-23 months | 3,523
10 | #6 NOT #7 | Infant: birth-23 months, Preschool Child: 2–5 years | 8,284
11 | #6 NOT #7 | Infant: birth-23 months, Child: 6–12 years, Preschool Child: 2–5 years | 15,825
12 | (boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR girls[tw] OR infant*[tw] OR Kindergarten*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR Prekindergarten*[tw] OR Pre-kindergarten*[tw] OR Pre-k[tw] OR Preschool*[tw] OR Pre-school*[tw] OR Toddler*[tw]) | | 3,456,813
13 | #8 AND #12 | | 17,391
14 | #11 OR #13 | | 17,391
15 | #14 AND (“2014/01/01”[Date - Publication] : “3000”[Date - Publication]) | | 5,346
16 | randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] OR groups [tiab] | | 3,390,517
17 | #15 AND #16 | | 1,522
18 | “systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “cochrane database syst rev”[ta] OR “Umbrella Review”[tiab] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] | | 356,885
19 | #15 AND #18 | | 448
20 | #19 NOT #17 | | 255
21 | “Diagnostic Errors”[Mesh] OR “Stress, Physiological”[Mesh] OR “Life Change Events”[Mesh] OR “Prejudice”[Mesh] OR “Stereotyping”[Mesh] OR “Self Concept”[Mesh] OR “adverse effect*” OR harm* OR labeling OR overdiagnos* OR stigma* | | 3,391,991
22 | #15 AND #21 | | 549
23 | (cohort[all] OR (control[all] AND study[all]) OR (control[tw] AND group*[tw]) OR epidemiologic studies[mh] OR program[tw] OR clinical trial[pt] OR comparative stud*[all] OR evaluation studies[all] OR statistics as topic[mh] OR survey*[tw] OR follow-up*[all] OR time factors[all] OR ci[tw]) NOT ((animals[mh:noexp] NOT humans[mh:noexp]) OR comment[pt] OR editorial[pt] OR review[pt] OR meta analysis[pt] OR case report[tw] OR consensus[mh] OR guideline[pt] OR history[sh]) | | 8,562,725
24 | #22 AND #23 | | 324

### Cochrane Library, Screening, March 4, 2022

ID | Search | Hits
#1 | [mh “Communication Disorders”] | 1,911
#2 | ((“communication” NEXT disorder*):ti,ab OR dysarthria:ti,ab,kw OR (“developmental language” NEXT disorder*) OR DLD:ti,ab OR (“language development” NEXT disorder*) OR “language impairment” OR (receptive:ti,ab AND expressive:ti,ab AND delay:ti,ab) OR ((speech*:ti,ab OR language*:ti,ab) AND (disorder*:ti,ab OR delay*:ti,ab OR pathology*:ti,ab)) OR “speech impairment”) | 6,320
#3 | (#1 OR #2) NOT (autism:ti OR “down syndrome”:ti OR “fragile syndrome”:ti OR craniofacial:ti OR “cleft palate”:ti) | 7,313
#4 | [mh “Diagnostic Techniques and Procedures”] OR [mh “Language Tests”] OR [mh “Mass Screening”] OR [mh “Psychological Tests”] OR “case finding”:ti,ab OR casefinding:ti,ab OR instrument:ti,ab OR inventory:ti,ab OR questionnaire:ti,ab,kw OR scale:ti,ab OR screening:ti,ab OR screened:ti,ab OR screens:ti,ab OR screen*:ti,ab OR Surveillance:ti,ab,kw OR Survey:ti,ab,kw OR Test:ti,ab OR tests:ti,ab OR testing:ti,ab OR “Ages and Stages Questionnaire”:ti,ab OR “Battelle Developmental Inventory Screening Test”:ti,ab OR “Clinical Adaptive Test”:ti,ab OR “Clinical Linguistic and Auditory Milestone Scale” OR “Denver Developmental Screening Test”:ti,ab OR “Early Language Milestone Scale”:ti,ab OR “Fluharty Preschool Speech”:ti,ab OR “Infant Toddler Checklist”:ti,ab OR “Language Development Survey”:ti,ab OR “McArthur Bates Communicative Development Inventory”:ti,ab OR WILSTAAR:ti,ab OR “Preschool Language Scale”:ti,ab OR “Brigance Preschool Screen” OR “Denver Articulation Screening Exam” OR “Early Screening Profiles” OR “Northwestern Syntax Screening Test” OR “Sure Start Language Measure” | 744,746
#5 | #3 AND #4 | 4,654
#6 | address:pt OR autobiography:pt OR bibliography:pt OR biography:pt OR “case control”:ti,ab,kw OR “case report”:ti,ab,kw OR “case reports”:ti,ab,kw OR “case series”:ti,ab,kw OR comment:pt OR “comment on” OR congress:pt OR cross-sectional:ti,ab,kw OR dictionary:pt OR directory:pt OR editorial:pt OR festschrift:pt OR “historical article”:pt OR interview:pt OR lecture:pt OR “legal case”:pt OR legislation:pt OR letter:pt OR news:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh Animals] NOT [mh Humans]) OR rats:ti,ab,kw OR cow:ti,ab,kw OR cows:ti,ab,kw OR chicken:ti,ab,kw OR chickens:ti,ab,kw OR horse:ti,ab,kw OR horses:ti,ab,kw OR mice:ti,ab,kw OR mouse:ti,ab,kw OR bovine:ti,ab,kw OR sheep OR ovine OR murine OR murinae | 85,514
#7 | #5 NOT #6 | 3,416
#8 | #7 AND (boys:ti,ab,kw OR child:ti,ab,kw OR children*:ti,ab,kw OR childhood:ti,ab,kw OR “first grade”:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR Kindergarten*:ti,ab,kw OR neonat*:ti,ab,kw OR newborn*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR Prekindergarten*:ti,ab,kw OR Pre-kindergarten*:ti,ab,kw OR Pre-k:ti,ab,kw OR Preschool*:ti,ab,kw OR Pre-school*:ti,ab,kw OR Toddler*:ti,ab,kw) | 1,162
#9 | #8 Limited to Years First Published between 2014 to 2022 | 665 (all results are trials)

### Cochrane Library, Diagnostic Accuracy, March 4, 2022

ID | Search | Hits
#1 | [mh “Communication Disorders”] OR [mh “Rehabilitation of Speech and Language Disorders”] | 2,181
#2 | (“communication” NEXT disorder*):ti,ab OR dysarthria:ti,ab,kw OR (“developmental language” NEXT disorder*) OR DLD:ti,ab OR (“language development” NEXT disorder*) OR “language impairment” OR (receptive:ti,ab AND expressive:ti,ab AND delay:ti,ab) OR ((speech*:ti,ab OR language*:ti,ab) AND (disorder*:ti,ab OR delay*:ti,ab OR pathology*:ti,ab)) OR “speech impairment” | 6,787
#3 | (#1 OR #2) NOT (autism:ti OR “down syndrome”:ti OR “fragile syndrome”:ti OR craniofacial:ti OR “cleft palate”:ti) | 7,871
#4 | [mh “Diagnostic Techniques and Procedures”] OR [mh “Language Tests”] OR [mh “Mass Screening”] OR [mh “Psychological Tests”] OR “case finding”:ti,ab OR casefinding:ti,ab OR instrument:ti,ab OR inventory:ti,ab OR questionnaire:ti,ab,kw OR scale:ti,ab OR screening:ti,ab OR screened:ti,ab OR screens:ti,ab OR screen*:ti,ab OR Surveillance:ti,ab,kw OR Survey:ti,ab,kw OR Test:ti,ab OR tests:ti,ab OR testing:ti,ab | 744,743
#5 | #3 AND #4 | 4,969
#6 | [mh “Risk”] | 39,301
#7 | #3 AND #6 | 106
#8 | #5 OR #7 | 5,013
#9 | [mh “Area Under Curve”] OR [mh “Diagnosis, Differential”] OR [mh “Diagnostic Techniques and Procedures”] OR [mh “False Negative Reactions”] OR [mh “False Positive Reactions”] OR [mh “Likelihood Functions”] OR [mh “Predictive Value of Tests”] OR [mh “Reproducibility of Results”] OR [mh “ROC Curve”] OR [mh “Sensitivity and Specificity”] OR accuracy:ti,ab,kw OR “false positive”:ti,ab,kw OR “false negative”:ti,ab,kw OR “likelihood ratio”:ti,ab,kw OR “predictive value”:ti,ab,kw OR reproducib*:ti,ab,kw OR ROC:ti,ab,kw OR sensitivity:ti,ab,kw OR specificity:ti,ab,kw | 325,179
#10 | #8 AND #9 | 1,289
#11 | #10 AND (boys:ti,ab,kw OR child:ti,ab,kw OR children*:ti,ab,kw OR childhood:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR Kindergarten*:ti,ab,kw OR neonat*:ti,ab,kw OR newborn*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR Prekindergarten*:ti,ab,kw OR Pre-kindergarten*:ti,ab,kw OR Pre-k:ti,ab,kw OR Preschool*:ti,ab,kw OR Pre-school*:ti,ab,kw OR Toddler*:ti,ab,kw) | 478
#12 | “Ages and Stages Questionnaire”:ti,ab OR “Battelle Developmental Inventory Screening Test”:ti,ab OR “Clinical Adaptive Test”:ti,ab OR “Clinical Linguistic and Auditory Milestone Scale” OR “Denver Developmental Screening Test”:ti,ab OR “Early Language Milestone Scale”:ti,ab OR “Fluharty Preschool Speech”:ti,ab OR “Infant Toddler Checklist”:ti,ab OR “Language Development Survey”:ti,ab OR “McArthur Bates Communicative Development Inventory”:ti,ab OR “WILSTAAR”:ti,ab OR “Preschool Language Scale”:ti,ab | 228
#13 | “Brigance Preschool Screen” OR “Denver Articulation Screening Exam” OR “Early Screening Profiles” OR “Northwestern Syntax Screening Test” OR “Sure Start Language Measure” | 1
#14 | #12 OR #13 | 229
#15 | #14 AND #9 | 32
#16 | #15 AND (boys:ti,ab,kw OR child:ti,ab,kw OR children*:ti,ab,kw OR childhood:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR Kindergarten*:ti,ab,kw OR neonat*:ti,ab,kw OR newborn*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR Prekindergarten*:ti,ab,kw OR Pre-kindergarten*:ti,ab,kw OR Pre-k:ti,ab,kw OR Preschool*:ti,ab,kw OR Pre-school*:ti,ab,kw OR Toddler*:ti,ab,kw) | 32
#17 | #11 OR #16 | 509
#18 | address:pt OR autobiography:pt OR bibliography:pt OR biography:pt OR comment:pt OR “comment on” OR congress:pt OR cross-sectional:ti,ab,kw OR dictionary:pt OR directory:pt OR editorial:pt OR festschrift:pt OR “historical article”:pt OR interview:pt OR lecture:pt OR “legal case”:pt OR legislation:pt OR letter:pt OR news:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh Animals] NOT [mh Humans]) OR rats:ti,ab,kw OR cow:ti,ab,kw OR cows:ti,ab,kw OR chicken:ti,ab,kw OR chickens:ti,ab,kw OR horse:ti,ab,kw OR horses:ti,ab,kw OR mice:ti,ab,kw OR mouse:ti,ab,kw OR bovine:ti,ab,kw OR sheep OR ovine OR murine OR murinae | 62,926
#19 | #17 NOT #18 | 353
#20 | #19 Limited to Years First Published between 2014 to 2022 | 132 (all results are trials)

### Cochrane Library, Interventions and Harms of Interventions, March 4, 2022

ID | Search | Hits
#1 | [mh “Communication Disorders”] OR [mh “Rehabilitation of Speech and Language Disorders”] | 2,181
#2 | ((“communication” NEXT disorder*):ti,ab OR dysarthria:ti,ab,kw OR (“developmental language” NEXT disorder*) OR DLD:ti,ab OR (“language development” NEXT disorder*) OR “language impairment” OR (receptive:ti,ab AND expressive:ti,ab AND delay:ti,ab) OR ((speech*:ti,ab OR language*:ti,ab) AND (disorder*:ti,ab OR delay*:ti,ab OR pathology*:ti,ab)) OR “speech impairment”) | 6,320
#3 | (#1 OR #2) NOT (autism:ti OR “down syndrome”:ti OR “fragile syndrome”:ti OR craniofacial:ti OR “cleft palate”:ti) | 7,538
#4 | [mh “Communication Aids for Disabled”] OR “Comparative Study”:pt OR [mh “Early Medical Intervention”] OR “Evaluation Studies”:pt OR [mh “Evaluation Studies as Topic”] OR [mh “Epidemiologic Studies”] OR [mh Gestures] OR [mh Multilingualism] OR [mh “Outcome and Process Assessment, Health Care”] OR [mh “Rehabilitation of Speech and Language Disorders”] OR [mh “Therapy, Computer-Assisted”] OR [mh therapeutics] OR [mh /TH] OR treatment:kw OR intervention*:ti,ab OR “language facilitation”:ti,ab OR “speech therapy”:ti,ab | 929,743
#5 | #3 AND #4 | 5,841
#6 | address:pt OR autobiography:pt OR bibliography:pt OR biography:pt OR “case control”:ti,ab,kw OR “case report”:ti,ab,kw OR “case reports”:ti,ab,kw OR “case series”:ti,ab,kw OR comment:pt OR “comment on” OR congress:pt OR cross-sectional:ti,ab,kw OR dictionary:pt OR directory:pt OR editorial:pt OR festschrift:pt OR “historical article”:pt OR interview:pt OR lecture:pt OR “legal case”:pt OR legislation:pt OR letter:pt OR news:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh Animals] NOT [mh Humans]) OR rats:ti,ab,kw OR cow:ti,ab,kw OR cows:ti,ab,kw OR chicken:ti,ab,kw OR chickens:ti,ab,kw OR horse:ti,ab,kw OR horses:ti,ab,kw OR mice:ti,ab,kw OR mouse:ti,ab,kw OR bovine:ti,ab,kw OR sheep OR ovine OR murine OR murinae | 85,514
#7 | #5 NOT #6 | 3,984
#8 | (boys:ti,ab,kw OR child:ti,ab,kw OR children*:ti,ab,kw OR childhood:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR Kindergarten*:ti,ab,kw OR neonat*:ti,ab,kw OR newborn*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR Prekindergarten*:ti,ab,kw OR Pre-kindergarten*:ti,ab,kw OR Pre-k:ti,ab,kw OR Preschool*:ti,ab,kw OR Pre-school*:ti,ab,kw OR Toddler*:ti,ab,kw) | 218,689
#9 | #7 AND #8 | 1,463
#10 | #9 Limited to Years First Published between 2014 to 2022 | 791 (all results are trials)

### APA PsycInfo, Screening, March 4, 2022

# | Query | Limiters/Expanders | Results
1 | DE “Communication Disorders” OR DE “Language Disorders” OR DE “Speech Disorders” OR DE “Language Delay” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 18,682
2 | TI “communication disorder*” OR AB “communication disorder*” OR DE “Dysarthria” OR TX dysarthria OR TX “developmental language disorder*” OR TI DLD OR AB DLD OR TX “language development disorder*” OR TX “language impairment” OR (TI receptive AND TI expressive AND TI delay) OR (AB receptive AND AB expressive AND AB delay) OR ((TI speech* OR TI language*) AND (TI disorder* OR TI delay* OR TI patholog*)) OR ((AB speech* OR AB language*) AND (AB disorder* OR AB delay* OR AB patholog*)) OR TX “speech impairment” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 45,495
3 | ( S1 OR S2 ) NOT ( (TI autism OR TI “down syndrome” OR TI “fragile syndrome” OR TI craniofacial OR TI “cleft palate") ) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 48,331
4 | DE “Diagnostic Criteria” OR DE “Screening” OR DE “Screening Tests” OR DE “Questionnaires” OR DE “Testing” OR DE “Surveys” OR TI “case finding” OR AB “case finding” OR TI casefindng OR AB casefinding OR TI instrument OR AB instrument OR TI inventory OR AB inventory OR TI questionnaire OR AB questionnaire OR TI scale OR AB scale OR TI screening OR AB screening OR TI screened OR AB screened OR TI screens OR TI screens OR TI screen* OR AB screen* OR TX surveillance OR TX survey OR TI test OR AB test OR TI tests OR AB tests OR TI testing OR AB testing | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,550,448
5 | TX “Ages and Stages Questionnaire” OR TX “Battelle Developmental Inventory Screening Test” OR TX “Clinical Adaptive Test” OR TX “Clinical Linguistic and Auditory Milestone Scale” OR TX “Denver Developmental Screening Test” OR TX “Early Language Milestone Scale” OR TX “Fluharty Preschool Speech” OR TX “Infant-Toddler Checklist” OR TX “Language Development Survey” OR TX “McArthur-Bates Communicative Development Inventory” OR TX WILSTAAR OR TX “Preschool Language Scale” OR TX “Brigance Preschool Screen” OR TX “Denver Articulation Screening Exam” OR TX “Early Screening Profiles” OR TX “Northwestern Syntax Screening Test” OR TX “Sure Start Language Measure” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,785
6 | S4 OR S5 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,551,065
7 | S3 AND S6 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 15,793
8 | DE “Autobiography” OR DE “Biography” OR DE “Case Report” OR DE “Newspapers” (DE “Biography” OR DE “Newspapers” OR TX “comment on” OR TW “case report*” OR TX “case series” OR TX congress OR TX “cross-sectional” OR TX dictionary OR TX directory OR TX editorial OR TX festschrift OR TX “legal case” OR TX legislation OR TX “patient education handout” OR TX “periodical index” OR TX rats OR TX cow OR TX cows OR TX chicken OR TX chickens OR TX horse OR TX horses OR TX mice OR TX mouse OR TX bovine OR TX sheep OR TX ovine OR TX murine OR TX murinae | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 662,492
9 | S7 NOT S8 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 14,581
10 | S9 | Limiters - English; Language: English; Population Group: Human; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 12,939
11 | S10 | Limiters - Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs); Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 2,904
12 | TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI “first grade” OR AB “first grade” OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler* | Limiters - Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs); Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 143,616
13 | S10 AND S12 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 2,707
14 | S11 OR S13 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 2,904
15 | S14 | Limiters - Published Date: 20140101–20221231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,042
16 | S15 | Limiters - Methodology: -Systematic Review, META ANALYSIS, METASYNTHESIS; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 11
17 | “randomized controlled trial” OR “controlled clinical trial” OR TI randomized OR AB randomized OR TI randomly OR AB randomly OR TI trial OR AB trial OR TI groups OR AB groups | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,121,985
18 | S15 AND S17 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 462
19 | (TX cohort OR (TX control AND TX study) OR (TX control AND TX group*) OR TX “epidemiologic stud*” OR TX program OR MR “clinical trial” OR TX “comparative stud*” OR TX “evaluation stud*” OR TX survey* OR DE “Followup Studies” OR TX “follow-up*” OR TX “time factors”) NOT ((PO Animal NOT PO Human) OR TI editorial OR AB editorial OR DE “Literature Review” OR MR “meta analysis” OR TI consensus OR AB consensus OR TI guideline OR AB guideline) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,517,702
20 | S15 AND S19 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 493

### APA PsycInfo, Diagnostic Accuracy, March 4, 2022

# | Query | Limiters/Expanders | Results
1 | DE “Communication Disorders” OR DE “Language Disorders” OR DE “Speech Disorders” OR DE “Language Delay” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 18,682
2 | TI “communication disorder*” OR AB “communication disorder*” OR DE “Dysarthria” OR TX dysarthria OR TX “developmental language disorder*” OR TI DLD OR AB DLD OR TX “language development disorder*” OR TX “language impairment” OR (TI receptive AND TI expressive AND TI delay) OR (AB receptive AND AB expressive AND AB delay) OR ((TI speech* OR TI language*) AND (TI disorder* OR TI delay* OR TI patholog*)) OR ((AB speech* OR AB language*) AND (AB disorder* OR AB delay* OR AB patholog*)) OR TX “speech impairment” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 45,495
3 | (S1 OR S2) NOT (TI autism OR TI “down syndrome” OR TI “fragile syndrome” OR TI craniofacial OR TI “cleft palate") | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 48,331
4 | S3 | Limiters - English; Language: English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 45,057
5 | S4 | Limiters - Published Date: 20140101–20221231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 14,042
6 | DE “Diagnostic Criteria” OR DE “Screening” OR DE “Screening Tests” OR DE “Questionnaires” OR DE “Testing” OR DE “Surveys” OR TI “case finding” OR AB “case finding” OR TI casefindng OR AB casefinding OR TI instrument OR AB instrument OR TI inventory OR AB inventory OR TI questionnaire OR AB questionnaire OR TI scale OR AB scale OR TI screening OR AB screening OR TI screened OR AB screened OR TI screens OR TI screens OR TI screen* OR AB screen* OR TX surveillance OR TX survey OR TI test OR AB test OR TI tests OR AB tests OR TI testing OR AB testing | Limiters - Published Date: 20140101–20221231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 529,268
7 | S5 AND S6 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 5,510
8 | DE “Risk Assessment” OR DE “Risk Factors” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 162,786
9 | S5 AND S8 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 468
10 | S7 OR S9 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 5,735
11 | TX accuracy OR TX “Area Under Curve” OR DE “Differential Diagnosis” OR TX “Diagnostic Technique*” OR TX “Diagnostic Procedur*” OR TX “False Negative” OR TX “False Positive” OR TX “likelihood function*” OR TX “likelihood ratio” OR DE “Predictive Validity” OR TX “predictive value” OR TX reproducib* OR TX ROC OR TX sensitivity OR TX specificity | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 311,227
12 | S10 AND S11 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 943
13 | S12 | Limiters - Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs); Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 235
14 | S12 AND (TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler*) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 422
15 | S13 OR S14 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 431
16 | TX “Ages and Stages Questionnaire” OR TX “Battelle Developmental Inventory Screening Test” OR TX “Clinical Adaptive Test” OR TX “Clinical Linguistic and Auditory Milestone Scale” OR TX “Denver Developmental Screening Test” OR TX “Early Language Milestone Scale” OR TX “Fluharty Preschool Speech” OR TX “Infant-Toddler Checklist” OR TX “Language Development Survey” OR TX “McArthur-Bates Communicative Development Inventory” OR TX WILSTAAR OR TX “Preschool Language Scale” OR TX | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,669
17 | “Brigance Preschool Screen” OR TX “Denver Articulation Screening Exam” OR TX “Early Screening Profiles” OR TX “Northwestern Syntax Screening Test” OR TX “Sure Start Language Measure” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 98
18 | S16 OR S17 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,785
19 | S18 | Limiters - English; Language: English; Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs); Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,312
20 | S19 AND (TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler*) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,212
21 | S19 OR S20 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,312
22 | S21 | Limiters - Published Date: 20140101–20221231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 2,429
23 | DE “Autobiography” OR DE “Biography” OR DE “Case Report” OR DE “Newspapers” (DE “Biography” OR DE “Newspapers” OR TX “comment on” OR TW “case report*” OR TX “case series” OR TX “case stud*” OR TX congress OR TX “cross-sectional” OR TX dictionary OR TX directory OR TX editorial OR TX festschrift OR TX “legal case” OR TX legislation OR TX “patient education handout” OR TX “periodical index” OR TX rats OR TX cow OR TX cows OR TX chicken OR TX chickens OR TX horse OR TX horses OR TX mice OR TX mouse OR TX bovine OR TX sheep OR TX ovine OR TX murine OR TX murinae | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 822,360
24 | S22 NOT S23 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 528
25 | S15 OR S24 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 996
26 | S25 AND PO Human | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 960
27 | S26 | Limiters - Methodology: -Systematic Review, META ANALYSIS, METASYNTHESIS; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 13
28 | S26 NOT S27 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 947

### APA PsycInfo, Interventions and Harms of Interventions, March 4, 2022

# | Query | Limiters/Expanders | Results
1 | DE “Communication Disorders” OR DE “Language Disorders” OR DE “Speech Disorders” OR DE “Language Delay” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 18,682
2 | TI “communication disorder*” OR AB “communication disorder*” OR DE “Dysarthria” OR TX dysarthria OR TX “developmental language disorder*” OR TI DLD OR AB DLD OR TX “language development disorder*” OR TX “language impairment” OR (TI receptive AND TI expressive AND TI delay) OR (AB receptive AND AB expressive AND AB delay) OR ((TI speech* OR TI language*) AND (TI disorder* OR TI delay* OR TI patholog*)) OR ((AB speech* OR AB language*) AND (AB disorder* OR AB delay* OR AB patholog*)) OR TX “speech impairment” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 45,495
3 | (S1 OR S2) NOT (TI autism OR TI “down syndrome” OR TI “fragile syndrome” OR TI craniofacial OR TI “cleft palate") | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 48,331
4 | DE “Speech Therapy” OR DE “Language Therapy” OR DE “Treatment” OR DE “Adjunctive Treatment” OR DE “Anxiety Management” OR DE “Behavior Modification” OR DE “Cognitive Techniques” OR DE “Computer Assisted Therapy” OR DE “Counseling” OR DE “Culturally Adapted Interventions” OR DE “Habilitation” OR DE “Interdisciplinary Treatment Approach” OR DE “Intervention” OR DE “Early Intervention” OR DE “Multimodal Treatment Approach” OR DE “Outpatient Treatment” OR DE “Personal Therapy” OR DE “Physical Treatment Methods” OR DE “Psychoeducation” OR DE “Psychotherapy” OR DE “Rehabilitation” OR DE “Self-Help Techniques” OR DE “Symptoms Based Treatment” OR DE “Therapeutic Processes” OR DE “Video-Based Interventions” OR DE “Gestures” OR DE “Multilingualism” OR DE “Bilingualism” OR TX “communication aids” OR TX “comparative stud*” OR TX “early medical intervention*” OR TX “evaluation stud*” OR TX “epidemiologic stud*” OR TI treatment OR AB treatment OR TI “language facilitation” OR AB “language facilitation” OR TI “speech therapy” OR AB “speech therapy” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 913,902
5 | S3 AND S4 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 14,490
6 | S5 | Limiters - English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 13,484
7 | DE “Autobiography” OR DE “Biography” OR DE “Case Report” OR DE “Newspapers” (DE “Biography” OR DE “Newspapers” OR TX “comment on” OR TW “case report*” OR TX “case series” OR TX congress OR TX “cross-sectional” OR TX dictionary OR TX directory OR TX editorial OR TX festschrift OR TX “legal case” OR TX legislation OR TX “patient education handout” OR TX “periodical index” OR TX rats OR TX cow OR TX cows OR TX chicken OR TX chickens OR TX horse OR TX horses OR TX mice OR TX mouse OR TX bovine OR TX sheep OR TX ovine OR TX murine OR TX murinae | Limiters - English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 639,200
8 | S6 NOT S7 | Limiters - English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 12,244
9 | S8 AND PO Human | Limiters - English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 11,759
10 | S9 | Limiters - Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs), School Age (6–12 yrs); Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 3,087
11 | S9 AND (TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler*) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 5,280
12 | S10 OR S11 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 5,565
13 | S12 | Limiters - Published Date: 20140101–20221231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,710
14 | “randomized controlled trial” OR “controlled clinical trial” OR TI randomized OR AB randomized OR TI randomly OR AB randomly OR TI trial OR AB trial OR TI groups OR AB groups | Limiters - Published Date: 20140101–20221231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 370,374
15 | S13 AND S14 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 660
16 | S13 | Limiters - Methodology: -Systematic Review, META ANALYSIS, METASYNTHESIS; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 67
17 | S16 NOT S15 | Limiters - Methodology: -Systematic Review, META ANALYSIS, METASYNTHESIS; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 38
18 | TI “Diagnostic Errors” OR AB “Diagnostic Errors” OR DE “Psychological Stress” OR DE “Life Changes” OR DE “Prejudice” OR DE “Stereotyped Attitudes” OR DE “Self-Concept” OR DE “Academic Self Concept” OR DE “Self-Confidence” OR DE “Self-Congruence” OR DE “Self-Esteem” OR DE “Self-Forgiveness” OR DE “Self-Regard” OR DE “Self-Worth” OR DE “Sense of Coherence” OR DE “Patient Safety” OR TX harm* OR DE “Labeling” OR TX overdiagnos* OR DE “Stigma” OR DE “Self-Stigma” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 214,341
19 | S13 AND S18 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 19
20 | (TX cohort OR (TX control AND TX study) OR (TX control AND TX group*) OR TX “epidemiologic stud*” OR TX program OR MR “clinical trial” OR TX “comparative stud*” OR TX “evaluation stud*” OR TX survey* OR DE “Followup Studies” OR TX “follow-up*” OR TX “time factors”) NOT ((PO Animal NOT PO Human) OR TI editorial OR AB editorial OR DE “Literature Review” OR MR “meta analysis” OR TI consensus OR AB consensus OR TI guideline OR AB guideline) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,517,702
21 | S19 AND S20 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 5

### ERIC, Interventions and Harms of Interventions, March 4, 2022

# | Query | Limiters/Expanders | Results
1 | DE “Aphasia” OR DE “Articulation Impairments” OR DE “Communication Disorders” OR DE “Delayed Speech” OR DE “Language Impairments” OR OR DE “Receptive Language” OR DE “Speech Impairments” OR DE “Speech Language Pathology” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 6,425
2 | TI “communication disorder*” OR AB “communication disorder*” OR TX dysarthria OR TX “developmental language disorder*” OR TI DLD OR AB DLD OR TX “language development disorder*” OR TX “language impairment” OR (TI receptive AND TI expressive AND TI delay) OR (AB receptive AND AB expressive AND AB delay) OR ((TI speech* OR TI language*) AND (TI disorder* OR TI delay* OR TI patholog*)) OR ((AB speech* OR AB language*) AND (AB disorder* OR AB delay* OR AB patholog*)) OR TX “speech impairment” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 10,756
3 | S1 OR S2 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 13,917
4 | (S1 OR S2) NOT (TI autism OR TI “down syndrome” OR TI “fragile syndrome” OR TI craniofacial OR TI “cleft palate") | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 12,462
5 | DE “Speech Therapy” OR DE “Behavior Modification” OR DE “Applied Behavior Analysis” OR DE “Contingency Management” OR DE “Positive Behavior Supports” OR DE “Counseling” OR OR DE “Family Counseling” OR DE “Individual Counseling” OR DE “Parent Counseling” OR DE “School Counseling” OR DE “Intervention” OR DE “Early Intervention” OR DE “Prereferral Intervention” OR DE “Response to Intervention” OR DE “Personal Therapy” OR DE “Psychotherapy” OR DE “Rehabilitation” OR DE “Therapy” OR DE “Educational Therapy” OR DE “Therapeutic Recreation” OR DE “Multilingualism” OR DE “Bilingualism” OR TX “communication aids” OR TX “comparative stud*” OR TX “early medical intervention*” OR TX “evaluation stud*” OR TX “epidemiologic stud*” OR TI treatment OR AB treatment OR TI “language facilitation” OR AB “language facilitation” OR TI “speech therapy” OR AB “speech therapy” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 140,078
6 | S4 AND S5 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 4,437
7 | DE “Autobiography” OR DE “Biography” OR DE “Case Report” OR DE “Newspapers” (DE “Biography” OR DE “Newspapers” OR TX “comment on” OR TW “case report*” OR TX “case series” OR TX congress OR TX “cross-sectional” OR TX dictionary OR TX directory OR TX editorial OR TX festschrift OR TX “legal case” OR TX legislation OR TX “patient education handout” OR TX “periodical index” OR TX rats OR TX cow OR TX cows OR TX chicken OR TX chickens OR TX horse OR TX horses OR TX mice OR TX mouse OR TX bovine OR TX sheep OR TX ovine OR TX murine OR TX murinae | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 102,375
8 | S6 NOT S7 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 4,240
9 | S8 | Limiters - Published Date: 20140101–20221231; Language: English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,174
10 | S9 | Limiters - Education Level: Early Childhood Education, Elementary Education, Grade 1; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 195
11 | S9 AND (TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler*) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 716
12 | S10 OR S11 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 758
13 | “randomized controlled trial” OR “controlled clinical trial” OR TI randomized OR AB randomized OR TI randomly OR AB randomly OR TI trial OR AB trial OR TI groups OR AB groups | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 283,136
14 | S12 AND S13 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 294
15 | TX “systematic literature review” OR TX “systematic review” OR TX “meta-analysis” OR TX “meta-analyses” OR TX “meta synthesis” OR TX “Umbrella Review” | Limiters - Publication Type: Journal Articles, Reports - Evaluative, Reports - Research; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 9,129
16 | S12 AND S15 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 38
17 | TI “Diagnostic Errors” OR AB “Diagnostic Errors” OR DE “Psychological Stress” OR DE “Life Changes” OR DE “Prejudice” OR DE “Stereotyped Attitudes” OR DE “Self-Concept” OR DE “Academic Self Concept” OR DE “Self-Confidence” OR DE “Self-Congruence” OR DE “Self-Esteem” OR DE “Self-Forgiveness” OR DE “Self-Regard” OR DE “Self-Worth” OR DE “Sense of Coherence” OR DE “Patient Safety” OR TX harm* OR DE “Labeling” OR TX overdiagnos* OR DE “Stigma” OR DE “Self-Stigma” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 11,539
18 | S12 AND S17 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 3

### Linguistic and Language Behavior Abstracts (ProQuest), March 4, 2022

#### Linguistic and Language Behavior Abstracts Interventions and Harms of Interventions

SRs + MAs = 56; 45 imported

RCTs = 54; 19 imported

Harms = 55; 19 imported

#### All searches were done in Advanced Search limited to Specific date range Start January 1, 2014 End December 31, 2022

Limited to these Source Types:

- Scholarly Journals
- Working Papers

Limited to these Document Types:

- Article
- Evidence Based Healthcare
- Fund/Grant/Fellowship/Award
- Report
- Limited to Language: English

#### Search for Systematic Reviews

(((((MAINSUBJECT.EXPLODE("Communication Disorders") OR AB,TI("communication disorder*")) AND (dysarthria OR "developmental language disorder*" OR DLD OR "language development disorder*" OR "language impairment" OR (receptive AND expressive AND delay) OR ((speech* OR language*) AND (disorder* OR delay* OR patholog*)) OR "speech impairment")) NOT TI(autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")) AND (MAINSUBJECT("Bilingualism") OR MAINSUBJECT("Multilingualism") OR MAINSUBJECT("Communication Aids") OR MAINSUBJECT("Therapy") OR AB,TI(intervention*) OR treatment OR AB,TI("language facilitation") OR AB,TI(speech therapy) OR AB,TI(evaluation))) AND (boys OR child OR children* OR childhood OR girls OR infant* OR Kindergarten* OR neonat* OR newborn* OR pediatric* OR paediatric* OR Prekindergarten* OR Pre-kindergarten* OR Pre-k OR Preschool* OR Pre-school* OR Toddler*)) AND ("systematic literature review" OR "systematic review" OR "meta-analysis" OR "meta-analyses" OR "meta synthesis" OR "Umbrella Review")

#### Search for RCTs

(((((MAINSUBJECT.EXPLODE("Communication Disorders") OR AB,TI("communication disorder*")) AND (dysarthria OR "developmental language disorder*" OR DLD OR "language development disorder*" OR "language impairment" OR (receptive AND expressive AND delay) OR ((speech* OR language*) AND (disorder* OR delay* OR patholog*)) OR "speech impairment")) NOT TI(autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")) AND (MAINSUBJECT("Bilingualism") OR MAINSUBJECT("Multilingualism") OR MAINSUBJECT("Communication Aids") OR MAINSUBJECT("Therapy") OR AB,TI(intervention*) OR treatment OR AB,TI("language facilitation") OR AB,TI(speech therapy) OR AB,TI(evaluation))) AND (boys OR child OR children* OR childhood OR girls OR infant* OR Kindergarten* OR neonat* OR newborn* OR pediatric* OR paediatric* OR Prekindergarten* OR Pre-kindergarten* OR Pre-k OR Preschool* OR Pre-school* OR Toddler*)) AND ("randomized controlled trial" OR "controlled clinical trial" OR TI(randomized) OR AB(randomized) OR TI(randomly) OR AB(randomly) OR TI(trial) OR AB(trial) OR TI(groups) OR AB(groups))

#### Search for Harms

(((((MAINSUBJECT.EXPLODE("Communication Disorders") OR AB,TI("communication disorder*")) AND (dysarthria OR "developmental language disorder*" OR DLD OR "language development disorder*" OR "language impairment" OR (receptive AND expressive AND delay) OR ((speech* OR language*) AND (disorder* OR delay* OR patholog*)) OR "speech impairment")) NOT TI(autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")) AND (MAINSUBJECT("Bilingualism") OR MAINSUBJECT("Multilingualism") OR MAINSUBJECT("Communication Aids") OR MAINSUBJECT("Therapy") OR AB,TI(intervention*) OR treatment OR AB,TI("language facilitation") OR AB,TI(speech therapy) OR AB,TI(evaluation))) AND (boys OR child OR children* OR childhood OR girls OR infant* OR Kindergarten* OR neonat* OR newborn* OR pediatric* OR paediatric* OR Prekindergarten* OR Pre-kindergarten* OR Pre-k OR Preschool* OR Pre-school* OR Toddler*)) AND ("Diagnostic Errors" OR Stress OR "Life Change Events" OR "Prejudice" OR "Stereotyping" OR "Self Concept" OR "adverse effect*" OR harm* OR labeling OR overdiagnos* OR stigma*)

### PubMed, Screening, January 17, 2023

Search Number | Query | Filters | Results
1 | “Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh] | | 19,192
2 | “communication disorder*”[tiab] OR dysarthria[tw] OR “developmental language disorder*”[All Fields] OR DLD[tiab] OR “language development disorder*”[All Fields] OR “language impairment”[All Fields] OR (receptive[tiab] AND expressive[tiab] AND delay[tiab]) OR ((speech*[tiab] OR language*[tiab]) AND (disorder*[tiab] OR delay*[tiab] OR patholog*[tiab])) OR “speech impairment”[All Fields] | | 70,075
3 | #1 OR #2 | | 81,862
4 | “Diagnostic Techniques and Procedures”[Mesh] OR “Language Tests”[Mesh] OR “Mass Screening”[Mesh] OR “Psychological Tests”[Mesh] OR “case finding”[tiab] OR casefinding[tiab] OR instrument[tiab] OR inventory[tiab] OR questionnaire[tw] OR scale[tiab] OR screening[tiab] OR screened[tiab] OR screens[tiab] OR screen*[tiab] OR Surveillance[tw] OR Survey[tw] OR Test[tiab] OR tests[tiab] OR testing[tiab] OR Ages and Stages Questionnaire[Title/Abstract] OR Battelle Developmental Inventory Screening Test[Title/Abstract] OR Clinical Adaptive Test[Title/Abstract] OR “Clinical Linguistic and Auditory Milestone Scale”[All Fields] OR Denver Developmental Screening Test[Title/Abstract] OR Early Language Milestone Scale[Title/Abstract] OR Fluharty Preschool Speech[Title/Abstract] OR Infant-Toddler Checklist[Title/Abstract] OR Language Development Survey[Title/Abstract] OR McArthur-Bates Communicative Development Inventory[Title/Abstract] OR WILSTAAR[Title/Abstract] OR Preschool Language Scale[title/abstract] OR “Brigance Preschool Screen”[All Fields] OR “Denver Articulation Screening Exam”[All Fields] OR “Early Screening Profiles”[All Fields] OR “Northwestern Syntax Screening Test”[All Fields] OR “Sure Start Language Measure”[All Fields] | | 11,658,446
5 | #3 AND #4 | | 43,486
6 | #3 AND #4 | English | 41,908
7 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 12,223,188
8 | #6 NOT #7 | | 31,069
9 | #6 NOT #7 | Infant: 1–23 months | 2,479
10 | #6 NOT #7 | Infant: 1–23 months, Preschool Child: 2–5 years | 6,773
11 | #9 AND (boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR “first grade”[tw] OR girls[tw] OR infant*[tw] OR Kindergarten*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR Prekindergarten*[tw] OR Pre-kindergarten*[tw] OR Pre-k[tw] OR Preschool*[tw] OR Pre-school*[tw] OR Toddler*[tw]) | | 14,426
12 | #10 OR #11 | | 14,426
13 | #12 AND (“2021/10/04”[Date - Publication] : “3000”[Date - Publication]) | | 1,039
14 | “systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “cochrane database syst rev”[ta] OR “Umbrella Review”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] | | 377,106
15 | #13 AND #14 | | 82
16 | randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] OR groups [tiab] | | 3,590,536
17 | #13 AND #16 | | 302
18 | (cohort[all] OR (control[all] AND study[all]) OR (control[tw] AND group*[tw]) OR epidemiologic studies[mh] OR program[tw] OR clinical trial[pt] OR comparative stud*[all] OR evaluation studies[all] OR statistics as topic[mh] OR survey*[tw] OR follow-up*[all] OR time factors[all] OR ci[tw]) NOT ((animals[mh:noexp] NOT humans[mh:noexp]) OR comment[pt] OR editorial[pt] OR review[pt] OR meta analysis[pt] OR case report[tw] OR consensus[mh] OR guideline[pt] OR history[sh]) | | 8,982,150
19 | #13 AND #18 | | 529
20 | #15 NOT (#17 OR #19) | | 44
21 | #20 NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 36
22 | #17 NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 246
23 | #19 NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 455

### PubMed, Diagnostic Accuracy, January 17, 2023

Search Number | Query | Filters | Results
1 | “Communication Disorders”[Mesh] OR “Rehabilitation of Speech and Language Disorders”[Mesh] | | 74,707
2 | “communication disorder*”[tiab] OR dysarthria[tw] OR “developmental language disorder*”[All Fields] OR DLD[tiab] OR “language development disorder*”[All Fields] OR “language impairment”[All Fields] OR (receptive[tiab] AND expressive[tiab] AND delay[tiab]) OR ((speech*[tiab] OR language*[tiab]) AND (disorder*[tiab] OR delay*[tiab] OR patholog*[tiab])) OR “speech impairment”[All Fields] | | 70,075
3 | (#1 OR #2) NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 116,717
4 | (#1 OR #2) NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | English | 103,113
5 | #4 AND (“2021/10/04”[Date - Publication] : “3000”[Date - Publication]) | | 7,634
6 | “Diagnostic Techniques and Procedures”[Mesh] OR “Language Tests”[Mesh] OR “Mass Screening”[Mesh] OR “Psychological Tests”[Mesh] OR “case finding”[tiab] OR casefinding[tiab] OR instrument[tiab] OR inventory[tiab] OR questionnaire[tw] OR scale[tiab] OR screening[tiab] OR screened[tiab] OR screens[tiab] OR screen*[tiab] OR Surveillance[tw] OR Survey[tw] OR Test[tiab] OR tests[tiab] OR testing[tiab] | | 11,658,439
7 | #5 AND #6 | | 3,785
8 | “Risk”[Mesh] | | 1,363,961
9 | #5 AND #8 | | 90
10 | #7 OR #9 | | 3,825
11 | “Area Under Curve”[Mesh] OR “Diagnosis, Differential”[Mesh] OR “Diagnostic Techniques and Procedures”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “Likelihood Functions”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “Reproducibility of Results”[Mesh] OR “ROC Curve”[Mesh] OR “Sensitivity and Specificity”[Mesh] OR accuracy[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw] OR “predictive value”[tw] OR reproducib*[tw] OR ROC[tw] OR sensitivity[tw] OR specificity[tw] | | 9,812,102
12 | #10 AND #11 | | 1,401
13 | #10 AND #11 | Infant: 1–23 months | 60
14 | #10 AND #11 | Infant: 1–23 months, Preschool Child: 2–5 years | 133
15 | #12 AND (boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR “first grade”[tw] OR girls[tw] OR infant*[tw] OR Kindergarten*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR Prekindergarten*[tw] OR Pre-kindergarten*[tw] OR Pre-k[tw] OR Preschool*[tw] OR Pre-school*[tw] OR Toddler*[tw]) | | 377
16 | #14 OR #15 | | 377
17 | Ages and Stages Questionnaire[Title/Abstract] OR Battelle Developmental Inventory Screening Test[Title/Abstract] OR Clinical Adaptive Test[Title/Abstract] OR “Clinical Linguistic and Auditory Milestone Scale”[All Fields] OR Denver Developmental Screening Test[Title/Abstract] OR Early Language Milestone Scale[Title/Abstract] OR Fluharty Preschool Speech[Title/Abstract] OR Infant-Toddler Checklist[Title/Abstract] OR Language Development Survey[Title/Abstract] OR McArthur-Bates Communicative Development Inventory[Title/Abstract] OR WILSTAAR[Title/Abstract] OR Preschool Language Scale[title/abstract] | | 1,115
18 | “Brigance Preschool Screen”[All Fields] OR “Denver Articulation Screening Exam”[All Fields] OR “Early Screening Profiles”[All Fields] OR “Northwestern Syntax Screening Test”[All Fields] OR “Sure Start Language Measure”[All Fields] | | 26
19 | #17 OR #18 | | 1,138
20 | #19 AND #11 | | 412
21 | #19 AND #11 | English | 401
22 | #19 AND #11 | English, Infant: 1–23 months | 245
23 | #19 AND #11 | English, Infant: 1–23 months, Preschool Child: 2–5 years | 333
24 | #21 AND (boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR girls[tw] OR infant*[tw] OR Kindergarten*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR Prekindergarten*[tw] OR Pre-kindergarten*[tw] OR Pre-k[tw] OR Preschool*[tw] OR Pre-school*[tw] OR Toddler*[tw]) | | 401
25 | #23 OR #24 | | 401
26 | #16 OR #25 | | 775
27 | #26 AND (“2021/10/04”[Date - Publication] : “3000”[Date - Publication]) | | 402
28 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control” OR “case report*” OR “case series” OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 12,232,385
29 | #27 NOT #28 | | 341
30 | “systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “cochrane database syst rev”[ta] OR “Umbrella Review”[tiab] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] | | 400,644
31 | #29 AND #30 | | 24
32 | #29 NOT #31 | | 317

### PubMed, Interventions and Harms of Interventions, January 17, 2023

Search Number | Query | Filters | Results
1 | “Communication Disorders”[Mesh] OR “Rehabilitation of Speech and Language Disorders”[Mesh] | | 74,707
2 | “communication disorder*”[tiab] OR dysarthria[tw] OR “developmental language disorder*”[All Fields] OR DLD[tiab] OR “language development disorder*”[All Fields] OR “language impairment”[All Fields] OR (receptive[tiab] AND expressive[tiab] AND delay[tiab]) OR ((speech*[tiab] OR language*[tiab]) AND (disorder*[tiab] OR delay*[tiab] OR patholog*[tiab])) OR “speech impairment”[All Fields] | | 70,075
3 | (#1 OR #2) NOT (autism[ti] OR “down syndrome”[ti] OR “fragile syndrome”[ti] OR craniofacial[ti] OR “cleft palate”[ti]) | | 116,717
4 | “Communication Aids for Disabled”[Mesh] OR “Comparative Study” [Publication Type] OR “Early Medical Intervention”[Mesh] OR “Evaluation Studies” [Publication Type] OR “Evaluation Studies as Topic”[Mesh] OR “Epidemiologic Studies”[Mesh] OR Gestures[Mesh] OR Multilingualism[Mesh] OR “Outcome and Process Assessment, Health Care”[Mesh] OR “Rehabilitation of Speech and Language Disorders”[Mesh] OR “Therapy, Computer-Assisted”[Mesh] OR therapeutics[Mesh] OR therapy[subheading] OR treatment[sh] OR “intervention*”[tiab] OR “language facilitation”[tiab] OR “speech therapy”[tiab] | | 13,439,535
5 | #3 AND #4 | | 63,783
6 | #3 AND #4 | English | 56,966
7 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 12,223,188
8 | #6 NOT #7 | | 41,099
9 | #6 NOT #7 | Infant: 1–23 months | 3,072
10 | #6 NOT #7 | Infant: 1–23 months, Preschool Child: 2–5 years | 8,106
11 | #6 NOT #7 | Child: 6–12 years, Infant: 1–23 months, Preschool Child: 2–5 years | 16,103
12 | (boys[tw] OR child[tw] OR children*[tw] OR childhood[tw] OR girls[tw] OR infant*[tw] OR Kindergarten*[tw] OR neonat*[tw] OR newborn*[tw] OR pediatric*[tw] OR paediatric*[tw] OR Prekindergarten*[tw] OR Pre-kindergarten*[tw] OR Pre-k[tw] OR Preschool*[tw] OR Pre-school*[tw] OR Toddler*[tw]) | | 3,569,712
13 | #8 AND #12 | | 18,066
14 | #11 OR #13 | | 18,066
15 | #11 OR #13 | from 2021/10/4 – 3000/12/12 | 938
16 | randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] OR groups [tiab] | | 3,590,538
17 | #15 AND #16 | | 263
18 | “systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “cochrane database syst rev”[ta] OR “Umbrella Review”[tiab] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] | | 400,644
19 | #15 AND #18 | | 94
20 | #19 NOT #17 | | 60
21 | “Diagnostic Errors”[Mesh] OR “Stress, Physiological”[Mesh] OR “Life Change Events”[Mesh] OR “Prejudice”[Mesh] OR “Stereotyping”[Mesh] OR “Self Concept”[Mesh] OR “adverse effect*” OR harm* OR labeling OR overdiagnos* OR stigma* | | 3,535,850
22 | #15 AND #21 | | 69
23 | (cohort[all] OR (control[all] AND study[all]) OR (control[tw] AND group*[tw]) OR epidemiologic studies[mh] OR program[tw] OR clinical trial[pt] OR comparative stud*[all] OR evaluation studies[all] OR statistics as topic[mh] OR survey*[tw] OR follow-up*[all] OR time factors[all] OR ci[tw]) NOT ((animals[mh:noexp] NOT humans[mh:noexp]) OR comment[pt] OR editorial[pt] OR review[pt] OR meta analysis[pt] OR case report[tw] OR consensus[mh] OR guideline[pt] OR history[sh]) | | 8,982,150
24 | #22 AND #23 | | 37

### Cochrane Library, Screening, January 17, 2023

ID | Search | Hits
#1 | [mh “Communication Disorders”] | 1,983
#2 | ((“communication” NEXT disorder*):ti,ab OR dysarthria:ti,ab,kw OR (“developmental language” NEXT disorder*) OR DLD:ti,ab OR (“language development” NEXT disorder*) OR “language impairment” OR (receptive:ti,ab AND expressive:ti,ab AND delay:ti,ab) OR ((speech*:ti,ab OR language*:ti,ab) AND (disorder*:ti,ab OR delay*:ti,ab OR pathology*:ti,ab)) OR “speech impairment”) | 6,883
#3 | (#1 OR #2) NOT (autism:ti OR “down syndrome”:ti OR “fragile syndrome”:ti OR craniofacial:ti OR “cleft palate”:ti) | 7,896
#4 | [mh “Diagnostic Techniques and Procedures”] OR [mh “Language Tests”] OR [mh “Mass Screening”] OR [mh “Psychological Tests”] OR “case finding”:ti,ab OR casefinding:ti,ab OR instrument:ti,ab OR inventory:ti,ab OR questionnaire:ti,ab,kw OR scale:ti,ab OR screening:ti,ab OR screened:ti,ab OR screens:ti,ab OR screen*:ti,ab OR Surveillance:ti,ab,kw OR Survey:ti,ab,kw OR Test:ti,ab OR tests:ti,ab OR testing:ti,ab OR “Ages and Stages Questionnaire”:ti,ab OR “Battelle Developmental Inventory Screening Test”:ti,ab OR “Clinical Adaptive Test”:ti,ab OR “Clinical Linguistic and Auditory Milestone Scale” OR “Denver Developmental Screening Test”:ti,ab OR “Early Language Milestone Scale”:ti,ab OR “Fluharty Preschool Speech”:ti,ab OR “Infant Toddler Checklist”:ti,ab OR “Language Development Survey”:ti,ab OR “McArthur Bates Communicative Development Inventory”:ti,ab OR WILSTAAR:ti,ab OR “Preschool Language Scale”:ti,ab OR “Brigance Preschool Screen” OR “Denver Articulation Screening Exam” OR “Early Screening Profiles” OR “Northwestern Syntax Screening Test” OR “Sure Start Language Measure” | 791,611
#5 | #3 AND #4 | 5,106
#6 | address:pt OR autobiography:pt OR bibliography:pt OR biography:pt OR “case control”:ti,ab,kw OR “case report”:ti,ab,kw OR “case reports”:ti,ab,kw OR “case series”:ti,ab,kw OR comment:pt OR “comment on” OR congress:pt OR cross-sectional:ti,ab,kw OR dictionary:pt OR directory:pt OR editorial:pt OR festschrift:pt OR “historical article”:pt OR interview:pt OR lecture:pt OR “legal case”:pt OR legislation:pt OR letter:pt OR news:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh Animals] NOT [mh Humans]) OR rats:ti,ab,kw OR cow:ti,ab,kw OR cows:ti,ab,kw OR chicken:ti,ab,kw OR chickens:ti,ab,kw OR horse:ti,ab,kw OR horses:ti,ab,kw OR mice:ti,ab,kw OR mouse:ti,ab,kw OR bovine:ti,ab,kw OR sheep OR ovine OR murine OR murinae | 88,533
#7 | #5 NOT #6 | 3,826
#8 | #7 AND (boys:ti,ab,kw OR child:ti,ab,kw OR children*:ti,ab,kw OR childhood:ti,ab,kw OR ”first grade”:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR Kindergarten*:ti,ab,kw OR neonat*:ti,ab,kw OR newborn*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR Prekindergarten*:ti,ab,kw OR Pre-kindergarten*:ti,ab,kw OR Pre-k:ti,ab,kw OR Preschool*:ti,ab,kw OR Pre-school*:ti,ab,kw OR Toddler*:ti,ab,kw) | 1,278
#9 | #8 Limited to Years First Published between 2021 to 2023 | 191 (all results are trials)

### Cochrane Library, Diagnostic Accuracy, January 17, 2023

ID | Search | Hits
#1 | [mh “Communication Disorders”] OR [mh “Rehabilitation of Speech and Language Disorders”] | 2,267
#2 | (“communication” NEXT disorder*):ti,ab OR dysarthria:ti,ab,kw OR (“developmental language” NEXT disorder*) OR DLD:ti,ab OR (“language development” NEXT disorder*) OR “language impairment” OR (receptive:ti,ab AND expressive:ti,ab AND delay:ti,ab) OR ((speech*:ti,ab OR language*:ti,ab) AND (disorder*:ti,ab OR delay*:ti,ab OR pathology*:ti,ab)) OR “speech impairment” | 7,366
#3 | (#1 OR #2) NOT (autism:ti OR “down syndrome”:ti OR “fragile syndrome”:ti OR craniofacial:ti OR “cleft palate”:ti) | 8,483
#4 | [mh “Diagnostic Techniques and Procedures”] OR [mh “Language Tests”] OR [mh “Mass Screening”] OR [mh “Psychological Tests”] OR “case finding”:ti,ab OR casefinding:ti,ab OR instrument:ti,ab OR inventory:ti,ab OR questionnaire:ti,ab,kw OR scale:ti,ab OR screening:ti,ab OR screened:ti,ab OR screens:ti,ab OR screen*:ti,ab OR Surveillance:ti,ab,kw OR Survey:ti,ab,kw OR Test:ti,ab OR tests:ti,ab OR testing:ti,ab | 791,608
#5 | #3 AND #4 | 5,439
#6 | [mh “Risk”] | 39,729
#7 | #3 AND #6 | 105
#8 | #5 OR #7 | 5,483
#9 | [mh “Area Under Curve”] OR [mh “Diagnosis, Differential”] OR [mh “Diagnostic Techniques and Procedures”] OR [mh “False Negative Reactions”] OR [mh “False Positive Reactions”] OR [mh “Likelihood Functions”] OR [mh “Predictive Value of Tests”] OR [mh “Reproducibility of Results”] OR [mh “ROC Curve”] OR [mh “Sensitivity and Specificity”] OR accuracy:ti,ab,kw OR “false positive”:ti,ab,kw OR “false negative”:ti,ab,kw OR “likelihood ratio”:ti,ab,kw OR “predictive value”:ti,ab,kw OR reproducib*:ti,ab,kw OR ROC:ti,ab,kw OR sensitivity:ti,ab,kw OR specificity:ti,ab,kw | 333,608
#10 | #8 AND #9 | 1,343
#11 | #10 AND (boys:ti,ab,kw OR child:ti,ab,kw OR children*:ti,ab,kw OR childhood:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR Kindergarten*:ti,ab,kw OR neonat*:ti,ab,kw OR newborn*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR Prekindergarten*:ti,ab,kw OR Pre-kindergarten*:ti,ab,kw OR Pre-k:ti,ab,kw OR Preschool*:ti,ab,kw OR Pre-school*:ti,ab,kw OR Toddler*:ti,ab,kw) | 487
#12 | “Ages and Stages Questionnaire”:ti,ab OR “Battelle Developmental Inventory Screening Test”:ti,ab OR “Clinical Adaptive Test”:ti,ab OR “Clinical Linguistic and Auditory Milestone Scale” OR “Denver Developmental Screening Test”:ti,ab OR “Early Language Milestone Scale”:ti,ab OR “Fluharty Preschool Speech”:ti,ab OR “Infant Toddler Checklist”:ti,ab OR “Language Development Survey”:ti,ab OR “McArthur Bates Communicative Development Inventory”:ti,ab OR “WILSTAAR”:ti,ab OR “Preschool Language Scale”:ti,ab | 258
#13 | “Brigance Preschool Screen” OR “Denver Articulation Screening Exam” OR “Early Screening Profiles” OR “Northwestern Syntax Screening Test” OR “Sure Start Language Measure” | 1
#14 | #12 OR #13 | 259
#15 | #14 AND #9 | 37
#16 | #15 AND (boys:ti,ab,kw OR child:ti,ab,kw OR children*:ti,ab,kw OR childhood:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR Kindergarten*:ti,ab,kw OR neonat*:ti,ab,kw OR newborn*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR Prekindergarten*:ti,ab,kw OR Pre-kindergarten*:ti,ab,kw OR Pre-k:ti,ab,kw OR Preschool*:ti,ab,kw OR Pre-school*:ti,ab,kw OR Toddler*:ti,ab,kw) | 37
#17 | #11 OR #16 | 522
#18 | address:pt OR autobiography:pt OR bibliography:pt OR biography:pt OR comment:pt OR “comment on” OR congress:pt OR cross-sectional:ti,ab,kw OR dictionary:pt OR directory:pt OR editorial:pt OR festschrift:pt OR “historical article”:pt OR interview:pt OR lecture:pt OR “legal case”:pt OR legislation:pt OR letter:pt OR news:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh Animals] NOT [mh Humans]) OR rats:ti,ab,kw OR cow:ti,ab,kw OR cows:ti,ab,kw OR chicken:ti,ab,kw OR chickens:ti,ab,kw OR horse:ti,ab,kw OR horses:ti,ab,kw OR mice:ti,ab,kw OR mouse:ti,ab,kw OR bovine:ti,ab,kw OR sheep OR ovine OR murine OR murinae | 64,226
#19 | #17 NOT #18 | 366
#20 | #19 Limited to Years First Published between 2021 to 2023 | 27 (all results are trials)

### Cochrane Library, Interventions and Harms of Interventions, January 17, 2023

ID | Search | Hits
#1 | [mh “Communication Disorders”] OR [mh “Rehabilitation of Speech and Language Disorders”] | 2,267
#2 | ((“communication” NEXT disorder*):ti,ab OR dysarthria:ti,ab,kw OR (“developmental language” NEXT disorder*) OR DLD:ti,ab OR (“language development” NEXT disorder*) OR “language impairment” OR (receptive:ti,ab AND expressive:ti,ab AND delay:ti,ab) OR ((speech*:ti,ab OR language*:ti,ab) AND (disorder*:ti,ab OR delay*:ti,ab OR pathology*:ti,ab)) OR “speech impairment”) | 6,883
#3 | (#1 OR #2) NOT (autism:ti OR “down syndrome”:ti OR “fragile syndrome”:ti OR craniofacial:ti OR “cleft palate”:ti) | 8,135
#4 | [mh “Communication Aids for Disabled”] OR “Comparative Study”:pt OR [mh “Early Medical Intervention”] OR “Evaluation Studies”:pt OR [mh “Evaluation Studies as Topic”] OR [mh “Epidemiologic Studies”] OR [mh Gestures] OR [mh Multilingualism] OR [mh “Outcome and Process Assessment, Health Care”] OR [mh “Rehabilitation of Speech and Language Disorders”] OR [mh “Therapy, Computer-Assisted”] OR [mh therapeutics] OR [mh /TH] OR treatment:kw OR intervention*:ti,ab OR “language facilitation”:ti,ab OR “speech therapy”:ti,ab | 954,578
#5 | #3 AND #4 | 6,287
#6 | address:pt OR autobiography:pt OR bibliography:pt OR biography:pt OR “case control”:ti,ab,kw OR “case report”:ti,ab,kw OR “case reports”:ti,ab,kw OR “case series”:ti,ab,kw OR comment:pt OR “comment on” OR congress:pt OR cross-sectional:ti,ab,kw OR dictionary:pt OR directory:pt OR editorial:pt OR festschrift:pt OR “historical article”:pt OR interview:pt OR lecture:pt OR “legal case”:pt OR legislation:pt OR letter:pt OR news:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh Animals] NOT [mh Humans]) OR rats:ti,ab,kw OR cow:ti,ab,kw OR cows:ti,ab,kw OR chicken:ti,ab,kw OR chickens:ti,ab,kw OR horse:ti,ab,kw OR horses:ti,ab,kw OR mice:ti,ab,kw OR mouse:ti,ab,kw OR bovine:ti,ab,kw OR sheep OR ovine OR murine OR murinae | 88,533
#7 | #5 NOT #6 | 4,391
#8 | (boys:ti,ab,kw OR child:ti,ab,kw OR children*:ti,ab,kw OR childhood:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR Kindergarten*:ti,ab,kw OR neonat*:ti,ab,kw OR newborn*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR Prekindergarten*:ti,ab,kw OR Pre-kindergarten*:ti,ab,kw OR Pre-k:ti,ab,kw OR Preschool*:ti,ab,kw OR Pre-school*:ti,ab,kw OR Toddler*:ti,ab,kw) | 230,223
#9 | #7 AND #8 | 1,579
#10 | #9 Limited to Years First Published between 2022 to 2023 | 239 (all results are trials)

### APA PsycInfo, Screening, January 17, 2023

# | Query | Limiters/Expanders | Results
1 | DE “Communication Disorders” OR DE “Language Disorders” OR DE “Speech Disorders” OR DE “Language Delay” | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 19,031
2 | TI “communication disorder*” OR AB “communication disorder*” OR DE “Dysarthria” OR TX dysarthria OR TX “developmental language disorder*” OR TI DLD OR AB DLD OR TX “language development disorder*” OR TX “language impairment” OR (TI receptive AND TI expressive AND TI delay) OR (AB receptive AND AB expressive AND AB delay) OR ((TI speech* OR TI language*) AND (TI disorder* OR TI delay* OR TI athology*)) OR ((AB speech* OR AB language*) AND (AB disorder* OR AB delay* OR AB athology*)) OR TX “speech impairment” | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 47,386
3 | ( S1 OR S2 ) NOT ( (TI autism OR TI “down syndrome” OR TI “fragile syndrome” OR TI craniofacial OR TI “cleft palate”) ) | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 50,061
4 | DE “Diagnostic Criteria” OR DE “Screening” OR DE “Screening Tests” OR DE “Questionnaires” OR DE “Testing” OR DE “Surveys” OR TI “case finding” OR AB “case finding” OR TI casefindng OR AB casefinding OR TI instrument OR AB instrument OR TI inventory OR AB inventory OR TI questionnaire OR AB questionnaire OR TI scale OR AB scale OR TI screening OR AB screening OR TI screened OR AB screened OR TI screens OR TI screens OR TI screen* OR AB screen* OR TX surveillance OR TX survey OR TI test OR AB test OR TI tests OR AB tests OR TI testing OR AB testing | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 1,611,251
5 | TX “Ages and Stages Questionnaire” OR TX “Battelle Developmental Inventory Screening Test” OR TX “Clinical Adaptive Test” OR TX “Clinical Linguistic and Auditory Milestone Scale” OR TX “Denver Developmental Screening Test” OR TX “Early Language Milestone Scale” OR TX “Fluharty Preschool Speech” OR TX “Infant-Toddler Checklist” OR TX “Language Development Survey” OR TX “McArthur-Bates Communicative Development Inventory” OR TX WILSTAAR OR TX “Preschool Language Scale” OR TX “Brigance Preschool Screen” OR TX “Denver Articulation Screening Exam” OR TX “Early Screening Profiles” OR TX “Northwestern Syntax Screening Test” OR TX “Sure Start Language Measure” | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 1,848
6 | S4 OR S5 | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 1,611,884
7 | S3 AND S6 | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 16,529
8 | DE “Autobiography” OR DE “Biography” OR DE “Case Report” OR DE “Newspapers” (DE “Biography” OR DE “Newspapers” OR TX “comment on” OR TW “case report*” OR TX “case series” OR TX congress OR TX “cross-sectional” OR TX dictionary OR TX directory OR TX editorial OR TX festschrift OR TX “legal case” OR TX legislation OR TX “patient education handout” OR TX “periodical index” OR TX rats OR TX cow OR TX cows OR TX chicken OR TX chickens OR TX horse OR TX horses OR TX mice OR TX mouse OR TX bovine OR TX sheep OR TX ovine OR TX murine OR TX murinae | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 680,692
9 | S7 NOT S8 | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 15,247
10 | S9 | Limiters – English; Language: English; Population Group: Human; Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 13,586
11 | S10 | Limiters – Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs); Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 3,031
12 | TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI “first grade” OR AB “first grade” OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler* | Limiters – Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs); Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 149,226
13 | S10 AND S12 | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 2,828
14 | S11 OR S13 | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 3,031
15 | S14 | Limiters – Published Date: 20211001–20231231; Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 91
16 | S15 | Limiters – Methodology: -Systematic Review, META ANALYSIS, METASYNTHESIS; Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 4
17 | “randomized controlled trial” OR “controlled clinical trial” OR TI randomized OR AB randomized OR TI randomly OR AB randomly OR TI trial OR AB trial OR TI groups OR AB groups | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 1,163,206
18 | S15 AND S17 | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 37
19 | (TX cohort OR (TX control AND TX study) OR (TX control AND TX group*) OR TX “epidemiologic stud*” OR TX program OR MR “clinical trial” OR TX “comparative stud*” OR TX “evaluation stud*” OR TX survey* OR DE “Followup Studies” OR TX “follow-up*” OR TX “time factors”) NOT ((PO Animal NOT PO Human) OR TI editorial OR AB editorial OR DE “Literature Review” OR MR “meta analysis” OR TI consensus OR AB consensus OR TI guideline OR AB guideline) | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 1,578,343
20 | S15 AND S19 | Expanders – Apply equivalent subjects; Search modes – Find all my search terms | 44

### APA PsycInfo, Diagnostic Accuracy, January 17, 2023

# | Query | Limiters/Expanders | Results
1 | DE “Communication Disorders” OR DE “Language Disorders” OR DE “Speech Disorders” OR DE “Language Delay” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 19,031
2 | TI “communication disorder*” OR AB “communication disorder*” OR DE “Dysarthria” OR TX dysarthria OR TX “developmental language disorder*” OR TI DLD OR AB DLD OR TX “language development disorder*” OR TX “language impairment” OR (TI receptive AND TI expressive AND TI delay) OR (AB receptive AND AB expressive AND AB delay) OR ((TI speech* OR TI language*) AND (TI disorder* OR TI delay* OR TI patholog*)) OR ((AB speech* OR AB language*) AND (AB disorder* OR AB delay* OR AB patholog*)) OR TX “speech impairment” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 47,386
3 | ( S1 OR S2 ) NOT ( (TI autism OR TI “down syndrome” OR TI “fragile syndrome” OR TI craniofacial OR TI “cleft palate”) ) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 50,061
4 | S3 | Limiters - English; Language: English; Population Group: Human; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 44,071
5 | S4 | Limiters - Published Date: 20211001–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,246
6 | DE “Diagnostic Criteria” OR DE “Screening” OR DE “Screening Tests” OR DE “Questionnaires” OR DE “Testing” OR DE “Surveys” OR TI “case finding” OR AB “case finding” OR TI casefindng OR AB casefinding OR TI instrument OR AB instrument OR TI inventory OR AB inventory OR TI questionnaire OR AB questionnaire OR TI scale OR AB scale OR TI screening OR AB screening OR TI screened OR AB screened OR TI screens OR TI screens OR TI screen* OR AB screen* OR TX surveillance OR TX survey OR TI test OR AB test OR TI tests OR AB tests OR TI testing OR AB testing | Limiters - Published Date: 20211001–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 67,035
7 | S5 AND S6 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 559
8 | DE “Risk Assessment” OR DE “Risk Factors” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 169,152
9 | S5 AND S8 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 32
10 | S7 OR S9 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 575
11 | TX accuracy OR TX “Area Under Curve” OR DE “Differential Diagnosis” OR TX “Diagnostic Technique*” OR TX “Diagnostic Procedur*” OR TX “False Negative” OR TX “False Positive” OR TX “likelihood function*” OR TX “likelihood ratio” OR DE “Predictive Validity” OR TX “predictive value” OR TX reproducib* OR TX ROC OR TX sensitivity OR TX specificity | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 322,459
12 | S10 AND S11 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 100
13 | S12 | Limiters - Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs); Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 15
14 | S12 AND (TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler*) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 25
15 | S13 OR S14 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 27
16 | TX “Ages and Stages Questionnaire” OR TX “Battelle Developmental Inventory Screening Test” OR TX “Clinical Adaptive Test” OR TX “Clinical Linguistic and Auditory Milestone Scale” OR TX “Denver Developmental Screening Test” OR TX “Early Language Milestone Scale” OR TX “Fluharty Preschool Speech” OR TX “Infant-Toddler Checklist” OR TX “Language Development Survey” OR TX “McArthur-Bates Communicative Development Inventory” OR TX WILSTAAR OR TX “Preschool Language Scale” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,762
17 | “Brigance Preschool Screen” OR TX “Denver Articulation Screening Exam” OR TX “Early Screening Profiles” OR TX “Northwestern Syntax Screening Test” OR TX “Sure Start Language Measure” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 98
18 | S16 OR S17 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,848
19 | S18 | Limiters - English; Language: English; Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs); Population Group: Human; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,354
20 | S19 AND (TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler*) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,250
21 | S19 OR S20 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,354
22 | S21 | Limiters - Published Date: 20211001–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 43
23 | DE “Autobiography” OR DE “Biography” OR DE “Case Report” OR DE “Newspapers” (DE “Biography” OR DE “Newspapers” OR TX “comment on” OR TW “case report*” OR TX “case series” OR TX “case stud*” OR TX congress OR TX “cross-sectional” OR TX dictionary OR TX directory OR TX editorial OR TX festschrift OR TX “legal case” OR TX legislation OR TX “patient education handout” OR TX “periodical index” OR TX rats OR TX cow OR TX cows OR TX chicken OR TX chickens OR TX horse OR TX horses OR TX mice OR TX mouse OR TX bovine OR TX sheep OR TX ovine OR TX murine OR TX murinae | Limiters - Published Date: 20211001–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 25,742
24 | S22 NOT S23 | Limiters - Published Date: 20211001–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 38
25 | S15 OR S24 | Limiters - Published Date: 20211001–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 65
26 | S25 AND PO Human | Limiters - Published Date: 20211001–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 65
27 | S26 | Limiters - Methodology: -Systematic Review, META ANALYSIS, METASYNTHESIS; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1
28 | S26 NOT S27 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 64

### APA PsycInfo, Interventions and Harms of Interventions, January 17, 2023

# | Query | Limiters/Expanders | Results
1 | DE “Communication Disorders” OR DE “Language Disorders” OR DE “Speech Disorders” OR DE “Language Delay” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 19,031
2 | TI “communication disorder*” OR AB “communication disorder*” OR DE “Dysarthria” OR TX dysarthria OR TX “developmental language disorder*” OR TI DLD OR AB DLD OR TX “language development disorder*” OR TX “language impairment” OR (TI receptive AND TI expressive AND TI delay) OR (AB receptive AND AB expressive AND AB delay) OR ((TI speech* OR TI language*) AND (TI disorder* OR TI delay* OR TI patholog*)) OR ((AB speech* OR AB language*) AND (AB disorder* OR AB delay* OR AB patholog*)) OR TX “speech impairment” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 47,386
3 | (S1 OR S2) NOT (TI autism OR TI “down syndrome” OR TI “fragile syndrome” OR TI craniofacial OR TI “cleft palate") | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 50,061
4 | DE “Speech Therapy” OR DE “Language Therapy” OR DE “Treatment” OR DE “Adjunctive Treatment” OR DE “Anxiety Management” OR DE “Behavior Modification” OR DE “Cognitive Techniques” OR DE “Computer Assisted Therapy” OR DE “Counseling” OR DE “Culturally Adapted Interventions” OR DE “Habilitation” OR DE “Interdisciplinary Treatment Approach” OR DE “Intervention” OR DE “Early Intervention” OR DE “Multimodal Treatment Approach” OR DE “Outpatient Treatment” OR DE “Personal Therapy” OR DE “Physical Treatment Methods” OR DE “Psychoeducation” OR DE “Psychotherapy” OR DE “Rehabilitation” OR DE “Self-Help Techniques” OR DE “Symptoms Based Treatment” OR DE “Therapeutic Processes” OR DE “Video-Based Interventions” OR DE “Gestures” OR DE “Multilingualism” OR DE “Bilingualism” OR TX “communication aids” OR TX “comparative stud*” OR TX “early medical intervention*” OR TX “evaluation stud*” OR TX “epidemiologic stud*” OR TI treatment OR AB treatment OR TI “language facilitation” OR AB “language facilitation” OR TI “speech therapy” OR AB “speech therapy” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 947,464
5 | S3 AND S4 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 15,098
6 | S5 | Limiters - English; Language: English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 14,075
7 | DE “Autobiography” OR DE “Biography” OR DE “Case Report” OR DE “Newspapers” (DE “Biography” OR DE “Newspapers” OR TX “comment on” OR TW “case report*” OR TX “case series” OR TX congress OR TX “cross-sectional” OR TX dictionary OR TX directory OR TX editorial OR TX festschrift OR TX “legal case” OR TX legislation OR TX “patient education handout” OR TX “periodical index” OR TX rats OR TX cow OR TX cows OR TX chicken OR TX chickens OR TX horse OR TX horses OR TX mice OR TX mouse OR TX bovine OR TX sheep OR TX ovine OR TX murine OR TX murinae | Limiters - English; Language: English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 657,094
8 | S6 NOT S7 | Limiters - English; Language: English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 12,793
9 | S8 AND PO Human | Limiters - English; Language: English; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 12,291
10 | S9 | Limiters - Age Groups: Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs); Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 2,102
11 | S9 AND (TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler*) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 5,478
12 | S10 OR S11 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 5,595
13 | S12 | Limiters - Published Date: 20211001–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 163
14 | “randomized controlled trial” OR “controlled clinical trial” OR TI randomized OR AB randomized OR TI randomly OR AB randomly OR TI trial OR AB trial OR TI groups OR AB groups | Limiters - Published Date: 20211001–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 46,365
15 | S13 AND S14 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 60
16 | S13 | Limiters - Methodology: -Systematic Review, META ANALYSIS, METASYNTHESIS; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 9
17 | S16 NOT S15 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 4
18 | TI “Diagnostic Errors” OR AB “Diagnostic Errors” OR DE “Psychological Stress” OR DE “Life Changes” OR DE “Prejudice” OR DE “Stereotyped Attitudes” OR DE “Self-Concept” OR DE “Academic Self Concept” OR DE “Self-Confidence” OR DE “Self-Congruence” OR DE “Self-Esteem” OR DE “Self-Forgiveness” OR DE “Self-Regard” OR DE “Self-Worth” OR DE “Sense of Coherence” OR DE “Patient Safety” OR TX harm* OR DE “Labeling” OR TX overdiagnos* OR DE “Stigma” OR DE “Self-Stigma” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 224,271
19 | S13 AND S18 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 3
20 | (TX cohort OR (TX control AND TX study) OR (TX control AND TX group*) OR TX “epidemiologic stud*” OR TX program OR MR “clinical trial” OR TX “comparative stud*” OR TX “evaluation stud*” OR TX survey* OR DE “Followup Studies” OR TX “follow-up*” OR TX “time factors”) NOT ((PO Animal NOT PO Human) OR TI editorial OR AB editorial OR DE “Literature Review” OR MR “meta analysis” OR TI consensus OR AB consensus OR TI guideline OR AB guideline) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 1,578,343
21 | S19 AND S20 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 2

### ERIC, Interventions and Harms of Interventions, January 18, 2023

# | Query | Limiters/Expanders | Results
1 | DE “Aphasia” OR DE “Articulation Impairments” OR DE “Communication Disorders” OR DE “Delayed Speech” OR DE “Language Impairments” OR OR DE “Receptive Language” OR DE “Speech Impairments” OR DE “Speech Language Pathology” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 6,770
2 | TI “communication disorder*” OR AB “communication disorder*” OR TX dysarthria OR TX “developmental language disorder*” OR TI DLD OR AB DLD OR TX “language development disorder*” OR TX “language impairment” OR (TI receptive AND TI expressive AND TI delay) OR (AB receptive AND AB expressive AND AB delay) OR ((TI speech* OR TI language*) AND (TI disorder* OR TI delay* OR TI patholog*)) OR ((AB speech* OR AB language*) AND (AB disorder* OR AB delay* OR AB patholog*)) OR TX “speech impairment” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 11,294
3 | S1 OR S2 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 14,583
4 | (S1 OR S2) NOT (TI autism OR TI “down syndrome” OR TI “fragile syndrome” OR TI craniofacial OR TI “cleft palate") | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 13,033
5 | DE “Speech Therapy” OR DE “Behavior Modification” OR DE “Applied Behavior Analysis” OR DE “Contingency Management” OR DE “Positive Behavior Supports” OR DE “Counseling” OR OR DE “Family Counseling” OR DE “Individual Counseling” OR DE “Parent Counseling” OR DE “School Counseling” OR DE “Intervention” OR DE “Early Intervention” OR DE “Prereferral Intervention” OR DE “Response to Intervention” OR DE “Personal Therapy” OR DE “Psychotherapy” OR DE “Rehabilitation” OR DE “Therapy” OR DE “Educational Therapy” OR DE “Therapeutic Recreation” OR DE “Multilingualism” OR DE “Bilingualism” OR TX “communication aids” OR TX “comparative stud*” OR TX “early medical intervention*” OR TX “evaluation stud*” OR TX “epidemiologic stud*” OR TI treatment OR AB treatment OR TI “language facilitation” OR AB “language facilitation” OR TI “speech therapy” OR AB “speech therapy” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 144,877
6 | S4 AND S5 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 4,665
7 | DE “Autobiography” OR DE “Biography” OR DE “Case Report” OR DE “Newspapers” (DE “Biography” OR DE “Newspapers” OR TX “comment on” OR TW “case report*” OR TX “case series” OR TX congress OR TX “cross-sectional” OR TX dictionary OR TX directory OR TX editorial OR TX festschrift OR TX “legal case” OR TX legislation OR TX “patient education handout” OR TX “periodical index” OR TX rats OR TX cow OR TX cows OR TX chicken OR TX chickens OR TX horse OR TX horses OR TX mice OR TX mouse OR TX bovine OR TX sheep OR TX ovine OR TX murine OR TX murinae | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 102,447
8 | S6 NOT S7 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 4,461
9 | S8 | Limiters - Published Date: 20210101–20231231; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 373
10 | S9 | Limiters - Education Level: Early Childhood Education, Elementary Education, Grade 1; Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 63
11 | S9 AND (TI boys OR AB boys OR TI child OR AB child OR TI Children* OR AB Children* OR TI childhood OR AB childhood OR TI girls OR AB girls OR TI Kindergarten* OR AB Kindergarten* OR TO Prekindergarten* OR AB Prekindergarten* OR TI Pre-k OR AB Pre-k OR TI Pre-kindergarten* OR AB Pre-kindergarten* OR TI Preschool* OR AB Preschool* OR TI Pre-school* OR AB Pre-school* OR TI pediatric* OR AB pediatric* OR TI paediatric* OR AB paediatric* OR TI Toddler* OR AB Toddler*) | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 211
12 | S10 OR S11 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 224
13 | “randomized controlled trial” OR “controlled clinical trial” OR TI randomized OR AB randomized OR TI randomly OR AB randomly OR TI trial OR AB trial OR TI groups OR AB groups | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 293,396
14 | S12 AND S13 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 99
15 | TX “systematic literature review” OR TX “systematic review” OR TX “meta-analysis” OR TX “meta-analyses” OR TX “meta synthesis” OR TX “Umbrella Review” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 11,006
16 | S12 AND S15 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 16
17 | TI “Diagnostic Errors” OR AB “Diagnostic Errors” OR DE “Psychological Stress” OR DE “Life Changes” OR DE “Prejudice” OR DE “Stereotyped Attitudes” OR DE “Self-Concept” OR DE “Academic Self Concept” OR DE “Self-Confidence” OR DE “Self-Congruence” OR DE “Self-Esteem” OR DE “Self-Forgiveness” OR DE “Self-Regard” OR DE “Self-Worth” OR DE “Sense of Coherence” OR DE “Patient Safety” OR TX harm* OR DE “Labeling” OR TX overdiagnos* OR DE “Stigma” OR DE “Self-Stigma” | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 12,029
18 | S12 AND S17 | Expanders - Apply equivalent subjects; Search modes - Find all my search terms | 2

### Linguistic and Language Behavior Abstracts (ProQuest), January 18, 2023

#### Linguistic and Language Behavior Abstracts Interventions and Harms of Interventions

SRs + MAs = 14; 13 imported

RCTs = 10; 2 imported

Harms = 10; 2 imported

#### All searches were done in Advanced Search limited to Specific date range Start October 4, 2021; End December 31, 2023

Limited to these Source Types:

- Scholarly Journals
- Working Papers

Limited to these Document Types:

- Article
- Evidence Based Healthcare
- Fund/Grant/Fellowship/Award
- Report
- Limited to Language: English

#### Search for Systematic Reviews

(((((MAINSUBJECT.EXPLODE("Communication Disorders") OR AB,TI("communication disorder*")) AND (dysarthria OR "developmental language disorder*" OR DLD OR "language development disorder*" OR "language impairment" OR (receptive AND expressive AND delay) OR ((speech* OR language*) AND (disorder* OR delay* OR patholog*)) OR "speech impairment")) NOT TI(autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")) AND (MAINSUBJECT("Bilingualism") OR MAINSUBJECT("Multilingualism") OR MAINSUBJECT("Communication Aids") OR MAINSUBJECT("Therapy") OR AB,TI(intervention*) OR treatment OR AB,TI("language facilitation") OR AB,TI(speech therapy) OR AB,TI(evaluation))) AND (boys OR child OR children* OR childhood OR girls OR infant* OR Kindergarten* OR neonat* OR newborn* OR pediatric* OR paediatric* OR Prekindergarten* OR Pre-kindergarten* OR Pre-k OR Preschool* OR Pre-school* OR Toddler*)) AND ("systematic literature review" OR "systematic review" OR "meta-analysis" OR "meta-analyses" OR "meta synthesis" OR "Umbrella Review")

#### Search for RCTs

(((((MAINSUBJECT.EXPLODE("Communication Disorders") OR AB,TI("communication disorder*")) AND (dysarthria OR "developmental language disorder*" OR DLD OR "language development disorder*" OR "language impairment" OR (receptive AND expressive AND delay) OR ((speech* OR language*) AND (disorder* OR delay* OR patholog*)) OR "speech impairment")) NOT TI(autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")) AND (MAINSUBJECT("Bilingualism") OR MAINSUBJECT("Multilingualism") OR MAINSUBJECT("Communication Aids") OR MAINSUBJECT("Therapy") OR AB,TI(intervention*) OR treatment OR AB,TI("language facilitation") OR AB,TI(speech therapy) OR AB,TI(evaluation))) AND (boys OR child OR children* OR childhood OR girls OR infant* OR Kindergarten* OR neonat* OR newborn* OR pediatric* OR paediatric* OR Prekindergarten* OR Pre-kindergarten* OR Pre-k OR Preschool* OR Pre-school* OR Toddler*)) AND ("randomized controlled trial" OR "controlled clinical trial" OR TI(randomized) OR AB(randomized) OR TI(randomly) OR AB(randomly) OR TI(trial) OR AB(trial) OR TI(groups) OR AB(groups))

#### Search for Harms

(((((MAINSUBJECT.EXPLODE("Communication Disorders") OR AB,TI("communication disorder*")) AND (dysarthria OR "developmental language disorder*" OR DLD OR "language development disorder*" OR "language impairment" OR (receptive AND expressive AND delay) OR ((speech* OR language*) AND (disorder* OR delay* OR patholog*)) OR "speech impairment")) NOT TI(autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")) AND (MAINSUBJECT("Bilingualism") OR MAINSUBJECT("Multilingualism") OR MAINSUBJECT("Communication Aids") OR MAINSUBJECT("Therapy") OR AB,TI(intervention*) OR treatment OR AB,TI("language facilitation") OR AB,TI(speech therapy) OR AB,TI(evaluation))) AND (boys OR child OR children* OR childhood OR girls OR infant* OR Kindergarten* OR neonat* OR newborn* OR pediatric* OR paediatric* OR Prekindergarten* OR Pre-kindergarten* OR Pre-k OR Preschool* OR Pre-school* OR Toddler*)) AND ("Diagnostic Errors" OR Stress OR "Life Change Events" OR "Prejudice" OR "Stereotyping" OR "Self Concept" OR "adverse effect*" OR harm* OR labeling OR overdiagnos* OR stigma*)

### Grey Literature

#### ClinicalTrials.gov Advanced/Expert Search, January 18, 2023

Screening and Diagnostic Accuracy: 40 results; 40 imported to EndNote

##### Condition box

“Developmental Language Disorder” OR “Developmental Language Disorders” OR “Developmental Language Disorder and Language Impairment” OR Dysarthria OR “Language Development Disorders” OR “Language Delay” OR “Language Development” OR “Language; Developmental Disorder, Expressive” OR “Language Disorder” OR “Language Disorders” OR “Language Impairment” OR “Specific Language Impairment” OR “Speech and Language Disorder” OR “Speech Articulation Disorder” OR “Speech Disorders” OR “Speech Disorders in Children” OR “Speech Sound Disorder” OR “Speech Sound Disorders” OR dysarthria OR EXPAND[Concept] "developmental language disorder" OR DLD OR EXPAND[Concept] "language development disorder" OR EXPAND[Concept] "language impairment" OR receptive AND expressive AND delay OR ( speech* OR language* ) AND ( disorder* OR delay* OR patholog* ) OR EXPAND[Concept] "speech impairment"

##### Intervention box

("Diagnostic Techniques and Procedures" OR "Language Tests" OR "Psychological Tests" OR instrument* OR inventory OR questionnaire* OR scale OR screening OR "Area Under Curve" OR "differential diagnosis" OR "Diagnostic Techniques and Procedures" OR "Likelihood Functions" OR "Predictive Value of Tests" OR accuracy OR "false positive" OR "false negative" OR "likelihood ratio" OR "predictive value" OR reproducib* OR ROC OR sensitivity OR specificity) NOT ( pharmacotherap* OR Drug* OR medicin* OR surg* OR Placebo OR autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")

##### Together in Expert Search:

AREA[ConditionSearch] (( “Developmental Language Disorder” OR “Developmental Language Disorders” OR “Developmental Language Disorder and Language Impairment” OR Dysarthria OR “Language Development Disorders” OR “Language Delay” OR “Language Development” OR “Language; Developmental Disorder, Expressive” OR “Language Disorder” OR “Language Disorders” OR “Language Impairment” OR “Specific Language Impairment” OR “Speech and Language Disorder” OR “Speech Articulation Disorder” OR “Speech Disorders” OR “Speech Disorders in Children” OR “Speech Sound Disorder” OR “Speech Sound Disorders” ) OR (dysarthria OR "developmental language disorder" OR DLD OR "language development disorder" OR "language impairment" OR (receptive AND expressive AND delay) OR ((speech* OR language*) AND (disorder* OR delay* OR patholog*)) OR "speech impairment")) AND AREA[InterventionSearch] ( ( EXPAND[Concept] "Diagnostic Techniques and Procedures" OR EXPAND[Concept] "Language Tests" OR EXPAND[Concept] "Psychological Tests" OR instrument* OR inventory OR questionnaire* OR scale OR screening OR EXPAND[Concept] "Area Under Curve" OR EXPAND[Concept] "differential diagnosis" OR EXPAND[Concept] "Diagnostic Techniques and Procedures" OR EXPAND[Concept] "Likelihood Functions" OR EXPAND[Concept] "Predictive Value of Tests" OR accuracy OR EXPAND[Concept] "false positive" OR EXPAND[Concept] "false negative" OR EXPAND[Concept] "likelihood ratio" OR EXPAND[Concept] "predictive value" OR reproducib* OR ROC OR sensitivity OR specificity ) AND NOT ( pharmacotherap* OR Drug* OR medicin* OR surg* OR Placebo OR autism OR EXPAND[Concept] "down syndrome" OR EXPAND[Concept] "fragile syndrome" OR craniofacial OR EXPAND[Concept] "cleft palate" ) ) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] "Child" AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[01/01/2014, 01/18/2023]

Limited to children and Last Update 1/1/2014 – 01/18/2023

Interventions: 134 results; 113 imported to EndNote

##### Condition box

“Developmental Language Disorder” OR “Developmental Language Disorders” OR “Developmental Language Disorder and Language Impairment” OR Dysarthria OR “Language Development Disorders” OR “Language Delay” OR “Language Development” OR “Language; Developmental Disorder, Expressive” OR “Language Disorder” OR “Language Disorders” OR “Language Impairment” OR “Specific Language Impairment” OR “Speech and Language Disorder” OR “Speech Articulation Disorder” OR “Speech Disorders” OR “Speech Disorders in Children” OR “Speech Sound Disorder” OR “Speech Sound Disorders” OR dysarthria OR EXPAND[Concept] "developmental language disorder" OR DLD OR EXPAND[Concept] "language development disorder" OR EXPAND[Concept] "language impairment" OR receptive AND expressive AND delay OR ( speech* OR language* ) AND ( disorder* OR delay* OR patholog* ) OR EXPAND[Concept] "speech impairment"

##### Intervention box

(Bilingualism OR "Communication Aids for Disabled" OR "Comparative Study" OR "Early Medical Intervention" OR "Evaluation Study" OR "Epidemiologic Study" OR Gestures OR “family workshop” OR “Intensive Language Action Therapy” OR intervention* OR "language facilitation" OR “Language Therapy” OR Multilingualism OR "Outcome and Process Assessment" OR “Parent-implemented intervention” OR “Rehabilitation of Speech and Language Disorders” OR “Speech and Language Therapy” OR “Speech Therapy” OR "Therapy, Computer-Assisted" OR therapeutics OR treatment*) NOT (pharmacotherap* OR Drug* OR medicin* OR surg* Placebo OR autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")

Limited to children and Last Update 1/1/2014 – 01/18/2023

##### Together in Expert Search

AREA[ConditionSearch] ( “Developmental Language Disorder” OR “Developmental Language Disorders” OR “Developmental Language Disorder and Language Impairment” OR Dysarthria OR “Language Development Disorders” OR “Language Delay” OR “Language Development” OR “Language; Developmental Disorder, Expressive” OR “Language Disorder” OR “Language Disorders” OR “Language Impairment” OR “Specific Language Impairment” OR “Speech and Language Disorder” OR “Speech Articulation Disorder” OR “Speech Disorders” OR “Speech Disorders in Children” OR “Speech Sound Disorder” OR “Speech Sound Disorders” OR dysarthria OR EXPAND[Concept] "developmental language disorder" OR DLD OR EXPAND[Concept] "language development disorder" OR EXPAND[Concept] "language impairment" OR receptive AND expressive AND delay OR ( speech* OR language* ) AND ( disorder* OR delay* OR patholog* ) OR EXPAND[Concept] "speech impairment" ) AND AREA[InterventionSearch] ((Bilingualism OR "Communication Aids for Disabled" OR "Comparative Study" OR "Early Medical Intervention" OR "Evaluation Study" OR "Epidemiologic Study" OR Gestures OR “family workshop” OR “Intensive Language Action Therapy” OR intervention* OR "language facilitation" OR “Language Therapy” OR Multilingualism OR "Outcome and Process Assessment" OR “Parent-implemented intervention” OR “Rehabilitation of Speech and Language Disorders” OR “Speech and Language Therapy” OR “Speech Therapy” OR "Therapy, Computer-Assisted" OR therapeutics OR treatment* ) NOT (pharmacotherap* OR Drug* OR medicin* OR surg* Placebo OR autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] "Child" AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[01/01/2014, 01/18/2023]

#### WHO International Clinical Trials Registry Platform (WHO ICTRP), January 18, 2023

Screening and Diagnostic Accuracy Search: 7 results, 7 imported to EndNote

##### Condition box

“Developmental Language Disorder” OR “Developmental Language Disorders” OR “Developmental Language Disorder and Language Impairment” OR Dysarthria OR “Language Development Disorders” OR “Language Delay” OR “Language Development” OR “Language; Developmental Disorder, Expressive” OR “Language Disorder” OR “Language Disorders” OR “Language Impairment” OR “Specific Language Impairment” OR “Speech and Language Disorder” OR “Speech Articulation Disorder” OR “Speech Disorders” OR “Speech Disorders in Children” OR “Speech Sound Disorder” OR “Speech Sound Disorders” OR dysarthria OR "developmental language disorder" OR DLD OR "language development disorder" OR "language impairment" OR receptive AND expressive AND delay OR ( speech* OR language* ) AND ( disorder* OR delay* OR patholog* ) OR "speech impairment"

##### Intervention box

("Diagnostic Techniques and Procedures" OR "Language Tests" OR "Psychological Tests" OR instrument* OR inventory OR questionnaire* OR scale OR screening OR "Area Under Curve" OR "differential diagnosis" OR "Diagnostic Techniques and Procedures" OR "Likelihood Functions" OR "Predictive Value of Tests" OR accuracy OR "false positive" OR "false negative" OR "likelihood ratio" OR "predictive value" OR reproducib* OR ROC OR sensitivity OR specificity) NOT ( pharmacotherap* OR Drug* OR medicin* OR surg* OR Placebo OR autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")

Selected Recruitment: ALL

Selected box to Search for clinical trials in children

Limited to dates: January 1, 2014 to January 18, 2023

Interventions Search: 63 results, 60 imported to EndNote

##### Condition box

“Developmental Language Disorder” OR “Developmental Language Disorders” OR “Developmental Language Disorder and Language Impairment” OR Dysarthria OR “Language Development Disorders” OR “Language Delay” OR “Language Development” OR “Language; Developmental Disorder, Expressive” OR “Language Disorder” OR “Language Disorders” OR “Language Impairment” OR “Specific Language Impairment” OR “Speech and Language Disorder” OR “Speech Articulation Disorder” OR “Speech Disorders” OR “Speech Disorders in Children” OR “Speech Sound Disorder” OR “Speech Sound Disorders” OR dysarthria OR "developmental language disorder" OR DLD OR "language development disorder" OR "language impairment" OR receptive AND expressive AND delay OR ( speech* OR language* ) AND ( disorder* OR delay* OR patholog* ) OR "speech impairment"

##### Intervention box

(Bilingualism OR "Communication Aids for Disabled" OR "Comparative Study" OR "Early Medical Intervention" OR "Evaluation Study" OR "Epidemiologic Study" OR Gestures OR “family workshop” OR “Intensive Language Action Therapy” OR intervention* OR "language facilitation" OR “Language Therapy” OR Multilingualism OR "Outcome and Process Assessment" OR “Parent implemented intervention” OR “Rehabilitation of Speech and Language Disorders” OR “Speech and Language Therapy” OR “Speech Therapy” OR "Therapy, Computer-Assisted" OR therapeutics OR treatment*) NOT (pharmacotherap* OR Drug* OR medicin* OR surg* Placebo OR autism OR "down syndrome" OR "fragile syndrome" OR craniofacial OR "cleft palate")

Selected Recruitment: ALL

Selected box to Search for clinical trials in children

Limited to dates: January 1, 2014 to January 18, 2023

## Appendix B2 Eligibility Criteria

Category | Include | Exclude
Population | KQs 1–3: Unselected or explicitly asymptomatic children age 5 years or younger who communicate using any language; KQs 4–6: Children who were diagnosed with a speech and language delay or disorder at age 6 years or younger^*^; All KQs: A priori specific populations of interest include those defined by age, sex, cultural/linguistic background, and native language | Studies limited to children who were preterm infants (under 36 weeks of gestation) or with known conditions associated with speech and language delay or disorder, such as selective mutism, hearing impairment, developmental disorders (e.g., Down syndrome, fragile X syndrome, and autism), craniofacial anomalies, or neurological/neurogenetic disorders
Setting | KQs 1–3: Primary care settings and primary care–referable settings, childcare, schools, and other education settings; KQs 4–6: Clinical, educational, early intervention, and home settings | All other settings
Screening | All validated tools and procedures applicable for use in primary care–relevant settings, designed to identify a speech and/or language delay or impairment, that meet the following criteria:; 10 minutes or less to administer or to be interpreted in a primary care setting; 10 minutes or more if completed by a parent or teacher and interpreted by the clinician; Tools specifically for speech and/or language and general developmental instruments with a separate component for speech and/or language skills are eligible | Instruments not designed for use in children age 5 years or younger, tools that take more than 10 minutes to administer or that are not feasible to administer in primary care settings; General developmental screening instruments that do not include a separate component for speech and language skills
Treatment/Interventions | Any interventions designed to improve speech and/or language in children delivered at any age, as long as diagnosis occurs when child is age 6 years or younger; interventions may be delivered in various formats (e.g., individual or group settings, face-to-face, or via telehealth); therapists may be speech-language pathologists or other clinicians, parents, or teachers | Interventions delivered to children diagnosed after age 6 years
Comparisons | KQs 1, 3: Screened vs. unscreened populations; KQs 2, 3: Screening tools vs. reference standard (diagnostic evaluation by qualified clinical professional); KQs 4–6: Intervention vs. no intervention (or usual care) | KQs 1, 3: No comparator; KQ 2: Another screening tool; KQs 4–6: No comparator, studies comparing two active interventions (i.e., comparative effectiveness)
Outcomes | KQs 1, 4: Speech and language outcomes, including speech domains (e.g., stuttering, fluency, articulation) and language domains (e.g., expressive language, receptive language, phonology, vocabulary, syntax, pragmatics); KQs 1, 5: Measures of academic skills or achievement (e.g., reading comprehension), behavior competence, socioemotional functioning, and quality of life; KQ 2: Measures of screening test accuracy (e.g., sensitivity, specificity, positive and negative predictive value, likelihood ratios, area under the curve); KQ 3: Harms of screening, including labeling, stigma, parent anxiety, and other psychosocial harms; KQ 6: Harms of interventions, including overdiagnosis, labeling, stigma, and others | All other outcomes
Study Designs | KQs 1, 3, 6: Controlled cohort studies; RCTs; nonrandomized, controlled trials; KQ 2: Cross-sectional or cohort studies; KQs 4, 5: RCTs | All KQs: Case-control studies, case reports, case series, or systematic reviews
Country | Studies conducted in countries categorized as “Very High” on the Human Development Index, as defined by the United Nations Development Programme | Studies conducted in countries not categorized as “Very High” on the Human Development Index
Quality Rating | Studies rated fair or good quality | Studies rated poor quality
Language of Published Study | English | Non-English

* Age criteria for studies of treatment include children up to age 6 years given that children who would be screened at age 5 years and referred for treatment may not receive services immediately.

Abbreviations: KQ=key question; RCT=randomized, controlled trial.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

### Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies will be graded “fair” if any or all of the following problems occur without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.

Poor: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies Criteria

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

### Definition of Ratings Based on Above Criteria:

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad spectrum patients with and without disease.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Has a fatal flaw, such as uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^33, 82^