# Appendix A Contextual Questions

## Contextual Questions

### CQ 1. Are There Disparities in the Prevalence of Speech and Language Delay or Disorders Among Specific Populations of Children? If So, What Factors Contribute to These Disparities?

Three studies addressed Contextual Question (CQ) 1 by describing disparities in the prevalence of speech and language delay or disorders based on groups defined by sex, race/ethnicity, and other social and economic factors (Appendix A Table 1). The studies were published across two decades (2002–2022). One study recruited from a single city^78^ and two studies used nationally representative data.^21, 79^ Study sample size ranged from 278 to 2,070,541 participants.^21, 78, 79^ Demographic data was available for two of the studies.^21, 79^ The studies generally enrolled an equal number of boys and girls. One study presented data on race/ethnicity. The majority of the children enrolled in the study were identified as non-Hispanic White, 22 percent were identified as African American, 13 percent as Hispanic, and 9 percent as other.^79^ For indicators of socioeconomic status, one study used a publicly and privately insured cohort of children (Medicaid Analytic eXtract (MAX) and IBM MarketScan Research Database, respectively).^21^ An additional study enrolled a sample in which 18 percent of the sample were categorized as having a low socioeconomic status (SES), 45 percent as middle SES, and 31 percent as upper SES.^79^

Disparities in the prevalence of speech and language delay were found based on child SES,^21, 78, 79^ sex/gender,^21, 78^ family history,^78^ maternal education,^78^ and child race/ethnicity.^79^ Using data on publicly and privately insured children, a higher prevalence of speech and/or language delay was observed among children who had public insurance: 8.4 percent vs. 4.5 percent.^21^ A similar finding was observed in the study by Campbell et al, where a higher prevalence of speech delay was associated with enrollment in Medicaid.^78^ Rescorla et al, using SES, found that as the level of SES increased, the prevalence of speech delay was lower, ranging from 21 percent for the lowest level of SES to 6 percent at the highest level.79 Disparities in prevalence of speech and/or language delay was seen by gender. In the study by Straub et al, male children had a higher prevalence of speech and/or language delay compared with female children in the MAX and MarketScan datasets (66.47% vs. 32.01% and 69.68% vs. 27.68%, respectively). Campbell et al also found that among children with speech delay, males represented 70 percent of the children compared with 48 percent in the cohort of children without speech delay.^78^ One study found an increased prevalence of speech and language delay among children identified as African American compared with children who identify as non-Hispanic White (29% vs. 4%, respectively).^79^ One study found a higher prevalence of speech delay among children who had a positive family history of developmental communication disorder and low maternal educational level.^78^

### CQ 2. Are There Disparities in the Detection of Speech and Language Delay or Disorders in Clinical Practice and Referral for Diagnostic Evaluation Among Specific Populations of Children? If So, What Factors Contribute to These Disparities?

One study addressed CQ 2 (Appendix A Table 2). Straub et al, using data from public and private insurance databases (MAX and MarketScan, respectively), found a statistically significant difference in the age of detection of language and/or speech delay by insurance type: MAX mean age 4.96 (95% confidence interval [CI], 4.91 to 5.01) compared with MarketScan mean age 3.53 (95% CI, 3.42 to 3.65).^21^ Disparities in the age of detection was observed in both the MAX and MarketScan datasets, where boys were diagnosed at a younger age compared with girls. (Absolute difference was 0.25 years and 0.34 years, respectively.) Disparities in the age of diagnosis was observed based on a child’s race/ethnicity in the MAX dataset. Relative to the children identified as White (reference group), statistically significant differences in the age of diagnosis were found among children who identified as Asian/Pacific Islander (absolute difference -1.67 (-1.95 to -1.39), Hispanic (absolute difference -0.71 (-0.88 to -0.55), and Other/Unknown (absolute difference -1.03 (-1.21 to -0.84). No statistically significant difference in age of diagnosis was observed among individuals identifying as Black. An additional disparity observed was based on maternal age. Relative to mothers who were age 24 years or younger, the only statistically significant difference in child age of diagnosis was seen for mothers who were age 35 years or older (absolute difference -0.48 (-0.68 to -0.28) in the MAX dataset.

### CQ 3. Are There Disparities in the Provision and Utilization of Treatment for Speech and Language Delay or Disorders Among Specific Populations of Children? If So, What Factors Contribute to These Disparities?

Two studies addressed CQ 3 using data from different population cohort studies (Appendix A Table 3). One used data from the Early Childhood Longitudinal Study–Birth Cohort to assess the association of speech services at 24, 48, and 60 months.^80^ The sample was racially and ethnically diverse with approximately 50 percent of children identifying as White. Males represented half of the sample. SES was evenly distributed across the five quintiles (lowest to highest). At 24 months, children who identified as Black (OR 0.43), children from the lowest SES, middle or second highest SES (OR 0.42, 0.45, and 0.52, respectively), and having a mother who was socially isolated (OR 0.56) had statistically significant decreased odds of reporting speech/language therapy at 24 months. At 48 months, a child identified as Black (OR 0.50) or Other race (OR 0.47), a single mother (OR 0.43), and having a primary language other than English had (OR 0.40) a statistically significant decreased odds of parental report of speech/language therapy. When examined at 60 months, statistically significant odds remained for children identified as Black (OR 0.59), having a lower SES, or having a non-English primary language.

The second study used data from the 2012 National Health Interview Survey (N=824) to assess children’s access to services for speech and language disorders during their lifetimes, including differences by race/ethnicity and insurance type.^81^ The sample included children ranging from ages 3 years to 17 years and 11 months, and grouped children into categories based on whether they had a speech or language disorder. Most children included in the study were younger than age 10 years and were male (approximately 33% were female). In both the speech disorder and language disorder categories, approximately 50 percent of children identified as Non-Hispanic White, and the proportion who identified as non-Hispanic Black and Hispanic in each category were similar, ranging from 16 to 27 percent. Most children had public insurance only or any private insurance, and 4 percent of children were uninsured. Overall, 75 percent of children had ever received services for their speech or language disorder. Privately insured children were more likely to receive services than children who were uninsured, both for speech disorders (47% vs. 84%; p<0.001) and for language disorders (40% vs. 83%; p=0.006). Children who were White and Other, non-Hispanic more frequently received services for both speech disorders (83% and 94%, respectively) and language disorders (81% and 77%, respectively) than children who were Black, non-Hispanic or Hispanic for speech (approximately 64% for both; p<0.001) and language disorders (70% and 61%, respectively; p=0.029).

Appendix A Table 1 CQ 1 Study Characteristics and Outcomes

First Author, Year | N | Demographics | Source | Outcome
Campbell, 2003^78^ | 639 | Randomized trial participants:; Sex: 57.3% male; 42.7% female; Insurance: 65.1% Medicaid; 34.9% private; Race/ethnicity: 38.5% African American; 61.5% White; Non-trial participants:; Sex: 49.8% male; 50.2% female; Insurance: 32.5% Medicaid; 67.5% private; Race/ethnicity: 16.4% African American; 83.6% White | Participants in trial set in Pittsburgh, PA | Prevalence of speech delay (delay % vs. no delay); Low maternal education: 22% vs. 10%; Male sex: 70% vs. 52%; Positive family history: 36% vs. 25%; Medicaid: 63% vs. 51%
Rescorla, 2002^79^ | 278 | Sex: 51% female; Race/ethnicity: 57% NHW; 22% African American; 13% Hispanic; 9% Other; Age of child:; 18 to 23 months: 101; 24 to 29 months: 90; 30 to 35 months:87; Lower SES: 18%; Middle SES: 45%; Upper SES: 31% | 1999 National Survey of Children, Youths, and Adults | Prevalence of speech delay among children ages 24 to 35 months; Lower SES: 21%; Middle SES: 14%; Upper SES: 6%; 4% NHW; 29% African American; 24% Other
Straub, 2022^21^ | 2,070,541 total:; 1,045,426 (MAX dataset);; 1,309,900 privately insured children (MarketScan dataset) | 50.5% boys in publicly insured cohort; 51% boys in privately insured cohort | 2000–2014 MAX and 2003–2015 IBM MarketScan Research Database | Prevalence of speech and/or language delay; (MAX vs MarketScan):; 8.4% vs. 4.5%; Disparities in prevalence by child sex (male vs. female); MAX:; 66.47% vs. 32.01%; MarketScan:; 69.68% vs. 27.68%

Abbreviations: MAX=Medicaid Analytic eXtract; NHW=non-Hispanic White; SES=socioeconomic status.

Appendix A Table 2 CQ 2 Study Characteristics and Outcomes

First Author, Year | N | Demographics | Source | Outcome
Straub, 2022^21^ | 1,045,426 publicly insured children;; 1,309,900 privately insured children | 51% boys in publicly insured cohort; 51% boys in privately insured cohort | MAX and MarketScan data | Age at diagnosis of speech and/or language delays (MAX vs. MarketScan); 4.96 (4.91 to 5.01) vs. 3.53 (3.42 to 3.65); Disparities in detection by child sex (boys vs. girls [reference]); MAX; Absolute difference: −0.25 (−0.36 to −0.14); 4.88 (4.81 to 4.95) vs. 5.12 (5.04 to 5.21); MarketScan; Absolute difference: −0.34 (−0.57 to −0.11); 3.41 (3.29 to 3.54) vs. 3.75 (2.85 to 3.60); Disparities in age of detection by child race/ethnicity in MAX (White is reference); Asian/Pacific Islander: absolute difference: −1.67 (−1.95 to −1.39) 3.49 (3.22 to 3.76); Black: absolute difference: 0.00 (−0.12 to – 0.13) 5.16 (5.06 to 5.26); Hispanic/Latino: absolute difference: −0.71 (−0.88 to −0.55) 4.44 (4.30 to 4.59); Other/Unknown: absolute difference: −1.03 _−1.21 to −0.84) 4.13 (3.96 to 4.30); White: absolute difference: ref 5.16 (5.08 to 5.23); Disparities in age of detection by maternal age (maternal age 24 years or younger is reference); MAX; Maternal age 35 years or older: absolute difference: −0.48 (−0.68 to −0.28) 4.54 (4.35 to 4.73); Maternal age 25 to 34 years: absolute difference: −0.07 (−0.18 to 0.05) 4.95 (4.86 to 5.05); Maternal age 24 years or younger: 5.02 (4.96 to 5.09); MarketScan; Maternal age 35 years or older: absolute difference: 0.04 (−0.40 to 0.48) 3.40 (3.28 to 3.51); Maternal age 25 to 34 years: 3.62 (3.45) absolute difference: 0.26 (−0.19 to 0.72); Maternal age 24 years or younger: absolute difference: 3.35 (2.93 to 3.78)

Abbreviations: MAX=Medicaid Analytic eXtract.

Appendix A Table 3 CQ 3 Study Characteristics and Outcomes

First Author, Year | N | Demographics | Source | Outcome
Morgan, 2016^80^ | 9,500 (weighted) | Race/ethnicity: White: 53.1%; African American: 13.8%; Hispanic: 25.6%; Other: 7.3%; Sex: 51.3% male; SES quintile at 24 months:; Lowest: 20.1%,; Second lowest: 20.1%; Middle: 20.1%; Second highest: 20.0%; Highest: 19.8% | Early Childhood Longitudinal Study, Birth Cohort | Receipt of services at ages 24, 48, and 60 months; At age 24 months:; Low total word score aOR (16.51 to 17.85); African American children (reference White children) aOR range (0.42 to 0.55); middle SES quintile aOR range (0.45 to 0.54); family member with mental illness aOR range (2.14 to 2.15); family member with learning disability aOR (2.16 to 2.18); Socially isolated mother aOR (0.56); At age 48 months:; Low total word score at 24 months aOR (9.12 to 11.74); low receptive vocabulary at 48 months aOR range (2.13 to 2.37); African American children (reference White) aOR (0.48 to 0.54); male aOR range (1.65 to 1.74); non-English primary language at 24 months aOR (0.40 to 0.43); maternal behavioral risk factor at birth aOR (1.65 to 2.02); family with learning disability at 24 months aOR (1.73 to 1.74); household person with special needs at 9 months aOR (1.81 to 1.84); child behaviors—externalizing problems at 24 months aOR (1.86); At age 60 months:; Low total word score at 24 months aOR (4.32 to 6.10); low receptive vocabulary score at 48 months aOR (2.10 to 2.37); maternal depression at 9 months aOR (1.58 to 1.65); child behaviors—externalizing problems at 24 months aOR (2.26)
Davidson, 2022^81^ | 824 total; 491 with speech disorders and 333 with language disorders | Age range: 3.0 to 17.11 (years, months); % by age range (years), speech disorder sample:; 3–6: 46; 7–10: 34; 11–17: 20; % by age range (years), language disorder sample:; 3–6: 33; 7–10: 40; 11–17: 27; Sex (% female):; Speech disorder sample: 32; Language disorder sample: 33; % Race/ethnicity:; Speech disorder sample: White, non-Hispanic: 54; Black, non-Hispanic:19; Other, non-Hispanic: 6; Hispanic: 21; Language disorder sample: White, non-Hispanic: 51; Black, non-Hispanic:16; Other, non-Hispanic: 6; Hispanic: 27; Health insurance type:; Speech disorder sample: Uninsured: 4; Public only: 49; Any private: 47; Language disorder sample: Uninsured: 4; Public only: 58; Any private: 38 | 2012 National Health Interview Survey | Proportion of all children who had ever received services for speech and language disorders:; Total (overall, both samples): 75%; Proportion by race/ethnicity:; Speech disorder sample (%):; White, non-Hispanic: 83; Black, non-Hispanic: 64; Other, non-Hispanic: 94; Hispanic: 64; Language disorder sample (%):; White, non-Hispanic: 81; Black, non-Hispanic: 70; Other, non-Hispanic: 77; Hispanic: 61; Proportion by health insurance type:; Speech disorder sample (%):; Uninsured: 47; Public only: 70; Any private: 84; Language disorder sample (%):; Uninsured: 40; Public only: 71; Any private: 83

Abbreviations: aOR=adjusted odds ratio; SES=socioeconomic status.