# References

1 U.S. Preventive Services Task Force. Counseling to Prevent Dental and Periodontal Disease. In: Guide to Clinical Preventive Services: Report of the U.S. Preventive Services Task Force. 2nd ed., Baltimore: Williams & Wilkins; 1996: Chapter 61.
2 U. S. Preventive Services Task Force. Screening and Interventions to Prevent Dental Caries in Children Younger Than 5 Years: U.S. Preventive Services Task Force Recommendation Statement. JAMA. 2021;326(21):2172–8. doi: 10.1001/jama.2021.20007.34874412
3 Final Recommendation Statement Oral Cancer: Screening. U.S. Preventive Services Task Force. 2013. https://www.uspreventiveservicestaskforce.org/uspstf/recommendation/oral-cancer-screening. Accessed Oct 30, 2020.
4 Atchison KA, Rozier RG, Weintraub JA. Integration of Oral Health and Primary Care: Communication, Coordination and Referral. National Academy of Medicine; 2018. https://nam.edu/integration-of-oral-health-and-primary-care-communication-coordination-and-referral/. Accessed Jul 8 2022.
5 Hummel J, Phillips KE, Holt B, Oral health: an essential component of primary care. Seattle, WA: Qualis Health. 2015:9–12. https://www.safetynetmedicalhome.org/sites/default/files/White-Paper-Oral-Health-Primary-Care.pdf. Accessed Aug 26, 2023.
6 Primary Care Collaborative. Innovations in oral health and primary care integration: Alignment with the shared principles of primary care. 2021. https://www.pcpcc.org/sites/default/files/resources/PCC_Oral_Health_Primary_Care_Integration.pdf. Accessed Aug 26, 2023.
7 National Institutes of Health. Oral health in America: advances and challenges. U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research: Bethesda, MD, USA. 2021. https://www.nidcr.nih.gov/sites/default/files/2021-12/Oral-Health-in-America-Advances-and-Challenges.pdf Accessed Aug 26, 2023.
8 Chou R, Pappas M, Dana T, Screening and Interventions to Prevent Dental Caries in Children Younger Than Age Five Years: A Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 210. AHRQ Publication No. 21–05279-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2021 Agency for Healthcare Research and Quality (US). 2021.
9 Olson CM, Burda BU, Beil T, Screening for Oral Cancer: A Targeted Evidence Update for the U.S. Preventive Services Task Force. Evidence Synthesis No. 102. AHRQ Publication No. 13–05186-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; April 2013. https://www.ncbi.nlm.nih.gov/books/NBK132472/pdf/Bookshelf_NBK132472.pdf. Apr Services Task Force PMID: 2361701423617014.
10 U.S. Preventive Services Task Force. Final Research Plan - Oral Health: Screening, Referral, Behavioral Counseling, and Preventive Interventions. 2021. https://www.uspreventiveservicestaskforce.org/uspstf/document/final-research-plan/oral-health-screening-referral-behavioral-counseling-preventive-interventions. Accessed Jul 8 2022.
11 U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. Rockville, MD: US Department of Health and Human Services; 2000. https://www.nidcr.nih.gov/sites/default/files/2017-10/hck1ocv.%40www.surgeon.fullrpt.pdf. Accessed Aug 26, 2023.
12 Peres MA, Macpherson LM D, Weyant RJ, Oral diseases: a global public health challenge. Lancet. 2019 Jul 20;394(10194):249–60. doi: 10.1016/S0140-6736(19)31146-8. PMID: 31327369.31327369
13 Oral Health Conditions. Centers for Disease Control and Prevention. https://www.cdc.gov/oralhealth/conditions/index.html. Accessed Oct 30, 2020.
14 U. S. Preventive Services Task Force. Interventions for Tobacco Smoking Cessation in Adults, Including Pregnant Persons: U.S. Preventive Services Task Force Recommendation Statement. JAMA. 2021;325(3):265–79. doi: 10.1001/jama.2020.25019.33464343
15 U. S. Preventive Services Task Force. Screening and Behavioral Counseling Interventions to Reduce Unhealthy Alcohol Use in Adolescents and Adults: U.S. Preventive Services Task Force Recommendation Statement. JAMA. 2018;320(18):1899–909. doi: 10.1001/jama.2018.16789.30422199
16 U. S. Preventive Services Task Force. Behavioral Counseling Interventions to Promote a Healthy Diet and Physical Activity for Cardiovascular Disease Prevention in Adults With Cardiovascular Risk Factors: U.S. Preventive Services Task Force Recommendation Statement. JAMA. 2020;324(20):2069–75. doi: 10.1001/jama.2020.21749.33231670
17 Basics of Oral Health. Centers for Disease Control and Prevention. https://www.cdc.gov/oralhealth/basics/index.html. Accessed Oct 30 2020.
18 Dye BA. The Global Burden of Oral Disease: Research and Public Health Significance. J Dent Res. 2017 Apr;96(4):361–3. doi: 10.1177/0022034517693567. PMID: 28318392.28318392
19 Naavaal S, Griffin SO, Jones JA. Impact of Making Dental Care Affordable on Quality of Life in Adults Aged 45 Years and Older. J Aging Health. 2020 Aug-Sep;32(7–8):861–70. doi: 10.1177/0898264319857967. PMID: 31258028.31258028
20 Alpert PT. Oral Health: The Oral-Systemic Health Connection. Home Health Care Manag Pract. 2017;29(1):56–9. doi: 10.1177/1084822316651658.
21 Centers for Disease Control and Prevention. Oral Health Surveillance Report: Trends in Dental Caries and Sealants, Tooth Retention, and Edentulism, United States, 1999–2004 to 2011–2016. Atlanta, GA: Centers for Disease Control and Prevention, U.S. Department of Health and Human Services; 2019. https://www.cdc.gov/oralhealth/publications/OHSR-2019-index.html. Accessed Aug 26 2023.
22 GBD 2017 Disease and Injury Incidence and Prevalence Collaborators. Global, regional, and national incidence, prevalence, and years lived with disability for 354 diseases and injuries for 195 countries and territories, 1990–2017: a systematic analysis for the Global Burden of Disease Study 2017. Lancet. 2018;392(10159):1789–858. doi: 10.1016/S0140-6736(18)32279-7. PMID: 30496104.30496104
23 National Center for Health Statistics. Health, United States, 2019. Table 28. Untreated dental caries, by selected characteristics: United States, selected years 1988–1994 through 2015–2018. Hyattsville, MD; 2021. https://www.cdc.gov/nchs/data/hus/2019/028-508.pdf. Accessed Aug 26 2023.
24 Eke PI, Dye BA, Wei L, Prevalence of periodontitis in adults in the United States: 2009 and 2010. J Dent Res. 2012 Oct;91(10):914–20. doi: 10.1177/0022034512457373. PMID: 22935673.22935673
25 Dye BA, Thornton-Evans G, Li X, Dental caries and tooth loss in adults in the United States, 2011–2012. NCHS data brief, no 197. Hyattsville, MD: National Center for Health Statistics. 2015. https://www.cdc.gov/nchs/data/databriefs/db197.pdf.Accessed Aug 26 2023.
26 Teeuw WJ, Gerdes VE, Loos BG. Effect of periodontal treatment on glycemic control of diabetic patients: a systematic review and meta-analysis. Diabetes Care. 2010;33(2):421–7. doi: 10.2337/dc09-1378. PMID: 20103557.20103557
27 Kuo LC, Polson AM, Kang T. Associations between periodontal diseases and systemic diseases: a review of the inter-relationships and interactions with diabetes, respiratory diseases, cardiovascular diseases and osteoporosis. Public Health. 2008;122(4):417–33. doi: 10.1016/j.puhe.2007.07.004. PMID: 18028967.18028967
28 Garton BJ, Ford PJ. Root caries and diabetes: risk assessing to improve oral and systemic health outcomes. Aust Dent J. 2012;57(2):114–22. doi: 10.1111/j.1834-7819.2012.01690.x. PMID: 22624749.22624749
29 Bader JD, Rozier RG, Lohr KN, Physicians' roles in preventing dental caries in preschool children: A summary of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2004;26(4):315–25. doi: 10.1016/j.amepre.2003.12.001. PMID: 15110059.15110059
30 Caufield PW, Griffen AL. Dental caries. An infectious and transmissible disease. Pediatr Clin North Am. 2000;47(5):1001–19, v. PMID: 11059347.11059347
31 Centers for Disease Control and Prevention. Recommendations for using fluoride to prevent and control dental caries in the United States. MMWR Recomm Rep. 2001;50(RR-14):1–42. PMID: 11521913.11521913
32 Centers for Disease Control and Prevention. Periodontal Disease. https://www.cdc.gov/oralhealth/conditions/periodontal-disease.html. Accessed October 30, 2020.
33 U.S. National Library of Medicine. Periodontitis. https://medlineplus.gov/ency/article/001059.htm. Accessed Oct 30 2020.
34 Leite FR M, Nascimento GG, Scheutz F, Effect of Smoking on Periodontitis: A Systematic Review and Meta-regression. Am J Prev Med. 2018;54(6):831–41. doi: 10.1016/j.amepre.2018.02.014. PMID: 29656920.29656920
35 Leite RS, Marlow NM, Fernandes JK, Oral health and type 2 diabetes. Am J Med Sci. 2013;345(4):271–3. doi: 10.1097/MAJ.0b013e31828bdedf. PMID: 23531957.23531957
36 Ciancio SG. Medications' impact on oral health. J Am Dent Assoc. 2004;135(10):1440–8; doi: 10.14219/jada.archive.2004.0055. PMID: 15551986.15551986
37 Thomson WM, Lawrence HP, Broadbent JM, The impact of xerostomia on oral-health-related quality of life among younger adults. Health Qual Life Outcomes. 2006;4:86. doi: 10.1186/1477–7525-4–86. PMID: 17090332.17090332
38 Ship JA. Diabetes and oral health: an overview. J Am Dent Assoc. 2003;134 Spec No:4S-10S. doi: 10.14219/jada.archive.2003.0367. PMID: 18196667.18196667
39 Vujicic M, Nasseh K. A decade in dental care utilization among adults and children (2001–2010). Health Serv Res. 2014;49(2):460–80. doi: 10.1111/1475–6773.12130. PMID: 24299620.24299620
40 Griffin SO, Thornton-Evans G, Wei L, Disparities in Dental Use and Untreated Caries Prevalence by Income. JDR Clin Trans Res. 2021;6(2):234–41. doi: 10.1177/2380084420934746. PMID: 32585114.32585114
41 Gupta N, Vujicic M, Yarbrough C, Disparities in untreated caries among children and adults in the U.S., 2011–2014. BMC Oral Health. 2018;18(1):30. doi: 10.1186/s12903–018-0493–7.29510696
42 Vujicic M, Buchmueller T, Klein R. Dental Care Presents The Highest Level Of Financial Barriers, Compared To Other Types Of Health Care Services. Health Aff (Millwood). 2016;35(12):2176–82. doi: 10.1377/hlthaff.2016.0800. PMID: 27920304.27920304
43 Vujicic M. Health care reform brings new opportunities. J Am Dent Assoc. 2014;145(4):381–2. doi: 10.14219/jada.2014.16. PMID: 24686974.24686974
44 Hummel J, Phillips KE, Holt B, Oral Health: An Essential Component of Primary Care. Seattle, WA: Qualis Health; June 2015. http://www.safetynetmedicalhome.org/sites/default/files/White-Paper-Oral-Health-Primary-Care.pdf. Accessed Aug 26 2023.
45 Blackwell DL, Lucas JW, Clarke TC. Summary health statistics for U.S. adults: national health interview survey, 2012. Vital Health Stat 10. 2014;(260):1–161. PMID: 24819891.24819891
46 U.S. Food & Drug Administration. The Selection of Patients for Dental Radiographic Examinations. 2012. https://www.fda.gov/radiation-emitting-products/medical-x-ray-imaging/selection-patients-dental-radiographic-examinations. Accessed Nov 20 2020.
47 Tinanoff N, Reisine S. Update on early childhood caries since the Surgeon General's Report. Acad Pediatr. 2009;9(6):396–403. doi: 10.1016/j.acap.2009.08.006. PMID: 19945074.19945074
48 Levy SM, Broffitt B, Marshall TA, Associations between fluorosis of permanent incisors and fluoride intake from infant formula, other dietary sources and dentifrice during early childhood. J Am Dent Assoc. 2010;141(10):1190–201. PMID: 20884921.20884921
49 Ismail AI, Bandekar RR. Fluoride supplements and fluorosis: a meta-analysis. Community Dent Oral Epidemiol. 1999;27(1):48–56. doi: 10.1111/j.1600–0528.1999.tb01991.x. PMID: 10086926.10086926
50 Beltran-Aguilar ED, Barker L, Dye BA. Prevalence and severity of dental fluorosis in the United States, 1999–2004. NCHS Data Brief. 2010;(53):1–8. PMID: 21211168.21211168
51 Neurath C, Limeback H, Osmunson B, Dental Fluorosis Trends in US Oral Health Surveys: 1986 to 2012. JDR Clin Trans Res. 2019;4(4):298–308. doi: 10.1177/2380084419830957. PMID: 30931722.30931722
52 American Dental Association Council on Scientific Affairs. Professionally applied topical fluoride: evidence-based clinical recommendations. J Am Dent Assoc. 2006;137(8):1151–9. doi: 10.14219/jada.archive.2006.0356. PMID: 16873333.16873333
53 Ekstrand J, Koch G, Lindgren LE, Pharmacokinetics of fluoride gels in children and adults. Caries Res. 1981;15(3):213–20. doi: 10.1159/000260517. PMID: 6938306.6938306
54 Ekstrand J, Koch G, Petersson LG. Plasma fluoride concentration and urinary fluoride excretion in children following application of the fluoride-containing varnish Duraphat. Caries Res. 1980;14(4):185–9. doi: 10.1159/000260452. PMID: 6929729.6929729
55 Garcia RI, Gregorich SE, Ramos-Gomez F, Absence of Fluoride Varnish-Related Adverse Events in Caries Prevention Trials in Young Children, United States. Prev Chronic Dis. 2017;14:E17. doi: 10.5888/pcd14.160372. PMID: 28207379.28207379
56 Crystal YO, Marghalani AA, Ureles SD, Use of silver diamine fluoride for dental caries management in children and adolescents, including those with special health care needs. Pediatr Dent. 2017;39(5):135–45. PMID: 29070149.29070149
57 Horst JA, Ellenikiotis H, Milgrom PL. UCSF protocol for caries arrest using silver diamine fluoride: rationale, indications and consent. J Calif Dent Assoc. 2016;44(1):16–28. PMID: 26897901.26897901
58 Gao SS, Zhao IS, Hiraishi N, Clinical trials of silver diamine fluoride in arresting caries among children: a systematic review. JDR Clin Trans Res. 2016;1(3):201–10. doi: 10.1177/2380084416661474. PMID: 30931743.30931743
59 Ruff RR, Niederman R. Comparative effectiveness of treatments to prevent dental caries given to rural children in school-based settings: Protocol for a cluster randomised controlled trial. BMJ Open. 2018;8(4):e022646. doi: 10.1136/bmjopen-2018–022646. PMID: 29654053.29654053
60 American Academy of Pediatric Dentistry. Guideline on xylitol use in caries prevention. American Academy of Pediatric Dentistry Reference Manual. 2012/2013;34(6):166–9.
61 § 101.80 Health claims: dietary noncariogenic carbohydrate sweeteners and dental caries. https://ecfr.federalregister.gov/current/title-21/chapter-I/subchapter-B/part-101/subpart-E/section-101.80. Accessed Oct 15 2020.
62 Naaman R, El-Housseiny AA, Alamoudi N. The Use of Pit and Fissure Sealants-A Literature Review. Dent J (Basel). 2017;5(4)doi: 10.3390/dj5040034. PMID: 29563440.29563440
63 Community Preventive Services Task Force. Preventing Dental Caries: School-based Dental Sealant Delivery Programs. Atlanta, GA: U.S. Department of Health and Human Services, Community Preventive Services Task Force; 2013. https://www.thecommunityguide.org/findings/dental-caries-cavities-school-based-dental-sealant-delivery-programs.html. Accessed Nov 20 2020.
64 Miloro MB, Vujicic M. Physicians dissatisfied with current referral process to dentists. American Dental Association. 2016. https://www.ada.org/-/media/project/ada-organization/ada/ada-org/files/resources/research/hpi/hpibrief_0316_5.pdf. Accessed Aug 26 2023.
65 Sudhanthar S, Lapinski J, Turner J, Improving oral health through dental fluoride varnish application in a primary care paediatric practice. BMJ Open Quality. 2019;8(2):e000589. doi: 10.1136/bmjoq-2018–000589. PMID: 31259286.31259286
66 Kram J, Baumgardner D, de Grandville C, Evaluation of fluoride varnish implementation for well child visits in a family practice residency clinic. Ann Fam Med. 2022;20(Supplement 1):2644. doi: 10.1370/afm.20.s1.2644.
67 Institute of Medicine. Advancing Oral Health in America. Washington, DC: The National Academies Press; 2011. https://nap.nationalacademies.org/catalog/13086/advancing-oral-health-in-america. Accessed Aug 26 2023.
68 Institute of Medicine and National Research Council. 2011. Improving access to oral health care for vulnerable and underserved populations. Washington, DC: The National Academies Press. https://www.hrsa.gov/sites/default/files/publichealth/clinical/oralhealth/improvingaccess.pdf. Accessed Aug 26 2023.
69 Health Resources and Services Administration. Integration of Oral Health and Primary Care Practice. 2014. https://oralhealth.hsdm.harvard.edu/sites/hwpi.harvard.edu/files/oralhealth/files/integrationoforalhealth.pdf?m=1498574751 Accessed Aug 26 2023.
70 Weyant RJ, Tracy SL, Anselmo TT, Topical fluoride for caries prevention: executive summary of the updated clinical recommendations and supporting systematic review. J Am Dent Assoc. 2013;144(11):1279–91. doi: 10.14219/jada.archive.2013.0057. PMID: 24177407.24177407
71 American Academy of Family Physicians. Oral Health. 2018. https://www.aafp.org/about/policies/all/oral-health.html. Accessed Jul 8 2022.
72 Oral health care during pregnancy and through the lifespan. Committee Opinion No. 569. American College of Obstetricians and Gynecologists. Obstet Gynecol. 2013;122:417–22. https://www.acog.org/clinical/clinical-guidance/committee-opinion/articles/2013/08/oral-health-care-during-pregnancy-and-through-the-lifespan. Accessed Aug 2023.23969828
73 Sievers K, Clark MB, Douglass AB, Smiles for Life: A National Oral Health Curriculum. 4th Edition. Society of Teachers of Family Medicine; 2020. www.smilesforlifeoralhealth.com. Accessed Nov 20 2020.
74 Griffin SO, Griffin PM, Li CH, Changes in Older Adults' Oral Health and Disparities: 1999 to 2004 and 2011 to 2016. J Am Geriatr Soc. 2019;67(6):1152–7. doi: 10.1111/jgs.15777 PMID: 30698819.30698819
75 Guo Y, Logan HL, Dodd VJ, Health literacy: a pathway to better oral health. Am J Public Health. 2014;104(7):e85–91. doi: 10.2105/ajph.2014.30193077. PMID: 24832423.24832423
76 Wilson FA, Wang Y, Borrell LN, Disparities in oral health by immigration status in the United States. J Am Dent Assoc. 2018;149(6):414–21. doi: 10.1016/j.adaj.2018.01.0247. PMID: 29615187.29615187
77 Centers for Disease Control and Prevention. Disparities in Oral Health. https://www.cdc.gov/oralhealth/oral_health_disparities/index.htm. Accessed Oct 30 2020.
78 Eke PI, Thornton-Evans GO, Wei L, Periodontitis in US Adults: National Health and Nutrition Examination Survey 2009–2014. J Am Dent Assoc. 2018 Jul;149(7):576–88.e6. doi: 10.1016/j.adaj.2018.04.023. PMID: 29957185.29957185
79 U. S. Preventive Services Task Force. Procedure Manual. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual. Accessed Aug 26 2023.
80 George A, Dahlen HG, Blinkhorn A, Evaluation of a midwifery initiated oral health-dental service program to improve oral health and birth outcomes for pregnant women: a multi-centre randomised controlled trial. Int J Nurs Stud. 2018;82:49–57. doi: 10.1016/j.ijnurstu.2018.03.0067. PMID: 29605753.29605753
81 George A, Dahlen HG, Blinkhorn A, Measuring oral health during pregnancy: sensitivity and specificity of a maternal oral screening (MOS) tool. BMC Pregnancy Childbirth. 2017;16(347)doi: 10.1186/s12884–016-1140–47. PMID: 27829388.27829388
82 Deng K, Pelekos G, Jin L, Diagnostic accuracy of self-reported measures of periodontal disease: A clinical validation study using the 2017 case definitions. J Clin Periodontol. 2021;48(8):1037–50. doi: 10.1111/jcpe.13484. PMID: 33998009.33998009
83 Dietrich T, Stosch U, Dietrich D, Prediction of periodontal disease from multiple self-reported items in a German practice-based sample. J Periodontol. 2007;78(7 Suppl):1421–8. doi: 10.1902/jop.2007.060212. PMID: 17608613.17608613
84 Nijland N, Overtoom F, Gerdes VE A, External validation of a rapid, non-invasive tool for periodontitis screening in a medical care setting. Clin Oral Investig. 2021;25(12):6661–9. doi: 10.1007/s00784–021-03952–2. PMID: 33978832.33978832
85 Sekundo C, Bolk T, Kalmus O, Accuracy of a 7-Item Patient-Reported Stand-Alone Tool for Periodontitis Screening. J Clin Med. 2021;10(2):14. doi: 10.3390/jcm10020287. PMID: 33466797.33466797
86 Verhulst MJ L, Teeuw WJ, Bizzarro S, A rapid, non-invasive tool for periodontitis screening in a medical care setting. BMC Oral Health. 2019;19(1):87. doi: 10.1186/s12903–019-0784–7. PMID: 31122214.31122214
87 Westman EC, Duffy MB, Simel DL. Should physicians screen for oral disease? A physical examination study of the oral cavity. J Gen Intern Med. 1994;9(10):558–62. doi: 10.1007/BF02599281. PMID: 7823227.7823227
88 Tan HP, Lo EC, Dyson JE, A randomized trial on root caries prevention in elders. J Dent Res. 2010;89(10):1086–90. doi: 10.1177/0022034510375825. PMID: 20671206.20671206
89 Eden GT. Clinical evaluation of a pit and fissure sealant for young adults. J Prosthet Dent. 1976;36(1):51–7. doi: 10.1016/0022–3913(76)90233-x. PMID: 1067415.1067415
90 Li R, Lo EC M, Liu BY, Randomized Clinical Trial on Preventing Root Caries among Community-Dwelling Elders. JDR Clin Trans Res. 2017;2(1):66–72. doi: 10.1177/2380084416668491. PMID: 30938645.30938645
91 Zhang W, McGrath C, Lo EC, Silver diamine fluoride and education to prevent and arrest root caries among community-dwelling elders. Caries Res. 2013;47(4):284–90. doi: 10.1159/000346620. PMID: 23392087.23392087
92 Carter WJ, Jay P, Shklair IL, The effect of topical fluoride on dental caries experience in adult females of a military population. J Dent Res. 1955;34(1):73–6. doi: 10.1177/00220345550340011801. PMID: 13233389.13233389
93 Jabir E, McGrade C, Quinn G, Evaluating the effectiveness of fluoride varnish in preventing caries amongst Long-Term Care Facility Residents. Gerodontology. 2021;39(3):250–6. doi: 10.1111/ger.12563. PMID: 34028089.34028089
94 Obersztyn A, Kolwinski K, Trykowski J, Effects of stannous fluoride and amine fluorides on caries incidence and enamel solubility in adults. Aust Dent J. 1979;24(6):395–7. doi: 10.1111/j.1834–7819.1979.tb03633.x. PMID: 295205.295205
95 Wallace MC, Retief DH, Bradley EL. The 48-month increment of root caries in an urban population of older adults participating in a preventive dental program. J Public Health Dent. 1993;53(3):133–7. doi: 10.1111/j.1752–7325.1993.tb02691.x. PMID: 8371190.8371190
96 Yildiz E, Dorter C, Efes B, A comparative study of two fissure sealants: a 2-year clinical follow-up. J Oral Rehabil. 2004;31(10):979–84. doi: 10.1111/j.1365–2842.2004.01334.x. PMID: 15387838.15387838
97 Bader JD, Vollmer WM, Shugars DA, Results from the Xylitol for Adult Caries Trial (X-ACT). J Am Dent Assoc. 2013;144(1):21–30. doi: 10.14219/jada.archive.2013.0010. PMID: 23283923.23283923
98 Haag DG, Peres KG, Balasubramanian M, Oral Conditions and Health-Related Quality of Life: A Systematic Review. J Dent Res. 2017;96(8):864–74. doi: 10.1177/0022034517709737. PMID: 28581891.28581891
99 Sim S- J. Association between oral health status and perceived general health (EuroQol-5D). J Dent Hyg. 2014;14(3):364–70.
100 Baniasadi K, Armoon B, Higgs P, The Association of Oral Health Status and socioeconomic determinants with Oral Health-Related Quality of Life among the elderly: A systematic review and meta-analysis. Int J Dent Hyg. 2021;19(2):153–65. doi: 10.1111/idh.12489. PMID: 33523593.33523593
101 Gharehghani MA M, Bayani A, Bayat AH, Poor oral health-related quality of life among pregnant women: A systematic review and meta-analysis. Int J Dent Hyg. 2021;19(1):39–49. doi: 10.1111/idh.12465. PMID: 32941664.32941664
102 Ardila CM, Agudelo-Suarez AA. Association between dental pain and caries: a multilevel analysis to evaluate the influence of contextual and individual factors in 34 843 adults. J Investig Clin Dent. 2016;7(4):410–6. doi: 10.1111/jicd.12168. PMID: 26084783.26084783
103 Bastos JL, Nomura LH, Peres MA. Dental pain, socioeconomic status, and dental caries in young male adults from southern Brazil. Cadernos de Saude Publica. 2005;21(5):1416–23. PMID: 16158147.16158147
104 Garcia-Cortes JO, Mariel-Cardenas J, Martinez-Rider R, Dental pain and associated factors in Mexican adolescents and young adults: a cross-sectional study. Int Dent J. 2020;70(6):455–61. doi: 10.1111/idj.12598. PMID: 32737891.32737891
105 Hull PS, Worthington HV, Clerehugh V, The reasons for tooth extractions in adults and their validation. J Dent. 1997;25(3–4):233–7. doi: 10.1016/s0300–5712(96)00029–2. PMID: 9175351.9175351
106 Phipps KR, Stevens VJ. Relative contribution of caries and periodontal disease in adult tooth loss for an HMO dental population. J Public Health Dent. 1995;55(4):250–2. doi: 10.1111/j.1752–7325.1995.tb02377.x.. PMID: 8551465.8551465
107 Niessen LC, Weyant RJ. Causes of tooth loss in a veteran population. J Public Health Dent. 1989;49(1):19–23. doi: 10.1111/j.1752-7325.1989.tb02014.x. PMID: 2642966.2642966
108 Cahen PM, Frank RM, Turlot JC. A survey of the reasons for dental extractions in France. J Dent Res. 1985;64(8):1087–93. doi: 10.1177/00220345850640081401. PMID: 2862168.2862168
109 McCaul LK, Jenkins WM, Kay EJ. The reasons for extraction of permanent teeth in Scotland: a 15-year follow-up study. Br Dent J. 2001;190(12):658–62. doi: 10.1038/sj.bdj.4801068. PMID: 11453155.11453155
110 Firmino RT, Martins CC, Faria LD S, Association of oral health literacy with oral health behaviors, perception, knowledge, and dental treatment related outcomes: a systematic review and meta-analysis. J Public Health Dent. 2018;78(3):231–45. doi: 10.1111/jphd.12266. PMID: 29498754.29498754
111 Dahlan R, Badri P, Saltaji H, Impact of acculturation on oral health among immigrants and ethnic minorities: A systematic review. PLoS One. 2019;14(2):e0212891. doi: 10.1371/journal.pone.0212891. PMID: 30818332.30818332
112 Cibulka NJ, Forney S, Goodwin K, Improving oral health in low-income pregnant women with a nurse practitioner-directed oral care program. J Am Acad Nurse Pract. 2011;23(5):249–57. PMID: CN-00800456.21518073
113 Jurasic MM, Gibson G, Orner MB, Validation of a Subjective Caries Risk Assessment Tool. J Dent. 2021;113:103748. doi: 10.1016/j.jdent.2021.103748. PMID: 34274438.34274438
114 Su N, Lagerweij MD, van der Heijden G. Assessment of predictive performance of caries risk assessment models based on a systematic review and meta-analysis. J Dent. 2021;110:103664. doi: 10.1016/j.jdent.2021.103664s. PMID: 33984413.33984413
115 U.S. Department of Health and Human Services Federal Panel on Community Water Fluoridation. U.S. Public Health Service Recommendation for Fluoride Concentration in Drinking Water for the Prevention of Dental Caries. Public Health Rep. 2015;130(4):318–31. doi: 10.1177/003335491513000408. PMID: 26346489.26346489
116 Sterne JA, Sutton AJ, Ioannidis JP, Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. doi: 10.1136/bmj.d4002. PMID: 21784880.21784880
117 AMA Approves Code for Healthcare Personnel to Apply SDF. 2022. https://decisionsindentistry.com/2022/10/ama-approves-code-healthcare-personnel-apply-sdf/. Accessed Mar 26 2023.
118 Lewis C, Quinonez R, Sisk B, Incorporating Oral Health into Pediatric Practice: National Trends 2008, 2012, 2018. Acad Pediatr. 2022. doi: 10.1016/j.acap.2022.06.008. PMID: 35732259.35732259
119 Seifo N, Cassie H, Radford J, "Iťs really no more difficult than putting on fluoride varnish": a qualitative exploration of dental professionals' views of silver diamine fluoride for the management of carious lesions in children. BMC Oral Health. 2020;20(1):257. doi: 10.1186/s12903–020-01243-y. PMID: 32933507.32933507