# Chapter 4 Discussion

## Summary of Review Findings

Table 4 summarizes the evidence reviewed for this report. Dental caries and periodontal disease are common in U.S. adults and often remain untreated, potentially resulting in adverse oral and other health outcomes. Disparities in oral health, related in part to social determinants including inadequate access to dental services, suggest a potential role for primary care providers in oral health screening and prevention. This report updates and expands upon a 1996 USPSTF recommendation on oral health counseling by addressing oral health screening and prevention in adults. It complements other USPSTF reviews on oral health topics, including a concurrent review on oral health screening and prevention in children and adolescents 5 to 18 years of age^10^ and prior USPSTF reviews on dental caries screening and prevention in children less than 5 years of age^8^ and on screening for oral cancer.^9^

Table 4 Summary of Evidence - Oral Health in Adults Age 18 Years and Older

Analytic Framework | Key question | Number of studies (k) Number of participants (n) Study design | Summary of findings by outcome | Consistency/precision Reporting bias | Overall quality | Body of evidence limitations | Strength of evidence | Applicability
Screening | KQ 1 Screening effectiveness | k=1 RCT; N=477 | Decayed teeth: Mean 1.47 [SD 2.51] vs. 2.01 [SD 2.55]; Filled teeth: Mean 3.06 [SD 3.04] vs. 2.09 [SD 2.53]; Periodontal disease outcomes: No differences; Birth outcomes: No differences | Consistency: Unable to assess; Imprecise; Reporting bias: Not suspected | Poor | Single trial with serious methodological limitations and imprecise estimates | Insufficient | Midwife-led intervention likely has generalizability to primary care; trial enrolled pregnant persons in first trimester in Australia
Screening | KQ 2 Screening accuracy; a. Identification of existing oral health issues; b. Identification of persons at increased risk for future oral health issues | a. Questionnaires:; k=6; N=1,184; Oral health exam:; k=1; N=86; b. No studies | Questionnaires:; Pooled sensitivity 0.72 (95% CI 0.57 to 0.83) and pooled specificity 0.74 (95% CI 0.66 to 0.82) for periodontal disease, based on 4 studies of similar questionnaires; 2 other studies evaluated questionnaires that were not poolable (1 study reported an AUROC of 0.86 [95% 0.76 to 0.95] for a 7-item questionnaire and 1 study reported a sensitivity of 0.88 and specificity of 0.14 for a 2-item questionnaire); Oral health exam (1 study): For periodontal disease, sensitivity 0.42 and 0.56 and specificity 0.84 and 0.87; for dental caries, sensitivity 0.33 and 0.83 and specificity 0.80 and 0.93 | Consistency: Serious inconsistency present (questionnaire) and low interrater reliability (oral health examination); Some imprecision present; Reporting bias: Not suspected | Moderate | Most studies had methodological limitations; serious inconsistency or interrater reliability; variability in the questionnaires assessed; no studies on identification of persons at increased risk of future oral health issues and most studies focused on identification of periodontal disease | Low | 5 of 6 studies on questionnaires were conducted in dental settings but the questionnaires were self-administered and appeared relevant for primary care; high prevalence of periodontal disease in the studies; questionnaires included items on prior treatment for periodontal disease, potentially reducing applicability to screening
Screening | KQ 3 Screening harms | No studies | -- | -- | -- | -- | -- | --
Prevention | KQ 1 Screening accuracy^*^ (Identification of persons at increased risk of future caries) | No studies | -- | -- | -- | -- | -- | --
Prevention | KQ 2 Behavioral counseling | No studies | -- | -- | -- | -- | -- | --
Prevention | KQ 3 Referral | No studies | -- | -- | -- | -- | -- | --
Prevention | KQ 4 Preventive interventions; Topical fluorides (varnish or gel/solution) | k=5 trials; (1 RCT and 4 non-randomized, or randomization unclear, trials); N=971 | Inconsistent effects on caries burden for fluoride varnish (2 trials) and fluoride gels/solutions (3 trials) | Serious inconsistency; Reasonably precise; Reporting bias: Not suspected | Poor | Serious methodological limitations; serious inconsistency | Insufficient | Three trials focused on older adults (in residential or nursing homes in 2 trials and in the community in 1 trial) and two trials focused on young adults; two trials were conducted prior to 1980; topical fluorides were not administered by primary care clinicians in any trial (either administered by dental professionals or person administering not reported)
Prevention | KQ 4 Preventive interventions; Sealants | k=2 trials (1 RCT and 1 non-randomized trial); N=178 | Sealants associated with decreased likelihood of caries (RR 0.63, 95% CI 0.31 to 1.29) or proportion of teeth with caries (RR 0.23, 95% CI 0.10 to 0.49) in young adults | No inconsistency; Some imprecision; Reporting bias: Not suspected | Poor | Serious methodological limitations | Insufficient | Both trials focused on young adults (students); one trial published in 1979; sealants administered by dental professionals
Prevention | KQ 4 Preventive interventions; SDF | k=3 RCTs; N=590 | SDF associated with decreased new root caries lesions or fillings versus placebo (3 trials, mean reduction −0.33 to −1.8 at 24 to 30 months) | Some inconsistency in magnitude of benefit (no inconsistency in direction of benefit); Reasonably precise; Reporting bias: Not suspected | Fair | Some inconsistency in magnitude of benefit | Moderate | All trials conducted in older adults in China (2 trials of community dwelling persons and one trial in persons living in community or nursing homes); SDF administered by dental professionals
Prevention | KQ 4 Preventive interventions; Xylitol | No studies | -- | -- | -- | -- | -- | --
Prevention | KQ 5 Harms of preventive interventions | k=1 RCT; N=235 | Study states, “No major side effects or discomfort were reported” | Unable to assess inconsistency (1 trial); Imprecise; Potential reporting bias (1 of 9 trials of preventive interventions reported harms) | Poor | Suboptimal reporting of harms in 1 of 9 trials of preventive interventions | Insufficient | The only trial that reported harms evaluated fluoride varnish and SDF

* This is the same as KQ 2b from the screening framework.

Abbreviations: AUROC = area under the receiver operating characteristic; CI = confidence interval; KQ = key question; RCT = randomized controlled trial; RR = relative risk; SD = standard deviation; SDF = silver diamine fluoride.

Evidence on screening was very limited. One randomized trial evaluated a midwife-led oral health screening intervention in pregnant persons but had serious methodological limitations and found no differences in caries outcomes, periodontal disease outcomes, or birth outcomes.^80^ Six studies evaluated questionnaires for assessing presence of periodontal disease. The questionnaires were based on self-report and appeared feasible for use in primary care settings; however, four of the six studies were conducted in dental care settings and prevalence of periodontal disease was high. In four studies that evaluated questionnaires similar enough to pool, diagnostic accuracy was moderate (pooled sensitivity 0.72, 95% CI 0.57 to 0.83 and pooled specificity 0.74, 95% CI 0.66 to 0.82).^82–84,86^ The questionnaires included items on prior treatment for periodontal disease, which could limit applicability to screening. Two other studies evaluated questionnaires that included items not addressed in the pooled questionnaires (age, gender, smoking status, and educational level; AUROC 0.86, 95% CI 0.76 to 0.95)^85^ or only included two items evaluated in pregnant persons (sensitivity 0.88 and specificity 0.14).^80,81^ Evidence on accuracy of the primary care oral health examination was limited to one study that reported low specificity (0.56 and 0.68, based on two primary care examiners) for periodontal disease and high specificity (0.83 and 0.81) for dental caries, with variable sensitivity (range 0.33 to 0.93).^87^ No study evaluated the accuracy of questionnaires for identification of dental caries or the accuracy of questionnaires or oral health examination for identifying persons at high risk for future development of caries or periodontal disease. Although caries risk prediction instruments exist, they did not meet inclusion criteria because they utilized dental examination and tests not administered in primary care (x-rays, cariogenic bacteria levels, salivary flow rates); furthermore, most instruments were primarily designed for assessment of young children.^113,114^

Evidence on preventive interventions was also limited. There were no trials of primary care counseling versus no counseling or primary care referral to a dental professional versus no referral. Regarding preventive interventions, three RCTs conducted in China found SDF solution was associated with a small decrease in the number of new root caries lesions or filling versus placebo in older adults (mean difference −0.33 to −1.3 at 24 to 30 months).^88,90,91^ Evidence for sealants (two trials)^89,96^ and topical fluorides (varnish or gels/solutions; 5 trials)^88,92–95^ was insufficient, as all trials had serious methodological limitations (including non-randomized design, open-label design, and high attrition), with inconsistency in the topical fluoride trials. There were no trials of xylitol for prevention (one randomized trial of adults with existing caries that did not meet inclusion criteria found no beneficial effects of xylitol)^97^ and harms were poorly reported (one trial of fluoride varnish or SDF reported no harms^88^ and eight other trials of topical fluorides, sealants, and SDF did not report harms). No study reported harms of exposure to a fluoride preventive intervention in adults versus no exposure and risk of fluorosis.

## Limitations

There were important limitations in the evidence available to address the benefits and harms of primary care oral health screening and prevention. The greatest issue was the overall paucity of evidence. The only primary care relevant study of oral health screening versus no screening was conducted in pregnant persons, there was only one study on the accuracy of the primary care oral health examination, there were no studies on accuracy of questionnaires for identification of persons with dental caries or on identification of persons at risk for future oral health issues, and there were no studies of primary care counseling versus no counseling or primary care referral to a dental professional versus no referral. Trials of oral health primary care intervention focused on caries outcomes, with no trials evaluating effects on periodontal or health outcomes (quality of life, tooth loss/edentulism) and studies were not designed to evaluate effects on clinical conditions associated with poor oral health such as adverse cardiovascular or cognitive outcomes. In addition, studies of topical fluorides and sealants had serious methodological limitations, and reporting of harms in the trials was very poor. Importantly, several factors may also reduce applicability of the available evidence to U.S. primary care practice. First, the preventive interventions were administered by dental professionals in all trials, with unknown effectiveness and feasibility in primary care settings. Second, all three trials of fluoride gels and solutions and one of two trials of sealants were published between 1993 and 1995, when the prevalence of dental caries and periodontal disease was higher. Third, all trials of SDF were conducted in older adults in China, where oral health behaviors and dental care may differ from the United States, in an area with suboptimal water fluoridation (0.5 mg/L; the U.S. Public Health Service recommends an optimal concentration of 0.7 mg/L).^115^ Fourth, water fluoridation levels, provision of oral health education, and oral health behaviors were not consistently reported by the trials, although these factors could impact the effectiveness of oral health preventive interventions.

There were also potential limitations in the review methods. First, we excluded non-English language articles, which could result in language bias. However, we did not identify non-English language articles that appeared likely to impact conclusions. Second, we did not search for studies published only as abstracts. Third, we were unable to assess for publication bias with graphical or statistical methods for small sample effects, due to small numbers of studies with serious methodological limitations.^116^ Fourth, we did not perform meta-analysis for preventive interventions, also because of small numbers of studies with serious methodological limitations. Fifth, we did not evaluate the effectiveness of tooth brushing or flossing, as these are performed outside the primary care setting and routinely recommended. Rather, the review addressed the effectiveness of counseling on oral health, including counseling on tooth brushing, flossing and diet.

## Emerging Issues/Next Steps

SDF was cleared for U.S. marketing by the FDA in 2014 as a desensitizing agent in adults.^57^ Although it has been used to arrest existing caries, this use is off-label. Similarly, use of SDF for prevention of caries is also off-label. In 2022, the American Medical Association approved a Current Procedural Terminology (CPT) code for provision of SDF by non-dental healthcare professionals, which may facilitate reimbursement in primary care settings.^117^ A potential disadvantage of SDF is permanent dark discoloration of active caries lesions by the silver component, which may impact acceptability. However, active caries lesions themselves may be discolored, and may result in other cosmetic consequences.

There are also barriers to administration of oral health preventive interventions such as varnish, sealants, or SDF in primary care settings, including the need for additional training and equipment. Even if such interventions are effective in dental settings, the effectiveness, feasibility, acceptability and uptake (by clinicians and patients) in adult primary care settings is unknown. There is some evidence of increased uptake of primary care administration of fluoride varnish by primary care clinicians in young (<5 years) children,^118^ suggesting feasibility in other (e.g., adult) primary care settings. Applying SDF is considered similar in terms of technical difficulty to applying varnish.^119^ However, sealant application is more technically challenging than varnish application and evidence on implementation by non-dental professionals in primary care settings is lacking. Prior to implementation, it would also be important to clarify reimbursement of primary care clinicians for provision of oral health preventive interventions.

## Relevance for Priority Populations

Disparities among adults in oral health have been described with regard to age, race/ethnicity, socioeconomic status, insurance status, health literacy, immigration status, educational level, pregnancy status, and living in rural and urban underserved areas.^21,68,77^ The relevance of evidence on primary care oral health screening and prevention to priority populations defined by age, race/ethnicity, socioeconomic status, pregnancy status, and other social determinants is limited. Although the only trial of screening was conducted in pregnant persons, it was poor quality.^80^ All trials of SDF for prevention focused on older adults and root caries.^88,90,91^ However, there was no evidence on how effectiveness of oral health screening or preventive interventions varied according to age, race/ethnicity, socioeconomic status, or other social determinants.

## Future Research

Research is needed on benefits and harms of primary care screening versus no screening, primary care counseling versus no counseling, and primary care referral to a dental professional versus no referral. Research is also needed to clarify benefits and harms of oral health preventive interventions including topical fluorides, sealants, and SDF, particularly when they are administered in primary care settings. Importantly, studies of oral health preventive interventions should describe the training and equipment utilized when they are administered in primary care settings and studies on primary care referral should describe approaches to facilitate coordination between primary care and dentistry, in order to inform future implementation efforts. Trials should report water fluoridation levels, oral health behaviors (e.g., tooth brushing), provision of oral health education, and baseline oral health status, so that the context in which effective interventions are delivered are better understood. Studies should enroll representative populations including those disproportionately impacted by poor oral health, and should be conducted in high prevalence settings (e.g., low socioeconomic status, high oral health burden, rural and urban underserved settings). Research is needed on the accuracy of questionnaires that can be used for screening in primary care settings to identify persons more likely to have dental caries or periodontal disease. For questionnaires to be most useful for screening, they should not include items on prior diagnosis or treatment of oral health issues. For preventive interventions, studies on factors for predicting future oral health issues would be helpful for identifying those who may benefit more from preventive interventions. In addition to outcomes related to oral health such as caries burden, trials should assess and report outcomes related to quality of life, tooth loss/edentulism, and function as well as harms; research is also needed to determine effectiveness of screening or prevention of periodontal disease.

## Conclusions

SDF improved root caries outcomes in older adults when administered by dental professionals. Screening questionnaires were associated with moderate diagnostic accuracy for periodontal disease; evidence on the accuracy of the primary care oral health exam was limited and estimates varied. Research is needed to determine benefits and harms of screening, primary care counseling, dental referral, and oral health preventive interventions administered in primary care settings.