# Chapter 3 Results

A total of 16,177 references from electronic database searches and manual searches of recently published studies were reviewed and 312 full-text papers were evaluated for inclusion. Across all KQs, 16 studies (in 17 publications, total 3,300 participants) were included (Appendix A3).^80–96^ One randomized clinical trial (RCT)^80^ and seven diagnostic accuracy studies addressed screening,^81–87^ and four RCTs^88–91^ and five non-randomized trials^92–96^ addressed preventive interventions. Included studies and quality ratings are described in Appendix B.

## Screening Key Questions

### Key Question 1 How Effective Is Screening for Oral Health Performed by a Primary Care Clinician in Preventing Negative Oral Health Outcomes?

#### Summary

- Evidence from one poor-quality randomized controlled trial (RCT) was insufficient to determine effects of oral health screening of pregnant women by midwives versus no screening.

#### Evidence

Evidence on the effects of oral health screening versus no screening is very limited. We identified one RCT of screening versus no screening (Appendix B Table 1).^80^ It was conducted in Australia (water fluoridation status not described; however, the study was conducted in Sydney, which is fluoridated) among pregnant persons in the first trimester and evaluated a midwife-led dental screening intervention versus no intervention (mean age 29 years, n=477, excluding participants randomized to a third [dental intervention] arm). For the screening intervention, midwives administered the maternal oral health screening instrument (consisting of two questions and an optional visual inspection of the oral cavity) and provided oral health education, with dental referrals for persons identified as being at high risk. Baseline caries status was not reported. At followup in the third trimester, there were no statistically significant differences between the midwife screening intervention versus no intervention in the mean number of decayed teeth (1.47 [standard deviation (SD) 2.51] vs. 2.01 [SD 2.55]) or filled teeth (3.06 [SD 3.94] vs. 2.09 [SD 2.53]). Measures of periodontal disease (clinical attachment loss or sulcus bleeding index) and birth outcomes (birth weight, preterm, or low birth weight) were very similar between groups. The trial was rated poor-quality; methodological limitations included open-label design, unclear allocation concealment methods, and high attrition (oral health outcomes assessed in 44% of participants randomized) (Appendix B Table 2).

### Key Question 2a How Accurate Is Screening for Oral Health Performed by a Primary Care Clinician in Identifying Adults Who Have Oral Health Issues?

#### Summary

- Self-reported questionnaires on perceived dental health were associated with a pooled sensitivity of 0.72 (95% CI 0.57 to 0.83, I^2^=91%) and a specificity of 0.74 (95% CI 0.66 to 0.82, I^2^=73%) for periodontitis (four studies, N=965), though statistical heterogeneity was substantial. The questionnaires were associated with fair discrimination (area under summary receiver operating characteristic [sROC] 0.79, 95% CI 0.75 to 0.83).
- One study (n=86) found primary care examination associated with high specificity for dental caries and periodontal disease, with low sensitivity for periodontal disease and variable sensitivity for caries.

#### Evidence

##### Screening Risk Instruments

Six studies (N=1,184, range 88 to 408) reported in seven publications assessed the diagnostic accuracy of a self-reported oral health questionnaire for periodontal disease in adults (Appendix B Table 3).^80–86^ The reference standard was a dental exam,^81,82,85,86^ intra-oral screening using the Community Periodontal Index of Treatment Needs (CPITN) by a dentist,^84^ or radiographic evidence of periodontal disease.^83^ Studies were conducted in a dental setting (e.g., dental hospital, clinic, or school)^82,83,85,86^ or an outpatient medical setting.^80,81,84^ Two studies were conducted in Germany,^83,85^ two in the Netherlands,^84,86^ one in Australia,^80,81^ and one in China.^82^ Three studies used the same or a similar 8-item questionnaire on self-perceived dental health,^82,84,86^ one study used a more detailed 21-item questionnaire that also focused on self-perceived dental health,^83^ one combined items on self-perceived dental health with patient demographics and smoking status,^85^ and one assessed a brief (2-item) questionnaire in pregnancy.^81^ In the studies, the prevalence of at least mild periodontitis ranged from 39 percent to 100 percent and severe periodontitis ranged from 20 percent to 39 percent. Mean study age ranged from 40 to 58 years, except for one study of pregnant persons in which the mean age was 29 years. All studies were rated fair-quality; common methodological limitations included unclear blinding of screeners to the reference standard and use of non-predefined thresholds for a positive screen (Appendix B Table 4). One study evaluated a non-representative spectrum (patients referred for endodontic surgery),^83^ one study reported that a high proportion of patients did not undergo the reference standard,^80,81^ and in two studies it was unclear if reference standard assessment was blinded to screening results.^85,86^

The questionnaire used by two studies (N=311)^84,86^ consisted of eight self-reported items on dental health (Table 1); another study (n=408) used a similar but slightly modified questionnaire (“Do not know” added as a response; coronal scaling separated from root planing, and days per week not specified for questions 7 and 8).^82^ A fourth study (n=246) used a 21-item questionnaire that also focused on self-reported dental health, but was more detailed.^83^ There were some differences in the issues addressed: while questions on flossing and mouthwash were not included in the 21-item questionnaire, it had additional items on malodor or bad taste in mouth, gum recession, gaps between teeth, and swollen gums. In each study, a logistic regression model was developed to predict the probability of periodontal disease based on the responses to the questionnaires; diagnostic accuracy was based on the optimum probability threshold (the probability providing the best combination of sensitivity and specificity). An issue that could reduce applicability of the questionnaires for screening is that they included items on prior treatment for periodontal disease.

Table 1 Self-Reported Oral Health Questionnaire

Item # | Question | Possible Responses
1 | Do you think you might have gum disease? | Yes; No
2 | Overall, how would you rate the health of your teeth and gums? | Poor; Fair; Good; Very good; Excellent
3 | Have you ever had treatment for gum disease such as scaling and root planning, sometimes called “deep cleaning”? | Yes; No
4 | Have you ever had any teeth become loose on their own, without an injury? | Yes; No
5 | Have you ever been told by a dental professional that you lost bone around your teeth? | Yes; No
6 | During the past three months, have you ever noticed a tooth that doesn’t look right? | Yes; No
7 | Aside from brushing your teeth with a toothbrush, in the last seven days, how many times did you use dental floss or any other device to clean between your teeth? | 1–7 days/week; Never
8 | Aside from brushing your teeth with a toothbrush, in the last seven days, how many times did you use mouthwash or other dental rinse product that you use to treat dental disease or dental problems? | 1–7 days/week; Never

Source: Nijland 2021^84^ and Verhulst 2019.^86^

A pooled analysis of 4 studies (N=965) found the screening questionnaires that focused on self-perceived dental health associated with a sensitivity of 0.72 (95% CI 0.57 to 0.83, I^2^=91%) and a specificity of 0.74 (95% CI 0.66 to 0.82, I^2^=73%) for periodontitis (defined as stage I through IV periodontitis, CPITN scores 3 and 4, moderate and severe periodontitis, or ≥2 teeth with Alveolar Bone Loss (ABL) ≥5 mm)^82–84,86^ (Figure 3). The probability threshold ranged from 0.34 to 0.68 in three studies; the fourth study^83^ did not report the probability threshold utilized. Statistical heterogeneity was substantial, particularly for sensitivity. Stratified and sensitivity analyses to evaluate potential sources of heterogeneity were limited by the small number of studies. One study^84^ of an 8-item questionnaire administered in a medical setting reported lower sensitivity (0.49, 95% CI 0.38 to 0.60) compared to three studies conducted in dental settings (sensitivity ranged from 0.68 to 0.85), though its specificity (0.68, 95% CI 0.56 to 0.79) was within the range reported by the dental setting studies (range 0.63 to 0.84). A dental clinic setting study that used the identical 8-item questionnaire resulted reported similar specificity (0.63, 95% CI 0.48 to 0.76) but higher sensitivity (0.85, 95% CI 0.76 to 0.91).^86^

Figure 3 Sensitivity and Specificity of Questionnaire for Periodontitis

Abbreviations: CI = confidence interval; df = degrees of freedom.

Figure 3 depicts two forest plots—one for sensitivity and one for specificity. The sensitivity plot contains a pooled analysis of four studies with a sensitivity of 0.72 (95% CI 0.57 to 0.83) and an I-squared value of 91.27%. The specificity plot contains a pooled analysis of the same four studies with a specificity of 0.74 (95% CI 0.66 to 0.82) and an I-squared value of 73.40%.

The questionnaires were associated with fair discrimination for distinguishing between persons with and without periodontitis (area under sROC 0.79, 95% CI 0.75 to 0.83)^82–84,86^ (Figure 4).

Figure 4 sROC for Periodontitis vs. No Periodontitis

Abbreviations: AUC = area under curve; SENS = sensitivity; SPEC = specificity; sROC=summary receiver operating characteristic.

Figure 4 depicts a graph with sensitivity on the y-axis and specificity on the x-axis. The area under the summary receiver operating characteristics curve is 0.79 with a 95% CI of 0.75 to 0.83. Two sets of dotted circles surrounding the summary operating point indicate the 95% confidence contour and 95% prediction contour, respectively. The observed data are indicated by small circles surrounding the summary operating point, labeled one through four.

When the analysis was limited to identification of more severe periodontitis (i.e., stage III/IV periodontitis, CPITN score 4, severe periodontitis, ≥3 teeth with ABL ≥6 mm) pooled sensitivity was similar and specificity slightly higher than for any periodontitis, though confidence intervals overlapped (four studies, N=965, 0.68, 95% CI 0.61 to 0.75, I^2^=40%; 0.80, 95% CI 0.71 to 0.87, I^2^=90%, respectively; Figure 5). Focusing on the outcome of more severe periodontitis reduced statistical heterogeneity for sensitivity, although heterogeneity remained high for specificity. The probability threshold ranged from 0.16 to 0.30 in three studies; the fourth study^83^ did not report the probability threshold.

Figure 5 Sensitivity and Specificity of Questionnaire for Severe Periodontitis

Abbreviations: CI = confidence interval; df = degrees of freedom.

Figure 5 depicts two forest plots—one for sensitivity and one for specificity. The sensitivity plot contains a pooled analysis of four studies with a sensitivity of 0.68 (95% CI 0.61 to 0.75) and an I-squared value of 39.59%. The specificity plot contains a pooled analysis of the same four studies with a specificity of 0.80 (95% CI 0.71 to 0.87) and an I-squared value of 89.66%.

Discrimination of the questionnaires for distinguishing persons with from those without severe periodontitis was similar to discrimination for any periodontitis (area under sROC 0.76, 95% CI 0.72 to 0.80) (Figure 6).^82–84,86^

Figure 6 sROC Curve for Severe Periodontitis vs. No Severe Periodontitis

Abbreviations: AUC = area under curve; SENS = sensitivity; SPEC = specificity; sROC=summary receiver operating characteristic.

Figure 6 depicts a graph with sensitivity on the y-axis and specificity on the x-axis. The area under the summary receiver operating characteristics curve is 0.76 with a 95% CI of 0.72 to 0.80. Two sets of dotted circles surrounding the summary operating point indicate the 95% confidence contour and 95% prediction contour, respectively. The observed data are indicated by small circles surrounding the summary operating point, labeled one through four.

One study (n=88) used a 7-item questionnaire that differed from the instruments in the meta-analysis;^85^ therefore, it was not pooled with them. This questionnaire included items about gum bleeding and tooth mobility and five items on patient characteristics (age, gender, current and past smoking, and education); the seven items in the questionnaire were used to generate a patient-reported Periodontitis Risk Score (pPRS, range 0 to 20). A cutoff of ≥7 on the pPRS was associated with a sensitivity of 0.87 (95% CI, 0.78 to 0.94), specificity of 0.84 (95% CI, 0.67 to 0.95), and an odds ratio for periodontal inflammation of 39.09 (95% CI 9.82 to 132), using the ADA’s Periodontal Screening and Recording (PSR) by a dentist as the reference standard. The pPRS was associated with good discrimination for detecting periodontal inflammation (AUROC 0.86, 95% CI 0.76 to 0.95).

The sixth study (n=131) screened pregnant women during an antenatal visit and evaluated the Maternal Oral Screening tool, which consisted of two items: “Do you have problems in your mouth?” and “Have you seen a dentist in the last 12 months?” It was also not included in the pooled analyses of the more detailed questionnaires on self-perceived dental health.^80,81^ The 2-item screener was associated with sensitivity of 0.88 (95% CI 0.80 to 0.96) and specificity of 0.14 (95% CI 0.05 to 0.23) for a positive dental exam (defined as a PSR rating of at least 2, indicating early signs of periodontitis or presence of any tooth decay).^81^

##### Oral Health Exam

One good-quality study evaluated the diagnostic accuracy of an oral health exam in primary care (Appendix B Tables 3 and 4).^87^ Eighty-six patients (mean age 66 years, 99% male) at a Veterans Affairs medical clinic were screened independently by two primary care providers (a physician internist and a physician, resident, or physician assistant). The reference standard was a same-day exam by a dentist. The prevalence of periodontal disease and caries was 37 percent and 18 percent, respectively. A primary care oral health exam was associated with high specificity (range, 0.80 to 0.93) for periodontal disease or caries; however, sensitivity was low for periodontal disease (0.56, 95% CI 0.38 to 0.74 and 0.42, 95% CI 0.24 to 0.56 for two examiners) and variable for caries (0.33, 95% CI 0.12 to 0.62 and 0.83, 95% CI 0.52 to 0.96) (Table 2).

Table 2 Sensitivity and Specificity for Periodontal Disease and Caries

Disease | Screener | Sensitivity (95% CI) | Specificity (95% CI)
Periodontal Disease | Clinician 1 | 0.56 (0.38 to 0.74) | 0.87 (0.75 to 0.95)
Periodontal Disease | Clinician 2 | 0.42 (0.24 to 0.56) | 0.84 (0.71 to 0.92)
Caries | Clinician 1 | 0.33 (0.12 to 0.62) | 0.93 (0.84 to 0.98)
Caries | Clinician 2 | 0.83 (0.52 to 0.96) | 0.80 (0.69 to 0.89)

Source: Westman 1994.^87^

### Key Question 2b How Accurate Is Screening for Oral Health Performed by a Primary Care Clinician in Identifying Adults Who Are at Increased Risk for Future Oral Health Issues?

No studies addressed this Key Question that met inclusion criteria (examined screening for oral health accuracy performed by a primary care clinician in identifying adults at increased risk for future oral health issues).

### Key Question 3 What Are the Harms of Screening for Oral Health Performed by a Primary Care Clinician?

One trial of oral health screening of pregnant persons versus no screening did not report harms.^80^

## Prevention Key Questions

### Key Question 1 How Accurate Is Screening Performed by a Primary Care Clinician in Identifying Adults Who Are at Increased Risk of Future Oral Health Issues?

As noted for Key Question 2b in the Screening Analytic Framework, no studies addressed this Key Question that met inclusion criteria.

### Key Question 2 How Effective Is Oral Health Behavioral Counseling Provided by a Primary Care Clinician in Preventing Oral Health Issues?

No studies addressed this Key Question that met inclusion criteria.

### Key Question 3 How Effective Is Referral by a Primary Care Clinician to a Dental Health Care Provider in Preventing Oral Health Issues?

No studies addressed this Key Question that met inclusion criteria.

### Key Question 4 How Effective Are Preventive Interventions in Preventing Oral Health Issues?

#### Summary

- There was insufficient evidence from one fair-quality and four poor-quality trials (N=971) with inconsistent results to determine effects of topical fluorides (varnish or gel/solution) in adults.
- Evidence from two poor-quality trials (one randomized and one non-randomized) was insufficient to determine effects of sealants in adults.
- SDF solution was more effective than placebo in reducing the number of new root caries lesions or fillings in older adults (mean difference −0.33 to −1.3 at 24 to 30 months in three RCTs, N=590) and reducing the likelihood of developing new root caries (adjusted OR 0.4, 95% CI 0.3 to 0.7 and RR 0.19, 95% CI 0.07 to 0.46 in 2 RCTs, N=478); all trials were conducted in Hong Kong.
- No study evaluated effects of xylitol for prevention.

#### Evidence

##### Topical Fluorides

Five trials evaluated topical fluorides (varnish or gels/solutions) versus placebo or no topical fluoride for prevention of dental caries in adults (Appendix B Table 5).^88,92–95^ In all trials, topical fluorides were applied by dental professionals. Sample sizes ranged from 104 to 318 (N=971). Two trials were conducted in Europe, two trials in the United States, and one trial in Hong Kong. One U.S. trial described water fluoridation status as “optimal”^95^ and water fluoridation level is 0.5 parts per million (ppm) fluoride in Hong Kong;^88^ water fluoridation status was otherwise not reported. Three studies were published between 1993 to 2021 and two between 1955 to 1979; the older trials may have reduced generalizability to current practice due to marked decreases in caries burden in U.S. adults since the 1970s. One trial was fair-quality^88^ and four trials were rated poor-quality (Appendix B Table 6). The poor quality trials were included because higher quality evidence was largely unavailable. Only one trial was randomized;^88^ the other trials were non-randomized or use of randomization was unclear. Methodological limitations in the randomized trial included unclear allocation concealment methods, open-label design, and failure to report attrition or use of intention-to-treat analysis. In addition to not being randomized, the other trials had high or unclear attrition and open-label design, with unclear baseline similarity of groups; in addition, all but two^93,95^ of the trials did not adjust for potential confounders.

The randomized control trial^88^ and one non-randomized trial^93^ evaluated sodium fluoride varnish (22,600 ppm). The other trials evaluated sodium fluoride (2%) solution,^92^ stannous fluoride (30%) paste followed by a stannous fluoride (10%) aqueous solution,^94^ and acidulated phosphate fluoride (1.2%).^95^ Three trials^88,93,95^ focused on older adults; two trials^88,93^ focused on older adults (mean ages 79 to 84 years) in residential or nursing homes and one trial^95^ focused on older adults (60 years or older; mean age not reported) in the community. Two trials^92,94^ focused on young adults (means ages 20 to 22 years) enrolled at college or a military training center. None of the studies reported race or ethnicity. In three trials^88,92,93^ the proportion of women ranged from 61 percent to 100 percent; one trial^94^ only enrolled men and one trial^95^ did not report sex or gender. All patients in one trial^95^ reported use of fluoridated dentifrices in addition to the study interventions; oral health behaviors were not reported in the other trials.

###### Fluoride Varnish

Two trials evaluated 22,600 ppm sodium fluoride varnish in older adults and reported inconsistent results.^88,93^ One randomized controlled trial (n=104)^88^ performed in Hong Kong enrolled older adults in residential and nursing homes (mean age 79 years; mean decayed and filled surfaces (DFS)-root at baseline 2.2). It found application of sodium fluoride (22,600 ppm) varnish every three months associated with a non-statistically significant reduction in dental caries burden at 1 year (mean difference in new active caries or fillings of 0.7, p>0.05), though differences were larger and statistically significant at two (mean difference 1.8, p<0.001) and three (mean difference 1.6, p<0.001) years. Varnish was also associated with decreased risk of developing new caries (relative risk [RR] 0.25, 95% CI 0.10 to 0.63; number needed to treat [NNT] 3.1, 95% CI 2.1 to 7.7). One non-randomized cluster trial (n=232)^93^ of older adults in long-term care facilities (mean age 84 years; mean DMFT of 21.5 in the intervention group and 21.87 in the control group) found sodium fluoride varnish (22,600 ppm) associated with no difference in caries burden based on DMFT score at 1 year (adjusted mean difference −0.04, 95% CI −0.10 to 0.03).

###### Other Topical Fluorides

Three trials evaluated other topical fluorides.^92,94,95^ All were non-randomized or randomization was unclear. One non-randomized trial^94^ (n=169) conducted in male college students in Poland (age 19 to 20; DMFS at baseline 18.83 and 20.06) found application of stannous fluoride (30%) paste followed by stannous fluoride (10%) aqueous solution every six months associated with lower increase in DMFS index relative to baseline, compared with no treatment at 3 years (6.10 vs. 10.54, p<0.01). A non-randomized trial (n=148) conducted in women at a military training center in the United States (mean age 22 years; baseline caries status not reported) found application of sodium fluoride (2%) solution semi-weekly for 36 months associated with no difference versus placebo (sodium chloride 0.9%) in number of newly decayed teeth (0.95 vs 1.08, p=0.48) or likelihood of experiencing ≥1 new carious teeth (60% vs. 68%, RR 0.88, 95% CI 0.68 to 1.13) at 8 to 14 months.

One U.S. trial (randomization unclear) of adults 60 years and older (mean age not reported; n=318)^95^ living in the community and with at least 15 remaining teeth (mean decayed root surfaces 1.3 vs. 1.3 at baseline; mean filled root surfaces 1.6 vs. 2.3 at baseline) found topical acidulated phosphate fluoride (1.2%) gel applied every three months associated with decreased caries burden, based on new root caries surface lesions (mean 1.36 vs. 1.99, p<0.05) and lower increase in DMFS index relative to baseline, compared with placebo (mean 0.27 vs. 0.91, p<0.05) at 48 months.^95^

##### Sealants

Two trials (N=178) evaluated sealants versus no sealants in adults (Appendix B Table 7).^89,96^ Both trials were rated poor-quality (Appendix B Table 8), but were included because higher quality evidence was unavailable. One trial was conducted in the United States and one trial in Europe. The trials evaluated fluoride or non-fluoride containing light-cured resin-based sealants applied by dental professionals to premolars and molars in young adults. Each used a split mouth design (paired teeth on different sides of the mouth allocated to different treatments). One trial^89^ was randomized but did not report allocation concealment methods, and the other trial^96^ was non-randomized. Other methodological limitations in the trials included open label design and failure to report attrition with no intention-to-treat analysis; additionally, the non-randomized trial did not adjust for confounders. Although the trials both found sealants associated with reduced risk of caries, the estimate was imprecise in one of the trials. Due to poor quality and imprecision, the evidence was insufficient to determine effects of sealants in adults.

The randomized trial (n=119; 719 tooth pairs) was conducted in the United States among military (submarine school) recruits (mean age 22 years, mean baseline DMFT 7.2).^89^ It found non-fluoride-containing sealants associated with a non-statistically significant reduction in the percentage of teeth with caries, with a low rate of caries in both groups (1.7% vs. 2.6%, RR 0.63, 95% CI 0.31 to 1.29). In this trial, the sealant was either a commercially available sealant (Nuvaseal) or a non-commercially available tinted sealant (results were similar for both sealants). The non-randomized trial (n=59; 122 tooth pairs) was conducted in Turkey among dental students without clinically detectable caries.^96^ Although participants who received sealants received either fluoride-containing (Helioseal F) or non-fluoride containing (Concise Light Cure White Sealant) sealants, results were only reported for the sealant groups combined. Sealants were associated with a reduction in the proportion of teeth with caries (5.7% vs. 25.4% at 24 months, RR 0.23, 95% CI 0.10 to 0.49).

##### Silver Diamine Fluoride

Three RCTs evaluated SDF topical solution versus placebo for prevention of caries (Appendix B Table 9).^88,90,91^ Sample sizes for the SDF versus placebo comparisons ranged from 106 to 257 (total N=590). The trials were all conducted among older adults (mean age 72 to 80 years) in Hong Kong (fluoridation 0.5 ppm) and focused on effects of SDF on root caries. At baseline, the mean number of decayed and filled root surfaces ranged from 0.8 to 2.0. Two trials^90,91^ were restricted to community dwelling persons and one trial^88^ included community dwelling persons and those living in nursing homes. In each of the trials, 38 percent SDF solution was administered by a dentist annually. One trial^91^ reported that 88 percent of participants reported brushing twice or more daily and 87 percent used additional aids to clean teeth daily; in the other trials, oral health behaviors at baseline were not reported. In all of the trials, oral health education was provided to all participants. All trials were rated fair-quality; methodological limitations included unclear allocation concealment, unclear or no masking of care providers or patients, and high attrition with no analysis of patients with missing data (Appendix B Table 10).

At 2 to 3 years, SDF was associated with a decrease in the number of new root caries lesions or fillings versus placebo, with a mean reduction at 24 to 30 months of −0.33 to −0.48 in two RCTs^90,91^ and −1.3 in the other RCT.^88^ In the latter trial, the mean difference in new root caries lesions or fillings was −1.8 at 36 months.^88^ Two trials also found SDF associated with decreased likelihood of a new root caries (adjusted odd ratio [OR] 0.4, 95% CI 0.3 to 0.7^90^ and RR 0.19, 95% CI 0.07 to 0.46).^88^ Two trials evaluated additional interventions used in addition to SDF.^90,91^ One trial reported similar results for SDF and SDF plus topical potassium iodine (which may prevent staining).^90^ Another trial found SDF plus an oral health intervention associated with slightly fewer new root caries surfaces than SDF without the oral health intervention (mean number of new root caries surfaces at 24 months 0.70 [standard error (SE) 0.11] vs. 1.00 [SE 0.16]).^91^

##### Xylitol

No study evaluated xylitol for prevention. One trial of xylitol versus placebo was excluded because it restricted enrollment to patients with caries at baseline (n=691).^97^ It found a very small, non-statistically significant difference between xylitol lozenges versus placebo in D_2_FS increment (annualized mean difference −0.32; incidence rate ratio 0.89, 95% CI 0.80 to 1.01).

### Key Question 5 What Are the Harms of Specific Interventions (Behavioral Counseling, Referral, and Preventive Interventions) to Prevent Oral Health Issues?

#### Summary

- One trial (n=235) of fluoride varnish or SDF versus placebo reported no harms; eight other trials of oral health preventive interventions did not report harms.

#### Evidence

Reporting of harms of oral health preventive interventions was very limited. Of nine trials of oral health preventive interventions (topical fluorides [varnish or gels/solutions], sealants, and SDF) that met inclusion criteria for Key Question 4, only one trial reported harms. This trial (n=235) evaluated fluoride varnish or SDF versus placebo and stated “no major side effects or discomfort was reported.”^88^ Harms were unreported in the other eight trials of oral health preventive interventions. There were no trials of counseling versus no counseling or referral versus no referral and no cohort studies on risk of fluorosis following use of preventive interventions in adults.

## Contextual Questions

### Contextual Question 1 What Is the Association Between Presence or Severity of Dental Caries in Adults and Pain, Quality of Life, Function, and Tooth Loss/Edentulism?

No longitudinal studies evaluated the association between improvements in measures of dental caries or periodontal disease and health outcomes such as pain, quality of life, function, or tooth loss/edentulism. However, cross-sectional evidence indicates a negative association between dental caries and quality of life or function; evidence on periodontal disease is more mixed. Data also indicate an association between presence of dental caries and dental pain and dental caries or periodontal disease and tooth loss.

A systematic review of observational studies included three studies (N=15,326) of dental caries and seven studies (N=17,021) of periodontal disease.^98^ Dental caries was negatively associated with health-related quality of life (HRQoL) after adjustment for key confounding factors in all three studies. The largest study (N=14,231) included in the systematic review, which accounted for 93 percent of patients, was conducted in South Korea and utilized the EuroQol-5D (EQ-5D) questionnaire.^99^ It found a high DMFT index (≥7) associated with increased likelihood of self-reported problems with mobility (adjusted OR 1.18, p<0.001), usual activity (adjusted OR 1.19, p<0.01), and pain/discomfort (adjusted OR 1.16, p<0.001) domains on the EQ-5D, with no differences in self-care or anxiety/depression. The systematic review found presence of periodontitis (defined as a community periodontal index >3) associated with increased likelihood of self-reported problems with usual activity (adjusted OR 1.19, p<0.001), with no differences in other EQ-5D domains. Another systematic review of 19 observational studies (15 studies on DMFT) in elderly populations (age 75 years and older) conducted in upper-middle income and higher-income countries found an association between higher DMFT scores and worse oral health related quality of life (OHQoL) (15 studies, OR 0.91, 95% CI 0.87 to 0.96, I^2^=99%) and presence of periodontal disease and worse OHQoL (three studies, OR 1.38, 95% CI 1.15 to 1.62, I^2^=2%).^100^ A positive caries history was also associated with worse OHQoL, though the estimate was imprecise (five studies, OR 1.35, 95% CI 0.6 to 2.11, I^2^=82%).^100^ Another systematic review of 11 observational studies in pregnant persons (primarily conducted in low and middle income countries) found an association between higher DMFT and increased likelihood of poor quality of life (four studies, OR 1.40, 95% CI 1.24 to 1.55, I^2^=41.4%).^101^ In this review, periodontal disease was not associated with increased likelihood of poor quality of life (four studies, OR 0.83, 95% CI 0.28 to 1.38, I^2^=72.9%).

Evidence also indicates an association between dental caries and pain. A large survey of adults (mean age 39 years) in Colombia (n=34,843) found presence of dental caries associated with a very large increase in likelihood of dental pain (OR 56.2, 95% CI 49.5 to 63.9).^102^ Other, smaller studies also found an association between dental caries and dental pain, though the magnitude of increased risk was substantially smaller. A cross-sectional study of adult males in the Brazilian army (n=414) found presence of one or more untreated caries associated with increased likelihood of dental pain (adjusted OR 3.2, 95% CI 1.7 to 5.8).^103^ A cross-sectional study of young adults in Mexico (n=638) found an association between DMFT index (OR 1.05, 95% CI 1.01 to 1.09) and number of decayed teeth (OR 1.09, 95% CI 1.02 to 1.16) and presence of dental pain; there was no association between number of filled teeth and presence of dental pain (OR 1.01, 95% CI .97 to 1.0).^104^

Dental caries and periodontal diseases are the most common causes of tooth loss. In U.S. studies (168 extractions, 389 extractions, or 839 patients) the proportion of tooth extractions due to dental caries ranged from 37 to 63 percent and the proportion due to periodontal disease ranged from 29 to 51 percent.^105–107^ A large study conducted in France (14,621 extractions) found dental caries to be the most common reason for tooth extractions overall (49%), followed by periodontal disease (32%).^108^ However, among persons >50 years of age, periodontal disease was the most common reason for extraction. Similar results were reported in a study conducted in Scotland.^109^

### Contextual Question 2 What Factors (e.g., Race/Ethnicity, Age, Socioeconomic Status, Cultural Factors, Educational Attainment, or Health Literacy) Are Associated With Oral Health Care Disparities in Adults?

A number of factors have been associated with oral health care disparities in U.S. adults; these factors likely relate to decreased access to dental care and presence of other negative social determinants of health. Based on National Health and Nutrition Examination Survey (NHANES) 2011 to 2016 data,^21^ the prevalence of untreated tooth decay was highest in persons 20 to 34 years of age (29.3%), non-Hispanic Black persons (40.2% in those 20 to 64 years of age and 29.1% in those >65 years of age), and Mexican American persons (37.1% in those 20 to 64 years of age and 35.9% in those >65 years of age); by comparison, the prevalence of untreated tooth decay in non-Hispanic White persons was 22.2 percent among those 20 to 64 years of age and 13.4 percent among those >65 years of age. There was also an association between older age and higher caries burden (mean DMFT increasing from 6.7 for those 20 to 34 years of age to 17.8 for those ages 75 years and older) and edentulism (1.6% for those 35 to 49 years of age to 22.5% for those 75 years and older). Among persons >65 years of age, the group with the highest prevalence of edentulism was non-Hispanic Black Americans (30.7%); in non-Hispanic White and Mexican Americans the prevalence was 15.2 percent and 16.7 percent, respectively. There was also an association between socioeconomic status and likelihood of edentulism, with higher prevalence among those at less than 100 percent of the Federal poverty level (FPL) or 100 to 199 percent of the FPL (34.1% and 26.1%, respectively) than those at 200 percent or greater of the FPL (10.7%).

Similar factors were associated with disparities in periodontal disease. Based on NHANES 2009 to 2014 data,^78^ periodontitis was present in 42.2 percent of Americans ages 30 years and older (7.8% had severe periodontitis) (Table 3). The prevalence of periodontitis increased with age (29.5% for those age 30 to 44 years, 46.0% for those age 45 to 64 years, and 59.8% for those age 65 years and older), was higher for males than females (50.2% versus 34.6%, respectively), was lower for non-Hispanic White persons (37.0%) compared to those of other races and ethnicities (non-Hispanic Black 56.6%, Mexican American 59.7%, other race including multiracial 46.2%), and increased with lower socioeconomic status (<100% FPL 60.4%, 100 to 199% FPL 53.6%, 200 to 399% FPL 44.6%, >400% FPL 28.6%).

Table 3 NHANES Data for Oral Health

Outcome | Results
Dental Caries; Years 2011–2016^21^ | [underlined: Prevalence of adults ages 20–64 with dental caries]:; By age: 20–34 vs 35–49 vs 50–64: 82.0% vs 92.5%^*^ vs 96.4%^*^; By gender: male vs female: 88.2% vs 91.5%^*^; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 91.5% vs 86.1%^*^ vs 86.6%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 88.0%^*^ vs 89.3% vs 90.2%; [underlined: Prevalence of adults ages >65 years with dental caries]:; By age: 65–74 vs >or=75: 96.4% vs 96.0%; By gender: male vs female: 96.1% vs 96.3%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 98.2% vs 85.7%^*^ vs 85.3%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 88.1%^*^ vs 94.0%^*^ vs 98.2%
Untreated Tooth Decay; Years 2011–2016^21^ | [underlined: Prevalence with untreated tooth decay]:; By age: 20–34 vs 35–49 vs 50–64: 29.3% vs 26.4%^*^ vs 21.5%^*^; By gender: male vs female: 28.0% vs 24.3%^*^; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 22.2% vs 40.2%^*^ vs 37.1%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 45.3%^*^ vs 37.0%^*^ vs 17.7%; [underlined: Prevalence of adults >65 years with untreated tooth decay]:; By age: 65–74 vs >or=75: 15.4% vs 16.5%; By gender: male vs female: 18.0% vs 14.2%^*^; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 13.4% vs 29.1%^*^ vs 35.9%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 33.1%^*^26.9%^*^ vs 9.9%
DMFT; Years 2011–2016^21^ | [underlined: DMFT, mean (SE) of adults ages 20–64]:; By age: 20–34 vs 35–49 vs 50–64: 6.7 (0.12) vs 9.4 (0.15)^*^ vs 12.7 (0.13)^*^; By gender: male vs female: 9.0 (0.12 vs 9.6 (0.11)^*^; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 9.4 (0.13) vs 9.1 (0.17) vs 8.7 (0.20)^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 10.0 (0.17)^*^ vs 9.9 (0.15)^*^ vs 9.0 (0.11); [underlined: DMFT, mean (SE) of adults >65 years]:; By age: 65–74 vs >or=75: 15.9 (0.21) vs 17.8 (0.21)^*^; By gender: male vs female: 16.6 (0.22) vs 16.9 (0.17); By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 16.8 (0.17) vs 16.2 (0.40) vs 14.6 (0.60)^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 16.5 (0.42) vs 17.0 (0.29) vs 16.8 (0.19)
Edentulism; Years 2011–2016^21^ | [underlined: Percentage of adults aged 20–64 years who have lost all their natural teeth]:; By age: 20–34 vs 35–49 vs 50–64: NR vs 1.6% vs 5.6%; By gender: male vs female: 2.2% vs 2.1%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 2.4% vs 2.3% vs 0.7%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 6.1%^*^ vs 3.7%^*^ vs 1.1%; [underlined: Percentage of adults >65 years who have lost all their natural teeth]:; By age: 65–74 vs >or=75: 13.0% vs 22.5%^*^; By gender: male vs female: 17.7% vs 16.9%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 15.2% vs 30.7%^*^ vs 16.7%; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 34.1%^*^ vs 26.1%^*^ vs 10.7%
Periodontitis; Years 2009–2014^78^ | [underlined: Periodontitis]:; Adults ages >or=30 years: 42.2%; By severity: Mild or moderate vs severe periodontitis: 34.4% vs 7.8%; By age: 30–44 vs 45–64 vs >or=65: 29.5% vs 46.0%^†^ vs 59.8%^†^; By gender: male vs female: 50.2%^†^ vs 34.6%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American vs other Hispanic vs other race including multiracial: 37.0% vs 56.6%^†^ vs 59.7%^†^ vs 48.5%^†^ vs 46.2%^‡^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs 200–399% FPL vs >400% FPL: 60.4%^†^ vs 53.6%^†^ vs 44.6%^†^ vs 28.6%

Abbreviations: DMFT = decayed, missing, and filled teeth; FPL = federal poverty level; NR = not reported; SE = standard error.

* p<0.05

† p<0.001

‡ p<0.01.

Evidence on the association between social determinants of health other than socioeconomic status and oral health disparities in adults is limited. A systematic review of 25 observational studies (17 conducted in the U.S.) found no association between oral health literacy and oral health behaviors, oral health perception, or dental treatment outcomes; however, most studies in the review were rated as having a high risk of bias.^110^ A systematic review of 42 observational studies examined the impact of acculturation on oral health among immigrants and ethnic minorities and found a positive association between higher acculturation and better oral health outcomes, oral health behaviors, dental care utilization, and dental knowledge.^111^ The most commonly used indicators of acculturation were language spoken and length of stay in the host country.

### Contextual Question 3 What Is the Effectiveness of Primary Care Interventions to Reduce Oral Health Care Disparities in Adults?

Evidence on the effectiveness of primary care interventions to reduce oral health care disparities in adults was very limited. One U.S. trial found that an oral health education intervention to improve oral health in low-income pregnant women increased likelihood of attending a dental visit, but did not report dental caries or other health outcomes.^112^ No other study evaluated interventions in U.S. primary care settings to reduce oral health care disparities.