# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^79^ the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes reviewed for both screening (Figure 1) and prevention (Figure 2).

Figure 1 Analytic Framework and Key Questions - Screening for Oral Health in Adults Age 18 Years and Older

Key Questions

1. How effective is screening for oral health performed by a primary care clinician in preventing negative oral health outcomes?
2. How accurate is screening for oral health performed by a primary care clinician in identifying adults who:
  a. Have oral health issues?
  b. Are at increased risk for future oral health issues?
3. What are the harms of screening for oral health performed by a primary care clinician?

The analytic framework depicts the relationship between the population, screening, interventions, outcomes, and potential harms of screening for oral health. The far left of the framework shows the target population for screening as adults at least 18 years of age at a clinician office visit. To the right of the population is an arrow corresponding to key question 2, which represents the accuracy of screening and risk factor assessment, identifying those at average or increased risk for oral health issues. This step may lead to harms, which corresponds to key question 3. Arrows show that adults at either risk level with oral health issues may receive interventions, with the aim of decreased dental caries, periodontal disease, and tooth loss, and improved quality of life, functional status, and morbidity. These outcomes are represented in a box at the end of the pathway. An overarching arrow representing key question 1 represents the effect of screening on these outcomes of interest.

Figure 2 Analytic Framework and Key Questions - Interventions to Prevent Oral Health Issues in Adults Age 18 Years and Older

Key Questions

1. How accurate is screening performed by a primary care clinician in identifying adults who are at increased risk of future oral health issues?*
2. How effective is oral health behavioral counseling provided by a primary care clinician in preventing oral health issues?
3. How effective is referral by a primary care clinician to a dental health care provider in preventing oral health issues?
4. How effective are preventive interventions in preventing oral health issues?
5. What are the harms of specific interventions (behavioral counseling, referral, and preventive interventions) to prevent oral health issues?

*This is the same as Key Question 2b from the previous Analytic Framework.

The analytic framework depicts the relationship between the population, preventive interventions, outcomes, and potential harms of interventions to prevent oral health issues. The far left of the framework describes the target population as adults at least 18 years of age at a clinician office visit. To the right of the population is an arrow corresponding to key question 1 which represents accuracy of risk factor assessment, identifying those at average or increased risk for oral health issues. Arrows show that adults at either risk level without oral health issues would receive preventive interventions of behavioral counseling, referral to a dental health care provider, and preventive intervention, representing key questions 2, 3, and 4 respectively, with the aim of decreased dental caries, periodontal disease, and tooth loss, and improved quality of life, functional status, and morbidity. These outcomes are represented in a box at the end of the pathway. Preventive interventions may lead to harms, which are represented by an arrow for key question 5.

### Screening Key Questions

1. How effective is screening for oral health performed by a primary care clinician in preventing negative oral health outcomes?
2. How accurate is screening for oral health performed by a primary care clinician in identifying adults who: a. Have oral health issues? b. Are at increased risk for future oral health issues?
3. What are the harms of screening for oral health performed by a primary care clinician?

### Prevention Key Questions

1. How accurate is screening performed by a primary care clinician in identifying adults who are at increased risk of future oral health issues?*
2. How effective is oral health behavioral counseling provided by a primary care clinician in preventing oral health issues?
3. How effective is referral by a primary care clinician to a dental health care provider in preventing oral health issues?
4. How effective are preventive interventions in preventing oral health issues?
5. What are the harms of specific interventions (behavioral counseling, referral, and preventive interventions) to prevent oral health issues?

*This is the same as Key Question 2b from the screening Key Questions.

### Contextual Questions

Three Contextual Question were also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. What is the association between presence or severity of dental caries in adults and pain, quality of life, function, and tooth loss/edentulism?
2. What factors (e.g., race/ethnicity, age, socioeconomic status, cultural factors, educational attainment, or health literacy) are associated with oral health care disparities in adults?
3. What is the effectiveness of primary care interventions to reduce oral health care disparities in adults?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews, and Ovid MEDLINE from database conception to October 3, 2022 for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles. Ongoing surveillance was conducted to identify major studies published since October 3, 2022 that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on July 21, 2023 and identified no studies affecting review conclusions.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each key question (Appendix A2). Disagreements were resolved by consensus. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists included studies, and Appendix A5 lists excluded studies with reasons for exclusion.

This review addresses screening, risk assessment, and preventive interventions for oral health in adults. Separate Analytic Frameworks address screening for oral health conditions and prevention of oral health conditions, to more clearly distinguish treatment of adults with existing dental caries identified by screening (Screening Analytic Framework) from treatment of those without dental caries to prevent the development of future caries (Prevention Analytic Framework).

For both Analytic Frameworks, the population was asymptomatic adults (≥18 years of age), including pregnant persons. Groups of interest were defined by age (<65 vs. ≥65 years), sex, gender, socioeconomic status, race/ethnicity, educational attainment, and health literacy. Studies that selected patients based on presence of caries were ineligible; however, given the very high prevalence of caries in U.S. adults, we did not exclude studies based on high baseline mean caries prevalence, if patients were not required to have caries to be enrolled. Screening interventions were oral examination or clinical assessment by a primary care provider, or risk assessment for dental caries or periodontal disease using a standardized risk assessment instrument. Risk assessment instruments that utilized findings from a dental professional oral exam or that utilized tests not commonly utilized in primary care (dental x-rays, salivary flow rates, levels of cariogenic bacteria) were excluded. Preventive interventions were oral health behavioral counseling, preventive medications (topical fluoride [varnish, foam, or gel], SDF topical solution, dental sealants, or xylitol), or referral of persons deemed at high risk for oral disease by a primary care provider to a dental professional. Comparisons were against placebo or no screening/treatment/referral. Dental X-rays were not addressed because they are not typically obtained in primary care settings or ordered by primary care clinicians. Outcomes were presence of and severity of caries (likelihood of developing caries [dichotomous outcome] or caries burden [continuous outcome, often measured based on the number of decayed, missing, or filled teeth [DMFT index] or surfaces [DMFS index]; the capital letters indicate permanent teeth or tooth surfaces), presence and severity of periodontal disease, morbidity, quality of life, functional status, and harms of screening and treatment. Settings were primary care or primary care applicable; the preventive interventions selected for review were assessed as potentially primary care feasible (defined as not requiring extensive training to administer); studies of such interventions were considered potentially primary care applicable even if the intervention was administered in a dental care setting or by a dental health professional. Randomized trials were included for screening and preventive interventions; we also included cohort studies of screening and large cohort studies for dental fluorosis and studies on diagnostic accuracy of oral examination/clinical assessment and risk assessment instruments. In accordance with USPSTF procedures,^79^ poor quality studies were excluded unless higher quality evidence was unavailable.

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we created data abstraction forms to summarize characteristics of study populations, interventions (including the specific drug, formulation or material used; dose; frequency; duration; and professional background or training of persons administering the intervention), comparators, outcomes, study designs, settings (including clinical setting, geographic status, and fluoridation status, if available), and methods. One investigator conducted data abstraction, which was reviewed for completeness and accuracy by another team member.

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies by using criteria developed by the USPSTF; studies were rated as “good,” “fair,” or “poor” per USPSTF criteria, depending on the seriousness of the methodological shortcomings (Appendix A6).^79^ For each study, quality assessment was performed by two team members. Disagreements were resolved by consensus.

## Data Synthesis

For all Key Questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^79^ Evidence was rated “good”, “fair”, or “poor” based on study quality, consistency of results between studies, precision of estimates, study limitations, risk of reporting bias, and applicability.^79^

For diagnostic accuracy, a bivariate mixed-effects binary regression model with xtmelogit in Stata 14.2 was used to summarize sensitivity and specificity of screening tests for simultaneously identifying those with periodontitis, severe periodontitis and caries from those without periodontitis, severe periodontitis and caries. This model produced summary values for sensitivity and specificity with corresponding 95 percent confidence intervals (CIs) and required at least four studies to pool. Meta-analyses were limited to studies that screened with a self-reported questionnaire on dental health due to sparse evidence for other forms of screening. The bivariate mixed-effects model was also used to create summary area under the receiver operator characteristic (AUROCs) curves with 95 percent CIs for both confidence and prediction contours using hierarchical methods. Statistical heterogeneity was assessed using the I^2^, which does not depend on the number of the studies in the meta-analysis. However, due to few studies available for diagnostic accuracy meta-analyses, statistical heterogeneity was explored qualitatively.

Meta-analysis was not conducted for preventive interventions, due to small numbers of studies and methodological limitations in the available studies.

## USPSTF and AHRQ Involvement

The authors worked with USPSTF members at key points throughout the review process to develop and refine the Analytic Frameworks and Key Questions and to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated the systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.

## Expert Review and Public Comment

We obtained input to inform the draft work plan from Key Informants to identify important subpopulations and inform the development of the scope and Key Questions. In addition, the draft Research Plan was posted on the USPSTF website for public comment from March 18, 2021, to April 14, 2021. In response, the USPSTF revised the inclusion criteria to clarify that screening is performed by a primary care provider and that preventive interventions are administered by a primary care provider or are feasible to be administered by a primary care provider. The USPSTF made no other changes.

The draft report was reviewed by content experts and collaborative partners (Appendix A7) and minor clarifications were made to the report. The report was also posted for public comment from May 23, 2023 to June 20, 2023; no public comments were received.