# Chapter 1 Introduction and Background

## Purpose

Screening, referral, behavioral counseling, and preventive interventions for oral health in adults is a new topic for the U.S. Preventive Services Task Force (USPSTF). However, the USPSTF previously addressed the related topics of counseling to prevent dental and periodontal disease (1996),^1^ screening and prevention of dental caries in children younger than 5 years of age (2021),^2^ and oral cancer screening (2013);^3^ a concurrent topic addresses oral health screening and preventive interventions in children and adolescents 5 to 17 years of age.

In 1996, the USPSTF issued several recommendations relevant to adults on counseling to prevent dental and periodontal disease (note: the grading system used for the 1996 recommendations differed from current USPSTF definitions and are defined below).^1^ The USPSTF recommended counseling patients to visit a dental care provider on a regular basis, floss daily, brush their teeth daily with a fluoride-containing toothpaste, and appropriately use fluoride for caries prevention and chemotherapeutic mouth rinses for plaque prevention (“B” recommendation [“fair evidence to support the recommendation that the condition be specifically considered in a periodic health examination”]). However, the USPSTF found that effectiveness of clinician counseling to change any of these behaviors had not been adequately evaluated (“C” recommendation [“insufficient evidence to recommend for or against the inclusion of the condition in a periodic health examination”]). Additionally, the USPSTF suggested that clinicians examine the oral cavity and be alert for obvious signs of oral disease (ungraded statement); screening for oral cancer was addressed separately (“C” [insufficient] recommendation in 1996; most recently, in 2013, the USPSTF issued an I [insufficient] statement on oral cancer screening).^3^

In 2006, the USPSTF inactivated the topic of counseling to prevent dental and periodontal disease, based on the lack of new evidence on the role of the primary care clinician in counseling for dental services to inform updated recommendations. In 2016, the USPSTF received a nomination on the topic of risks and benefits of dental x-rays for screening; oral health was selected as a topic for further refinement. Through the topic refinement process, the scope was broadened to address screening, referral, behavioral counseling, and preventive interventions for oral health conditions (dental caries and periodontal disease) in adults. Given current interest in primary care and oral health,^4–6^ evidence of gaps in provision of oral health services,^7^ and potential new evidence to inform recommendations, the USPSTF commissioned a systematic review to address oral health in adults. For this topic, screening was defined as risk assessment or oral cavity examination; dental x-rays were excluded during topic refinement because of limited relevance to primary care. The new oral health topic was scoped to not overlap with currently active related topics (dental caries in children from birth to age 5 years^8^ and oral cancer screening^9^); a concurrent systematic review was commissioned on screening and preventive services for oral health in children.^10^ This review will be used by the USPSTF to inform the development of new recommendations on screening and prevention for oral health in adults.

## Condition Background

### Condition Definition

In 2000, the U.S. Surgeon General published the first Oral Health in America report,^11^ which emphasized that “oral health means much more than healthy teeth. It means being free of chronic oral-facial pain conditions, oral and pharyngeal (throat) cancers, oral soft tissue lesions, birth defects such as cleft lip and palate, and scores of other diseases and disorders that affect the oral, dental, and craniofacial tissues, collectively known as the craniofacial complex.” An Oral Health in America follow-up report from the National Institutes of Health was published in 2021.^7^ It noted that “…in adulthood, the relationship between oral health and overall health becomes much more apparent and manifests in a variety of ways.” The 2021 report noted a lack of progress in improving oral health in adults: “Overall, U.S. adults’ oral health has not improved—and in some respects has worsened—since publication of the 2000 Surgeon General’s report on oral health.” In adults, common oral health conditions include dental caries, periodontal (gum) disease, and oral cancer.^12,13^ This report focuses on dental caries and periodontal disease. As previously noted, oral cancer screening is covered as a separate USPSTF topic;^3^ other topics that may impact oral health (e.g., tobacco smoking cessation,^14^ unhealthy alcohol use,^15^ healthy diet^16^) are also addressed elsewhere by the USPSTF, although recommendations do not specifically address impacts on oral health. Oral health conditions that are associated with symptoms (e.g., orofacial pain or temporomandibular joint disorders) and treatment of existing oral health conditions or management of oral health conditions that may occur due to other treatments or medications are outside the scope of the USPSTF.

### Prevalence and Burden of Disease/IIIness

Dental caries and gum disease, the most common oral health conditions in adults, can lead to pain, disability, and decreased wellbeing for millions of Americans.^12,17–19^ In addition, infections and tooth loss may lead to problems with eating and speaking and negatively impact quality of life and social interactions.^20^ Caries is common in adulthood, with over 90 percent of adults affected;^7,21^ according to the Global Burden of Disease Study, untreated dental caries is the most common health condition worldwide.^22^ The prevalence of oral health conditions increases with age. In 2011 to 2014, the overall prevalence of caries among persons 20 to 64 years of age was estimated at 92 percent; the prevalence increased from 82 percent among those 20 to 34 years of age to 97 percent among those 50 to 64 years of age.^7^ In 2015 to 2018, the prevalence of untreated caries was estimated at 25.9 percent in persons 20 to 44 years of age.^23^ Although the overall prevalence of oral health conditions increases with age, the prevalence of untreated oral health conditions is lower in older adults, due to better access to dental care or other factors. Based on 2011 to 2016 data, the prevalence of untreated caries was 15 percent among those 65 to 74 years of age and 17 percent among those 75 years of age or older.^7^ Over 40 percent of U.S. adults have some form of periodontal disease, with at least 60 percent of adults age 65 years and older having this condition.^21,24^ Although the prevalence of complete tooth loss (edentulism) has declined,^7,21^ the prevalence of edentulism in 2011 to 2012 was 26 percent in adults 75 years of age or older and 13 percent in those 65 to 74 years of age (in 1960 to 1962, the proportion of persons 65 to 74 years of age with edentulism was 59 percent).^7,25^ In addition to pain and wellbeing, untreated dental caries and gum disease have been associated with other health problems, including diabetes, and heart disease.^7,11,20,26–28^

### Etiology and Natural History

Dental caries is a multifactorial disease process that occurs when various strains of bacteria colonize the tooth surface and metabolize dietary carbohydrates (especially refined sugars) to produce lactic and other acids, resulting in demineralization of teeth.^29,30^ Dental caries first manifests as white spot lesions, which are small areas of demineralization under the enamel surface. At this stage, the caries lesion is usually reversible, if appropriate preventive action is taken (e.g., change in dietary behaviors or application of fluoride varnish). If oral health conditions do not improve, demineralization progresses, and eventually results in irreversible cavities, with a loss of the normal tooth shape and contour. Continued progression of the caries process leads to pulpitis and tooth loss, and can be associated with complications such as facial cellulitis and systemic infections.^30,31^

Periodontitis refers to inflammation of the gingival tissues. Gradual build-up of dental plaque (consisting of colonies of mixed oral bacteria) on the teeth at the margin of the gums may induce gingival inflammation and bleeding, which usually precedes development of periodontitis.^32^ Left untreated, periodontitis can progress to destroy the tissues that support the teeth (the bone and periodontal ligaments) and cause the gums to pull away from the teeth, leading to exposure of tooth roots. Exposed tooth roots can cause sensitivity or pain and are more susceptible to caries (root caries). Severe periodontitis is the leading cause of tooth loss in older adults.^33^

### Risk Factors

Risk factors for dental caries and periodontal disease include poor oral hygiene, tobacco use, excessive alcohol use, methamphetamine use, and inappropriate dietary practices, and may be influenced by genetics. As discussed earlier, older age is also associated with increased risk of poor oral health.^7,34,35^ Certain conditions (e.g., diabetes), comorbidities (e.g., xerostomia), and medications (e.g., those that cause xerostomia) also increase risk of dental caries and periodontal disease.^36–38^

### Rationale for Screening/Screening Strategies

Oral health issues in adults are common, are often untreated, and can lead to tooth loss or irreversible damage and other adverse health outcomes. Patients may be asymptomatic or be aware of their condition but not seek treatment because oral health conditions can progress slowly over time. In addition, patients may have inadequate access to dental services due to insurance status or other socioeconomic factors, or not utilize dental services for other reasons.^39^ In 2015, approximately 40 percent of adults aged 21 to 64 years reported having a dental visit in the last year.^7^ For patients who lack access to dental services, oral health screening and preventive interventions for dental caries and periodontal disease, the most common oral health conditions in adults, could potentially be provided in primary care settings. Therefore, identifying and treating oral health issues early in primary care could help prevent adverse health outcomes.

Screening for oral health conditions and provision of interventions for oral health in primary care also provide an opportunity to potentially reduce observed disparities related to race/ethnicity, socioeconomic status, or other factors (see subsequent section on Disparities).^40,41^ In most communities, dental care is the most common unmet health need.^42^ Screening in primary care would reach patients who do not have access to dental care; 35 percent of the population (108 million people) who see a doctor, do not see a dentist.^43^ Forty percent of the population lacks dental insurance and a similar proportion do not have an annual visit with a dentist.^44,45^ Forty-five million Americans live in areas with a shortage of dental health professionals (defined as >5,000 persons per dentist).^44^

### Interventions/Treatment

Screening for oral health conditions may include risk assessment, health history, visual/tactile examination, and imaging (dental x-rays)^46^ to identify persons with early untreated dental caries or periodontal disease, or those at high risk for developing these conditions. Interventions to prevent development of caries focus on reducing the burden of bacteria, reducing the intake of refined sugars, and increasing the resistance of teeth to caries development.^29,47^ Counseling interventions include those that address oral hygiene (e.g., brushing twice daily with fluoride toothpaste, flossing daily), diet, tobacco use, or alcohol use, as well as counseling to visit a dentist. Preventive interventions include fluoride, dental sealants, varnish, xylitol, medication adjustment (e.g., to reduce dry mouth), and referral to a dentist.

Use of fluorides primarily focuses on promoting remineralization of the enamel. Fluoride can be topical (fluoride dentifrices, rinses, gels, foams, varnishes) or systemic (dietary fluoride supplements).^29,47^ Fluoride is incorporated into the biofilm (dental plaque), saliva and tooth enamel and increases tooth resistance to acid decay, acts as a reservoir for remineralization of caries lesions, and inhibits cariogenic bacteria.^29,31^ A potential harm of excessive systemic fluoride exposure is enamel fluorosis, a visible change in enamel opacity due to altered mineralization during teeth formation. The severity of enamel fluorosis depends on the dose, duration and timing of fluoride intake, and is most strongly associated with cumulative intake during enamel development in early childhood; children are most susceptible between 15 to 30 months of age.^48,49^ Mild fluorosis manifests as small opaque white streaks or specks in the tooth enamel.^50^ Severe fluorosis results in discoloration and pitted or rough enamel.^31^ In 1999 to 2004, the prevalence of severe enamel fluorosis in the United States was estimated at less than 1 percent.^50,51^

Topical fluoride is typically applied as a varnish with a small brush (more commonly used in younger children) or as a gel or foam (more commonly used in older, school-aged children).^52^ Fluoride varnish application does not require specialized dental devices or equipment and can be applied quickly by both dental professionals and non-dental health professionals in a variety of settings; topical gels and foams typically require special suction. Systemic exposure to fluoride is lower following application of fluoride varnish compared to a gel or foam because smaller amounts are swallowed.^29,52–54^ Fluoride varnish results in prolonged contact time between the fluoride and the tooth surface, which maintains a higher level of the calcium fluoride in the biofilm; later the released fluoride promotes remineralization. Fluoride varnish is typically available in the United States as 5 percent sodium fluoride (2.26% F). Fluoride varnish is cleared for marketing by the U.S. Food and Drug Administration (FDA) as a cavity liner and tooth desensitizer; its use for prevention of caries is off-label.^55^ Fluoride gel is typically available as sodium fluoride and acidulated phosphate fluoride.

Silver diamine fluoride (SDF) is a topical solution that is noninvasive, relatively inexpensive, and easy to apply.^56^ Its mechanism of action is related to the antibacterial properties of silver in addition to the effects of fluoride. The most common concentration is 38 percent, though it has been evaluated in 10 to 38 percent formulations. SDF was cleared for marketing by the FDA in 2014 as a desensitizing agent in adults, similar to fluoride varnish 20 years earlier^57^; it has long been used outside the United States to arrest progression of existing caries lesions and avoid the need for restorative treatment. SDF works by the combined effects of silver and fluoride on promoting remineralization, as a short-term germicide, and by inhibiting enzymes involved in collagen degradation, all of which result in an arrest of the carious process;^56,58^ SDF is also being evaluated for preventing future caries.^59^ A potential disadvantage of SDF is cosmetic concern due to the permanent dark discoloration of active caries lesions by the silver component. However, SDF will not discolor healthy enamel, and caries lesions themselves may be discolored. Based on its potential as a caries treatment, SDF has been granted “breakthrough therapy” designation by the FDA, providing the opportunity for expedited approval for this indication, and a number of clinical trials of SDF for treating or preventing caries are in progress.

Xylitol is a naturally occurring sugar alcohol that cannot be metabolized by the oral microflora and thus has the potential to reduce levels of caries-forming mutans streptococci in the plaque and saliva.^60^ Xylitol can be administered topically (e.g., wipes) or via gum, lozenges, or snack foods. FDA allows foods (including chewing gums) that contain xylitol to make the following statement: “Xylitol may reduce the risk of tooth decay.”^61^ Other topical antimicrobials such as chlorhexidine varnish or gel and povidone-iodine rinses are not commonly used in the United States. Neither chlorhexidine nor povidone iodine has been approved by FDA for caries reduction or prevention.

Dental sealants are a thin coating applied to the chewing and other surfaces of the premolars and molars, providing a physical barrier with the ability to prevent cavities over a prolonged period of time. A variety of sealant materials are available, though the main materials are resins/composites and glass ionomers. Sealants are applied as a paste; following application sealants can be activated (cured) using light or chemicals; resulting in polymerization of the sealant material and hardening on the tooth surface (some sealants are autopolymerized [not requiring light or chemicals]). Resin-based sealants are classified into four generations, based on the method of polymerizations. First generation sealants utilized ultraviolet light for polymerization and are no longer used; second generation sealants are auto-polymerizing or chemically cured; third generation sealants are activated using visible light; and fourth generation sealants contain fluoride-releasing particles.^62^ Glass ionomer sealants contain fluoride and can be classified as low or high viscosity; high viscosity sealants may have better retention on the tooth. Dental sealants are typically applied by dental health professionals in their office or in community settings such as schools.^63^ Other interventions typically performed by dental health professionals to prevent dental caries or periodontal disease or to treat disease identified on screening which are considered beyond the scope of primary care practice include teeth cleaning, plaque removal, and treatments for caries (fillings, crowns, root canals, tooth extractions) and periodontal disease (surgery and grafts).

A potential barrier to provision of oral health services in primary care settings is unfamiliarity with interventions, need for additional training or equipment (e.g., fluoride varnish, dental sealants, or silver diamine fluoride), and non-reimbursement; in addition, there are barriers to dental referrals from primary care.^64^ However, some data in non-adult populations suggest that increased provision of an oral health intervention (fluoride varnish) in non-adult (children younger than 5 years of age) primary care settings is feasible.^65,66^ For some interventions, state laws or regulations currently restrict administration to certain dental professionals (e.g., dental sealants can be placed by dentists, dental hygienists, and dental assistants [in certain states]), though such regulations do not apply to medical professionals.

### Current Clinical Practice/Recommendations of Other Groups

The 2000 U.S. Surgeon General’s report, Oral Health in America,^11^ and 2021 update^7^ highlight the importance of integrating oral health into primary care medical settings, primarily focusing on counseling, coordination, and referral. Reports from the Institute of Medicine in 2011 (Advancing Oral Health in America,^67^ and Improving Access to Oral Health Care for Vulnerable and Underserved Populations^68^) and from the Health Resources and Services Administration in 2014 (Integration of Oral Health and Primary Care Practice^69^), also emphasized the importance of integrating oral health services in primary care medicine.

In 2013, the American Dental Association (ADA) recommended professionally applied 2.26 percent fluoride varnish or 1.23 percent fluoride (acidulated phosphate fluoride) gel in adults at elevated risk of developing caries, based on expert opinion.^70^ In 2018, the American Academy of Family Physicians (AAFP) recommended physician education in oral condition screening and management, as well as the consequences of poor oral hygiene on overall health.^71^ The AAFP also encouraged collaboration of family physicians with dental health practitioners to provide comprehensive medical care. The AAFP did not provide recommendations on specific oral health preventive interventions. In 2013, the American College of Obstetricians and Gynecologists (ACOG) recommended that women be routinely counseled about maintaining good oral health habits throughout their lives as well as the safety and importance of oral health care during pregnancy.^72^ Other groups, such as Smiles for Life and Qualis Health, have also issued educational resources and recommendations on provision of oral health services in primary medical care settings.^44,73^

### Disparities

Oral health disparities have been described with regard to race/ethnicity (Black, Hispanic, American Indian, and Alaska Native persons are disproportionately impacted), socioeconomic status,^74^ insurance status, health literacy,^75^ immigration status,^76^ and educational level.^21,77^ Populations with higher prevalence of dental caries and periodontal disease include pregnant persons, people with special needs, older adults, individuals living in rural and urban underserved areas, individuals without insurance, individuals with public insurance, and individuals experiencing homelessness.^68^ In 2011 to 2016, the prevalence of untreated dental caries among adults 20 to 64 years of age was approximately 28 percent in men and 24 percent in women, and 45 percent among those at less than 100 percent below the federal poverty threshold and 18 percent among those at greater than or equal to 200 percent of the federal poverty threshold.^21^ The percentage of untreated dental caries among adults 20 to 64 years of age was approximately 22 percent in non-Hispanic White persons, compared with 40 percent in non-Hispanic Black persons and 37 percent among Mexican Americans. Periodontal disease is also more common in men than women (50% vs 35%), persons living below the federal poverty level (60%), and current smokers (62%).^78^ (Additional details on oral health disparities are discussed in Contextual Question 2.)