# Appendix B Evidence Tables and Quality Tables

Appendix B Table 1 Data Abstraction of Screening Trial

Appendix B Table 2 Quality Assessment of Screening Trial

Appendix B Table 3 Data Abstraction of Diagnostic Accuracy Studies

Appendix B Table 4 Quality Assessment of Diagnostic Accuracy Studies

Appendix B Table 5 Data Abstraction of Topical Fluoride Trials

Appendix B Table 6 Quality Assessment of Topical Fluoride Trials

Appendix B Table 7 Data Abstraction of Sealant Trial

Appendix B Table 8 Quality Assessment of Sealant Trials

Appendix B Table 9 Data Abstraction of Silver Diamine Fluoride Trials

Appendix B Table 10 Quality Assessment of Silver Diamine Fluoride Trials