# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Overall

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti.
2 limit 1 to full systematic reviews
3 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti.
4 2 and 3
5 2 not 4

### Screening

#### Database: Ovid MEDLINE(R) ALL (Systematic Reviews)

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Mass Screening/
8 screen*.ti,ab,kf.
9 Risk Assessment/
10 Risk Factors/
11 risk.ti,ab,kf.
12 or/7–11
13 6 and 12
14 limit 13 to (meta analysis or "systematic review")
15 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
16 14 and 15
17 limit 16 to english language
18 14 not 15
19 limit 18 to english language

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab.
6 or/1–5
7 Mass Screening
8 screen*.ti,ab.
9 Risk Assessment/
10 Risk Factors/
11 risk.ti,ab.
12 or/7–11
13 6 and 12
14 conference abstract.pt.
15 "journal: conference abstract".pt.
16 "journal: conference review".pt.
17 "http://www.who.int/trialsearch*".so.
18 "https://clinicaltrials.gov*".so.
19 14 or 15 or 16 or 17 or 18
20 13 not 19
21 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,sh.
22 20 and 21
23 20 not 22

#### Database: Ovid MEDLINE(R) ALL

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Mass Screening/
8 screen*.ti,ab,kf.
9 Risk Assessment/
10 Risk Factors/
11 risk.ti,ab,kf.
12 or/7–11
13 Primary Health Care/
14 ("primary care" or "general practic*" or "family medicine" or "family practic*").ti,ab,kf.
15 13 or 14
16 6 and 12 and 15
17 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
18 16 and 17
19 16 not 18

#### Database: Ovid MEDLINE(R) ALL

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Mass Screening/
8 screen*.ti,ab,kf.
9 Risk Assessment/
10 Risk Factors/
11 risk.ti,ab,kf.
12 or/7–11
13 6 and 12
14 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
15 13 not 14
16 exp "Sensitivity and Specificity"/
17 (diagnos* adj2 accura*).ti,ab,kf.
18 16 or 17
19 15 and 18
20 limit 15 to randomized controlled trial
21 (random* or control* or trial or cohort).ti,ab.
22 15 and 21
23 19 or 20 or 22

### Interventions

#### Database: Ovid MEDLINE(R) ALL

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Counseling/
8 health education/ or health education, dental/ or health promotion/ or patient education as topic/
9 exp Cariostatic Agents/
10 "Pit and Fissure Sealants"/
11 exp Dentifrices/
12 Xylitol/
13 "Referral and Consultation"/
14 (counsel* or education or fluoride or "silver diamine" or sealant* or xylitol or referral).ti,ab,kf.
15 or/7–14
16 6 and 15
17 limit 16 to (meta analysis or "systematic review")
18 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
19 17 and 18
20 17 not 19
21 limit 20 to english language

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab.
6 or/1–5
7 Counseling/
8 health education/ or health education, dental/ or health promotion/ or patient education as topic/
9 exp Cariostatic Agents/
10 "Pit and Fissure Sealants"/
11 exp Dentifrices/
12 Xylitol/
13 "Referral and Consultation"/
14 (counsel* or education or fluoride or "silver diamine" or sealant* or xylitol or referral).ti,ab.
15 or/7–14
16 6 and 15
17 limit 16 to english language
18 conference abstract.pt.
19 "journal: conference abstract".pt.
20 "journal: conference review".pt.
21 "http://www.who.int/trialsearch*".so.
22 "https://clinicaltrials.gov*".so.
23 18 or 19 or 20 or 21 or 22
24 17 not 23
25 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,sh.
26 24 and 25
27 24 not 26

#### Database: Ovid MEDLINE(R) ALL

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Counseling/
8 health education/ or health education, dental/ or health promotion/ or patient education as topic/
9 exp Cariostatic Agents/
10 "Pit and Fissure Sealants"/
11 exp Dentifrices/
12 Xylitol/
13 "Referral and Consultation"/
14 (counsel* or education or fluoride or "silver diamine" or sealant* or xylitol or referral).ti,ab,kf.
15 or/7–14
16 Primary Health Care/
17 ("primary care" or "general practic*" or "family medicine" or "family practic*").ti,ab,kf.
18 16 or 17
19 6 and 15 and 18
20 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
21 19 and 20
22 19 not 21
23 limit 22 to english language

Database: Ovid MEDLINE(R) ALL

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Counseling/
8 health education/ or health education, dental/ or health promotion/ or patient education as topic/ (220967)
9 exp Cariostatic Agents/
10 "Pit and Fissure Sealants"/
11 exp Dentifrices/
12 Xylitol/
13 "Referral and Consultation"/
14 (counsel* or education or fluoride or "silver diamine" or sealant* or xylitol or referral).ti,ab,kf.
15 or/7–14
16 6 and 15
17 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
18 16 not 17
19 limit 18 to randomized controlled trial
20 (random* or control* or trial or cohort).ti,ab,kf.
21 18 and 20
22 19 or 21

## Appendix A2 Inclusion and Exclusion Criteria

Category | Included | Excluded
Populations | Asymptomatic adults, including pregnant persons; Populations of interest were groups defined by: age (<65 vs. ≥65 years), sex, gender, socioeconomic status, race/ethnicity, educational attainment, and health literacy | Children and adolescents less than 18 years (addressed in separate USPSTF recommendations)
Interventions | Screening:; - Oral examination/clinical assessment by a primary care provider; - Risk assessment by a primary care provider for dental caries or periodontitis based on history, examination, standardized risk-assessment instrument, or some combination thereof; Preventive interventions:; - Behavioral counseling/education by a primary care provider; - Preventive medications (topical fluoride [varnish, foam, or gel], silver diamine fluoride, dental sealants, and xylitol-containing products) that are feasible to be administered by a primary care provider; - Referral of persons deemed at high risk for oral diseases by a primary care provider to a dental care health provider | Treatment for existing oral health issues
Comparisons | No intervention or placebo | Active treatment
Outcomes | Dental caries (incidence and severity); Periodontal disease in adults (incidence and severity); Tooth loss; Morbidity; Quality of life; Functional status; Harms of screening and treatment (e.g., dental fluorosis, tooth staining, bone effects, and neurological effects) | Cost effectiveness
Setting | Primary care or applicable to U.S. primary care practice (e.g., screening or preventive interventions do not require specialized dental training or equipment and are feasible for implementation in primary care); includes tele-dentistry approaches based in primary care settings | Dental clinics providing interventions not available in primary care settings
Study Design | Screening: Trials and cohort studies; Preventive interventions: Trials; large cohort studies for selected harms (e.g., dental fluorosis); Risk assessment: Studies of diagnostic accuracy or risk prediction | Case-control studies or uncontrolled studies
Study Quality | Good or fair quality | Poor quality

## Appendix A3 Literature Flow Diagram

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The figure shows that 16,177 citations were identified through literature database searches and other sources. Three hundred and twelve articles were reviewed at the full-text level after excluding 15,865 citations based on review of titles and abstracts. Two hundred and ninety-five full-text articles were excluded for the following reasons: Ineligible intervention: 110, Not a study: 48, Ineligible outcome: 36 , Publication used as source document to identify studies: 32, Ineligible population: 21, Ineligible study design: 20, Ineligible comparison: 17, Study not in English language: 3, Results not usable: 3, Ineligible screener: 2, Irretrievable: 2, Poor quality: 1. Sixteen studies (in 17 publications) were included that provided evidence for the KQs. For the Screening framework, 1 study was included for KQ1 on screening effectiveness, and 7 studies were included for KQ2a on diagnostic accuracy for those with existing oral health issues. There were no studies included for KQs 2b or 3. For the Prevention framework, for KQ4 on Preventive Interventions, the following studies were included: Topical Fluorides: 5 trials, Sealants: 2 trials, SDF: 3 trials, Xylitol: 0 trials. For KQ5 on Harms of Preventive Interventions, 1 trial was included. There were no studies included for KQs 1, 2, or 3.

## Appendix A4 List of Included Studies

1 Carter WJ, Jay P, Shklair IL, The effect of topical fluoride on dental caries experience in adult females of a military population. J Dent Res. 1955 Feb;34(1):73–6. doi: 10.1177/00220345550340011801. PMID: 13233389.13233389
2 Deng K, Pelekos G, Jin L, Diagnostic accuracy of self-reported measures of periodontal disease: A clinical validation study using the 2017 case definitions. J Clin Periodontol. 2021 08;48(8):1037–50. doi: 10.1111/jcpe.13484. PMID: 33998009.33998009
3 Dietrich T, Stosch U, Dietrich D, Prediction of periodontal disease from multiple self-reported items in a German practice-based sample. J Periodontol. 2007 Jul;78(7 Suppl):1421–8. doi: 10.1902/jop.2007.060212. PMID: 17608613.17608613
4 Eden GT. Clinical evaluation of a pit and fissure sealant for young adults. J Prosthet Dent. 1976 Jul;36(1):51–7. doi: 10.1016/0022–3913(76)90233-x. PMID: 1067415.1067415
5 George A, Dahlen HG, Blinkhorn A, Evaluation of a midwifery initiated oral health-dental service program to improve oral health and birth outcomes for pregnant women: a multi-centre randomised controlled trial. Int J Nurs Stud. 2018;82:49–57. doi: 10.1016/j.ijnurstu.2018.03.006. PMID: 29605753.29605753
6 George A, Dahlen HG, Blinkhorn A, Measuring oral health during pregnancy: sensitivity and specificity of a maternal oral screening (MOS) tool. BMC Pregnancy Childbirth. 2017;16(347) PMID: 27829388.27829388
7 Jabir E, McGrade C, Quinn G, Evaluating the effectiveness of fluoride varnish in preventing caries amongst Long-Term Care Facility Residents. Gerodontology. 2021 May 24;24:24. doi: 10.1111/ger.12563. PMID: 34028089.34028089
8 Li R, Lo EC M, Liu BY, Randomized Clinical Trial on Preventing Root Caries among Community-Dwelling Elders. JDR Clin Trans Res. 2017 Jan;2(1):66–72. doi: 10.1177/2380084416668491. PMID: 30938645.30938645
9 Nijland N, Overtoom F, Gerdes VE A, External validation of a rapid, non-invasive tool for periodontitis screening in a medical care setting. Clin Oral Investig. 2021 May 12;12:12. doi: 10.1007/s00784–021-03952–2. PMID: 33978832.33978832
10 Obersztyn A, Kolwinski K, Trykowski J, Effects of stannous fluoride and amine fluorides on caries incidence and enamel solubility in adults. Aust Dent J. 1979 Dec;24(6):395–7. doi: 10.1111/j.1834–7819.1979.tb03633.x. PMID: 295205.295205
11 Sekundo C, Bolk T, Kalmus O, Accuracy of a 7-Item Patient-Reported Stand-Alone Tool for Periodontitis Screening. J Clin Med. 2021 Jan 14;10(2):14. doi: 10.3390/jcm10020287. PMID: 33466797.33466797
12 Tan HP, Lo EC, Dyson JE, A randomized trial on root caries prevention in elders. J Dent Res. 2010;89(10):1086–90. doi: 10.1177/0022034510375825. PMID: 20671206.20671206
13 Verhulst MJ L, Teeuw WJ, Bizzarro S, A rapid, non-invasive tool for periodontitis screening in a medical care setting. BMC Oral Health. 2019 05 23;19(1):87. doi: 10.1186/s12903–019-0784–7. PMID: 31122214.31122214
14 Wallace MC, Retief DH, Bradley EL. The 48-month increment of root caries in an urban population of older adults participating in a preventive dental program. J Public Health Dent. 1993;53(3):133–7. doi: 10.1111/j.1752–7325.1993.tb02691.x. PMID: 8371190.8371190
15 Westman EC, Duffy MB, Simel DL. Should physicians screen for oral disease? A physical examination study of the oral cavity. J Gen Intern Med. 1994 Oct;9(10):558–62. doi: 10.1007/BF02599281. PMID: 7823227.7823227
16 Yildiz E, Dorter C, Efes B, A comparative study of two fissure sealants: a 2-year clinical follow-up. J Oral Rehabil. 2004 Oct;31(10):979–84. doi: 10.1111/j.1365–2842.2004.01334.x. PMID: 15387838.15387838
17 Zhang W, McGrath C, Lo EC, Silver diamine fluoride and education to prevent and arrest root caries among community-dwelling elders. Caries Res. 2013;47(4):284–90. doi: 10.1159/000346620. PMID: 23392087.23392087

## Appendix A5 List of Excluded Studies

1 Alsarraf AH, Kujan O, Farah CS. The utility of oral brush cytology in the early detection of oral cancer and oral potentially malignant disorders: A systematic review. J Oral Pathol Med. 2018 Feb;47(2):104–16. doi: 10.1111/jop.12660. PMID: 29130527. Exclusion reason: Ineligible outcome29130527
2 Ab Malik N, Zhang J, Lam OL, Effectiveness of computer-aided learning in oral health among patients and caregivers: a systematic review. J Am Med Inform Assoc. 2017 01;24(1):209–17. doi: 10.1093/jamia/ocw045. PMID: 27274013. Exclusion reason: Used as source document27274013
3 Adel-Khattab D, Montero E, Herrera D, Evaluation of the FDI Chairside Guide for Assessment of Periodontal Conditions: A Multicentre Observational Study. Int Dent J. 2021 Oct;71(5):390–8. doi: 10.1016/j.identj.2020.12.024. PMID: 33531146. Exclusion reason: Ineligible intervention33531146
4 Akuno MH, Nocella G, Milia EP, Factors influencing the relationship between fluoride in drinking water and dental fluorosis: a ten-year systematic review and meta-analysis. J Water Health. 2019 Dec;17(6):845–62. doi: 10.2166/wh.2019.300. PMID: 31850893. Exclusion reason: Ineligible intervention31850893
5 Al Khamis S, Asimakopoulou K, Newton T, The effect of dental health education on pregnant women's adherence with toothbrushing and flossing - A randomized control trial. Community Dent Oral Epidemiol. 2017;45(5):469–77. doi: 10.1111/cdoe.12311. PMID: 28612363. Exclusion reason: Ineligible intervention28612363
6 Al-Ak'hali MS, Halboub ES, Asiri YM, WhatsApp-assisted Oral Health Education and Motivation: a Preliminary Randomized Clinical Trial. J Contemp Dent Pract. 2020;21(8):922–5. PMID: 33568616. Exclusion reason: Ineligible outcome33568616
7 Alabdullah JH, Daniel SJ. A Systematic Review on the Validity of Teledentistry. Telemedicine Journal and e-Health. 2018 Aug;24(8):639–48. doi: 10.1089/tmj.2017.0132. PMID: 29303678. Exclusion reason: Used as source document29303678
8 Albrecht M, Kupfer R, Reissmann DR, Oral health educational interventions for nursing home staff and residents. Cochrane Database Syst Rev. 2016(9) doi: 10.1002/14651858.CD010535.pub2. PMID: 27689868. Exclusion reason: Ineligible intervention27689868
9 Alirezaei M, Bagherian A, Sarraf Shirazi A. Glass ionomer cements as fissure sealing materials: yes or no?: A systematic review and meta-analysis. J Am Dent Assoc. 2018 Jul;149(7):640–9.e9. doi: 10.1016/j.adaj.2018.02.001. PMID: 29735163. Exclusion reason: Ineligible comparison29735163
10 Alrashdi M, Hameed A, Cervantes Mendez MJ, Education intervention with respect to the oral health knowledge, attitude, and behaviors of refugee families: a randomized clinical trial of effectiveness. J Public Health Dent. 2021;81(2):90–9. doi: 10.1111/jphd.12415. PMID: 33084019. Exclusion reason: Ineligible outcome33084019
11 Amarasena N, Haag D, Peres KG. A scoping review of caries risk management protocols in Australia and New Zealand. Australian Dental Journal. 2019 03;64(1):19–26. doi: 10.1111/adj.12653. PMID: 30242843. Exclusion reason: Ineligible intervention30242843
12 American Dental Association Council on Scientific A. Professionally applied topical fluoride: evidence-based clinical recommendations. J Dent Educ. 2007 Mar;71(3):393–402. doi: 10.1002/j.0022–0337.2007.71.3.tb04289.x. PMID: 17389574. Exclusion reason: Not a study17389574
13 American Dental Association Council on Scientific Affairs. Professionally applied topical fluoride: evidence-based clinical recommendations. J Am Dent Assoc. 2006 Aug;137(8):1151–9. doi: 10.14219/jada.archive.2006.0356. PMID: 16873333. Exclusion reason: Not a study16873333
14 Anders PL, Davis EL. Oral health of patients with intellectual disabilities: a systematic review. Spec Care Dentist. 2010 May-Jun;30(3):110–7. doi: 10.1111/j.1754–4505.2010.00136.x. PMID: 20500706. Exclusion reason: Ineligible intervention20500706
15 Anonymous. Educators and Clinicians Create New Assessment Tool to Improve Oral-Systemic Health. Dentistry Today. 2015 Mar;34(3):48, 50. PMID: 26351724. Exclusion reason: Ineligible study design26351724
16 Anter E, Zayet MK, El-Dessouky SH. Accuracy and precision of cone beam computed tomography in periodontal defects measurement (systematic review). J Indian Soc Periodontol. 2016 May-Jun;20(3):235–43. doi: 10.4103/0972–124X.176389. PMID: 27563194. Exclusion reason: Ineligible intervention27563194
17 Antonio AG, Pierro VS, Maia LC. Caries preventive effects of xylitol-based candies and lozenges: a systematic review. J Public Health Dent. 2011;71(2):117–24. doi: 10.1111/j.1752–7325.2010.00208.x. PMID: 21774134. Exclusion reason: Used as source document21774134
18 Armstrong S, Dermont M. Does prevention-focused dental care provision during recruit training reduce adverse dental outcomes in UK Armed Forces personnel? A retrospective cohort analysis. Br Dent J. 2021 04;230(7):400–6. doi: 10.1038/s41415–021-2741–5. PMID: 33837335. Exclusion reason: Ineligible intervention33837335
19 Asimakopoulou K, Newton JT, Daly B, The effects of providing periodontal disease risk information on psychological outcomes - a randomized controlled trial. J Clin Periodontol. 2015;42(4):350–5. doi: 10.1111/jcpe.12377. PMID: 25682859. Exclusion reason: Ineligible population25682859
20 Asimakopoulou K, Nolan M, McCarthy C, The effect of risk communication on periodontal treatment outcomes: a randomized controlled trial. J Periodontol. 2019. doi: 10.1002/JPER.18–0385. PMID: 30997690. Exclusion reason: Ineligible intervention30997690
21 Astvaldsdottir A, Bostrom AM, Davidson T, Oral health and dental care of older persons-A systematic map of systematic reviews. Gerodontology. 2018 Dec;35(4):290–304. doi: 10.1111/ger.12368. PMID: 30129220. Exclusion reason: Used as source document30129220
22 Atara AGMRSVJVDB. Clinical evaluation of Krimidanta Pratishedha (anti-caries) activity of Triphaladi Gandusha in high risk dental caries patients. Ayu. 2014;35(1):42–5. doi: 10.4103/0974–8520.141916. PMID: 25364198. Exclusion reason: Ineligible intervention25364198
23 Axelsson S, Soder B, Nordenram G, Effect of combined caries-preventive methods: a systematic review of controlled clinical trials. Acta Odontol Scand. 2004 Jun;62(3):163–9. doi: 10.1080/00016350410006842. PMID: 15370637. Exclusion reason: Ineligible outcome15370637
24 Azarpazhooh A, Main PA. Efficacy of dental prophylaxis (rubber cup) for the prevention of caries and gingivitis: a systematic review of literature. Br Dent J. 2009 Oct 10;207(7):E14; discussion 328–9. doi: 10.1038/sj.bdj.2009.899. PMID: 19816459. Exclusion reason: Ineligible intervention19816459
25 Bader JD, Perrin NA, Maupome G, Validation of a simple approach to caries risk assessment. J Public Health Dent. 2005;65(2):76–81. doi: 10.1111/j.1752–7325.2005.tb02790.x. PMID: 15929544. Exclusion reason: Ineligible intervention15929544
26 Bader JD, Shugars DA, Bonito AJ. Systematic reviews of selected dental caries diagnostic and management methods. J Dent Educ. 2001 Oct;65(10):960–8. doi: 10.1002/j.0022–0337.2001.65.10.tb03470.x. PMID: 11699997. Exclusion reason: Used as source document11699997
27 Bader JD, Shugars DA, Vollmer WM, Design of the xylitol for adult caries trial (X-ACT). BMC Oral Health. 2010;10(22)doi: 10.1186/1472–6831-10–22. PMID: 20920261. Exclusion reason: Not usable20920261
28 Bader JD, Vollmer WM, Shugars DA, Results from the Xylitol for Adult Caries Trial (X-ACT). J Am Dent Assoc. 2013;144(1):21–30. doi: 10.14219/jada.archive.2013.0010. PMID: 23283923. Exclusion reason: Ineligible population23283923
29 Bahri N, Tohidinik HR, Bahri N, Educational intervention to improve oral health beliefs and behaviors during pregnancy: a randomized-controlled trial. J Egypt Public Health Assoc. 2015;90(2):41–5. doi: 10.1097/01.EPX.0000464139.06374.a4. PMID: 26154829. Exclusion reason: Ineligible outcome26154829
30 Bakhtiar K, Gharouni K, Gharouni B, The effect of training interventions on the psychological factors of oral health in pregnant women. Electron Physician. 2017 Oct;9(10):5506–15. doi: 10.19082/5506. PMID: 29238491. Exclusion reason: Ineligible intervention29238491
31 Bansal A, Ingle NA, Kaur N, Recent advancements in fluoride: A systematic review. J Int Soc Prev Community Dent.. 2015 Sep-Oct;5(5):341–6. doi: 10.4103/2231–0762.165927. PMID: 26539383. Exclusion reason: Not usable26539383
32 Banting DW, Papas A, Clark DC, The effectiveness of 10% chlorhexidine varnish treatment on dental caries incidence in adults with dry mouth. Gerodontology. 2000;17(2):67–76. doi: 10.1111/j.1741–2358.2000.00067.x. PMID: 11808057. Exclusion reason: Ineligible intervention11808057
33 Beauchamp J, Caufield PW, Crall JJ, Evidence-based clinical recommendations for the use of pit-and-fissure sealants: a report of the American Dental Association Council on Scientific Affairs. J Am Dent Assoc. 2008 Mar;139(3):257–68. doi: 10.14219/jada.archive.2008.0155. PMID: 18310730. Exclusion reason: Not a study18310730
34 Beauchamp J, Caufield PW, Crall JJ, Evidence-based clinical recommendations for the use of pit-and-fissure sealants: a report of the American Dental Association Council on Scientific Affairs. Dent Clin North Am. 2009 Jan;53(1):131–47, x. doi: 10.1016/j.cden.2008.09.003. PMID: 19215748. Exclusion reason: Not a study19215748
35 Beier G, Riethe P. Effect of periodontal sprays on uncalcified deposition, infectious periodontal diseases and enamel. Deutsche zahnarztliche Zeitschrift. 1971;26(5):600–3. PMID: 5280922. Exclusion reason: Not in English5280922
36 Beiruti N, Frencken JE, van ť Hof MA, Caries-preventive effect of resin-based and glass ionomer sealants over time: a systematic review. Community Dent Oral Epidemiol. 2006 Dec;34(6):403–9. doi: 10.1111/j.1600–0528.2006.00321.x. PMID: 17092268. Exclusion reason: Ineligible comparison17092268
37 Beltran-Aguilar ED. Silver diamine fluoride (SDF) may be better than fluoride varnish and no treatment in arresting and preventing cavitated carious lesions. J Evid Based Dent Prac. 2010 Jun;10(2):122–4. doi: 10.1016/j.jebdp.2010.02.014. PMID: 20466328. Exclusion reason: Ineligible intervention20466328
38 Berg JH. Dental caries detection and caries management by risk assessment. J Esthet Restor Dent. 2007;19(1):49–55. doi: 10.1111/j.1708–8240.2006.00059.x. PMID: 17244151. Exclusion reason: Not a study17244151
39 Bijle MN A, Yiu CK Y, Ekambaram M. Calcium-Based Caries Preventive Agents: A Meta-evaluation of Systematic Reviews and Meta-analysis. J Evid Based Dent Prac. 2018 09;18(3):203–17.e4. doi: 10.1016/j.jebdp.2017.09.003. PMID: 30077374. Exclusion reason: Ineligible intervention30077374
40 Bizarra MF, Ribeiro Graca S. Short-term impact of an oral health program for adults with cerebral palsy. Spec Care Dentist. 2020 Jan;40(1):26–34. doi: 10.1111/scd.12431. PMID: 31697453. Exclusion reason: Ineligible outcome31697453
41 Bonetti D, Clarkson JE. Fluoride Varnish for Caries Prevention: Efficacy and Implementation. Caries Res. 2016;50 Suppl 1:45–9. doi: 10.1159/000444268. PMID: 27100219. Exclusion reason: Not a study27100219
42 Bonetti D, Hampson V, Queen K, Improving oral hygiene for patients. Nurs Stand. 2015 Jan 13;29(19):44–50. doi: 10.7748/ns.29.19.44.e9383. PMID: 25563127. Exclusion reason: Ineligible outcome25563127
43 Botelho J, Machado V, Mendes JJ, Causal Association between Periodontitis and Parkinson's Disease: A Bidirectional Mendelian Randomization Study. Genes (Basel). 2021 05 19;12(5):19. doi: 10.3390/genes12050772. PMID: 34069479. Exclusion reason: Ineligible study design
44 Boyle S, Duke A. Are adjunctive therapies effective in reducing gingivitis and plaque? Evid Based Dent. 2021 01;22(3):98–9. doi: 10.1038/s41432–021-0204–0. PMID: 34561658. Exclusion reason: Not a study34561658
45 Brady EP. Dental caries and topically applied fluorides. The Journal of the Missouri State Dental Association. 1948 May;28(5):159–65. PMID: 18865692. Exclusion reason: Not a study18865692
46 Brennan MT, Runyon MS, Batts JJ, Odontogenic signs and symptoms as predictors of odontogenic infection: a clinical trial. J Am Dent Asoc. 2006;137(1):62–6. doi: 10.14219/jada.archive.2006.0022. PMID: 16457000. Exclusion reason: Ineligible outcome16457000
47 Brocklehurst P, Kujan O, O'Malley LA, Screening programmes for the early detection and prevention of oral cancer. Cochrane Database Syst Rev. 2013 Nov 19(11):CD004150. doi: 10.1002/14651858.CD004150.pub4. PMID: 24254989. Exclusion reason: Ineligible outcome24254989
48 Brown JB, Rosenstein D, Mullooly J, Impact of intensified dental care on outcomes in human immunodeficiency virus infection. AIDS Patient Care STDs. 2002;16(10):479–86. doi: 10.1089/10872910260351258. PMID: 12437859. Exclusion reason: Ineligible population12437859
49 Cagetti MG, Bonta G, Cocco F, Are standardized caries risk assessment models effective in assessing actual caries status and future caries increment? A systematic review. BMC Oral Health. 2018 07 16;18(1):123. doi: 10.1186/s12903–018-0585–4. PMID: 30012136. Exclusion reason: Ineligible intervention30012136
50 Carra MC, Detzen L, Kitzmann J, Promoting behavioural changes to improve oral hygiene in patients with periodontal diseases: A systematic review. J Clin Periodontol. 2020 Jul;47 Suppl 22:72–89. doi: 10.1111/jcpe.13234. PMID: 31912530. Exclusion reason: Ineligible population31912530
51 Carson SJ. Limited evidence for existing caries assessment systems. Evid Based Dent. 2013 Mar;14(1):10–1. doi: 10.1038/sj.ebd.6400911. PMID: 23579298. Exclusion reason: Not a study23579298
52 Carta G, Cagetti MG, Cocco F, Caries-risk profiles in Italian adults using computer caries assessment system and ICDAS. Pesqui Odontol Bras. 2015;29(1):S1806–83242015000100306. doi: 10.1590/1807–3107BOR-2015.vol29.0126. PMID: 26892361. Exclusion reason: Ineligible intervention26892361
53 Cascaes AM, Bielemann RM, Clark VL, Effectiveness of motivational interviewing at improving oral health: a systematic review. Rev Saude Publica. 2014 Feb;48(1):142–53. doi: 10.1590/s0034–8910.2014048004616. PMID: 24789647. Exclusion reason: Used as source document24789647
54 Centers for Disease C, Prevention. Promoting oral health: interventions for preventing dental caries, oral and pharyngeal cancers, and sports-related craniofacial injuries. A report on recommendations of the task force on community preventive services. Morbidity & Mortality Weekly Report. Recommendations & Reports. 2001 Nov 30;50(RR-21):1–13. PMID: 11770576. Exclusion reason: Used as source document11770576
55 Chalmers J, Pearson A. Oral hygiene care for residents with dementia: a literature review. Journal of Advanced Nursing. 2005 Nov;52(4):410–9. doi: 10.1111/j.1365–2648.2005.03605.x. PMID: 16268845. Exclusion reason: Not a study16268845
56 Chalmers JM, Pearson A. A systematic review of oral health assessment by nurses and carers for residents with dementia in residential care facilities. Spec Care Dentist. 2005 Sep-Oct;25(5):227–33. doi: 10.1111/j.1754–4505.2005.tb01654.x. PMID: 16454098. Exclusion reason: Ineligible population16454098
57 Chan CL, You HJ, Lian HJ, Patients receiving comprehensive periodontal treatment have better clinical outcomes than patients receiving conventional periodontal treatment. J Formos Med Assoc. 2016 Mar;115(3):152–62. doi: 10.1016/j.jfma.2015.10.017. PMID: 26776448. Exclusion reason: Ineligible population26776448
58 Chandrashekar BR, Suma S, Kiran K, The use of school teachers to promote oral hygiene in some secondary school students at Hyderabad, Andhra Pradesh, India: A short term prospective pilot study. J Family Community Med. 2012 Sep;19(3):184–9. doi: 10.4103/2230–8229.102319. PMID: 23230385. Exclusion reason: Ineligible outcome23230385
59 Chapple IL, Van der Weijden F, Doerfer C, Primary prevention of periodontitis: managing gingivitis. J Clin Periodontol. 2015 Apr;42 Suppl 16:S71–6. doi: 10.1111/jcpe.12366. PMID: 25639826. Exclusion reason: Ineligible outcome25639826
60 Chia-Hui Chen C, Chyun DA, Li CY, A single-item approach to screening elders for oral health assessment. Nurs Res. 2007 Sep-Oct;56(5):332–8. doi: 10.1097/01.NNR.0000289504.30037.d8. PMID: 17846554. Exclusion reason: Ineligible outcome17846554
61 Cinar AB, Oktay I, Schou L. "Smile healthy to your diabetes": health coaching-based intervention for oral health and diabetes management. Clin Oral Investig. 2014;18(7):1793–801. doi: 10.1007/s00784-013-1165-2. PMID: 24362589. Exclusion reason: Ineligible comparison24362589
62 Clarkson JE, Ramsay CR, Averley P, IQuaD dental trial; improving the quality of dentistry: a multicentre randomised controlled trial comparing oral hygiene advice and periodontal instrumentation for the prevention and management of periodontal disease in dentate adults attending dental primary care. BMC Oral Health. 2013 Oct 26;13:58. doi: 10.1186/1472-6831-13-58. PMID: 24160246. Exclusion reason: Ineligible outcome24160246
63 Cocco F, Carta G, Cagetti MG, The caries preventive effect of 1-year use of low-dose xylitol chewing gum. A randomized placebo-controlled clinical trial in high-caries-risk adults. Clin Oral Investig. 2017;21(9):2733–40. doi: 10.1007/s00784-017-2075-5. PMID: 28303470. Exclusion reason: Ineligible intervention28303470
64 Coelho A, Paula AB P, Carrilho TM P, Chlorhexidine mouthwash as an anticaries agent: A systematic review. Quintessence Int J Dent Hyg. 2017;48(7):585–91. doi: 10.3290/j.qi.a38353. PMID: 28555200. Exclusion reason: Ineligible intervention28555200
65 Coker E, Ploeg J, Kaasalainen S. The effect of programs to improve oral hygiene outcomes for older residents in long-term care: a systematic review. Res Gerontol Nurs. 2014 Mar-Apr;7(2):87–100. doi: 10.3928/19404921–20140110-01. PMID: 24444451. Exclusion reason: Ineligible intervention24444451
66 Conceicao SD S, Gomes-Filho IS, Coelho JM F, An accuracy study of the clinical diagnosis of periodontitis in pregnant women. J Periodontol. 2021 Sep;92(9):1243–51. doi: 10.1002/JPER.20–0441. PMID: 33252149. Exclusion reason: Ineligible study design33252149
67 Cronin AJ, Claffey N, Stassen LF. Who is at risk? Periodontal disease risk analysis made accessible for the general dental practitioner. Br Dent J. 2008 Aug 09;205(3):131–7. doi: 10.1038/sj.bdj.2008.653. PMID: 18690185. Exclusion reason: Not a study18690185
68 Czwikla J, Herzberg A, Kapp S, Effectiveness of a Dental Intervention to Improve Oral Health among Home Care Recipients: A Randomized Controlled Trial. Int J Environ Res Public Health. 2021 Sep 03;18(17):03. doi: 10.3390/ijerph18179339. PMID: 34501925. Exclusion reason: Ineligible intervention34501925
69 Dan AD, Ghergic DL. Assessment of Oral Health Education with the Simplified Oral Hygiene Index in Military Students - A Comparative Study. Oral Health Prev. 2021 Jan 07;19(1):425–31. doi: 10.3290/j.ohpd.b1993907. PMID: 34505496. Exclusion reason: Ineligible outcome34505496
70 de Araujo Nobre M, Ferro A, Malo P. Adult Patient Risk Stratification Using a Risk Score for Periodontitis. J Clin Med. 2019 Mar 05;8(3):05. doi: 10.3390/jcm8030307. PMID: 30841500. Exclusion reason: Ineligible study design30841500
71 Deery C. Pits and fissure sealant guidelines. Summary guideline. Evid Based Dent. 2008;9(3):68–70. doi: 10.1038/sj.ebd.6400591. PMID: 18927561. Exclusion reason: Ineligible intervention18927561
72 Deery C. Clinical Practice Guidelines Proposed the Use of Pit and Fissure Sealants to Prevent and Arrest Noncavitated Carious Lesions. J Evid Based Dent Prac. 2017 03;17(1):48–50. doi: 10.1016/j.jebdp.2017.01.008. PMID: 28259315. Exclusion reason: Not a study28259315
73 Dholam KP, Somani PP, Prabhu SD, Effectiveness of fluoride varnish application as cariostatic and desensitizing agent in irradiated head and neck cancer patients. Int J Dent Hyg. 2013;2013:824982. doi: 10.1155/2013/824982. PMID: 23843793. Exclusion reason: Ineligible population23843793
74 Domejean S, Banerjee A, Featherstone JD B. Caries risk/susceptibility assessment: its value in minimum intervention oral healthcare. Br Dent J. 2017 Aug 11;223(3):191–7. doi: 10.1038/sj.bdj.2017.665. PMID: 28798458. Exclusion reason: Not a study28798458
75 Duane B. Psychological approaches to behaviour for improving plaque control. Evid Based Dent. 2017 03;18(1):3–4. doi: 10.1038/sj.ebd.6401213. PMID: 28338037. Exclusion reason: Not a study28338037
76 Dyer TA, Brocklehurst P, Glenny AM, Dental auxiliaries for dental care traditionally provided by dentists. Cochrane Database Syst Rev. 2014 Aug 20(8):CD010076. doi: 10.1002/14651858.CD010076.pub2. PMID: 25140869. Exclusion reason: Used as source document25140869
77 Elkerbout TA, Slot DE, Van Loveren C, Will a chlorhexidine-fluoride mouthwash reduce plaque and gingivitis? Int J Dent Hyg. 2019 Feb;17(1):3–15. doi: 10.1111/idh.12329. PMID: 29512317. Exclusion reason: Ineligible intervention29512317
78 Elrashid AH, Alshaiji BS, Saleh SA, Efficacy of Resin Infiltrate in Noncavitated Proximal Carious Lesions: A Systematic Review and Meta-Analysis. J Int Soc Prev Community Dent. 2019 May-Jun;9(3):211–8. doi: 10.4103/jispcd.JISPCD_26_19. PMID: 31198691. Exclusion reason: Ineligible population31198691
79 Emami E, Kadoch N, Homayounfar S, Patient satisfaction with E-Oral Health care in rural and remote settings: a systematic review protocol. Syst. 2017 08 29;6(1):174. doi: 10.1186/s13643–017-0550–3. PMID: 28851449. Exclusion reason: Ineligible intervention28851449
80 Engstrom S, Holmlund A. Self-estimated oral and general health are related and associated with clinically investigated dental health. Swed Dent J. 2011;35(4):169–75. PMID: 22372304. Exclusion reason: Ineligible intervention22372304
81 Escribano M, Figuero E, Martin C, Efficacy of adjunctive anti-plaque chemical agents: a systematic review and network meta-analyses of the Turesky modification of the Quigley and Hein plaque index. J Clin Periodontol. 2016 12;43(12):1059–73. doi: 10.1111/jcpe.12616. PMID: 27531174. Exclusion reason: Ineligible intervention27531174
82 Estai M, Bunt S, Kanagasingam Y, Diagnostic accuracy of teledentistry in the detection of dental caries: a systematic review. J Evid Based Dent Prac. 2016 09;16(3):161–72. doi: 10.1016/j.jebdp.2016.08.003. PMID: 27855831. Exclusion reason: Ineligible intervention27855831
83 Everaars B, Weening-Verbree LF, Jerkovic-Cosic K, Measurement properties of oral health assessments for non-dental healthcare professionals in older people: a systematic review. BMC Geriatr. 2020 01 03;20(1):4. doi: 10.1186/s12877–019-1349-y. PMID: 31900125. Exclusion reason: Not usable31900125
84 Ewoldsen N, Koka S. There are no clearly superior methods for diagnosing, predicting, and noninvasively treating dental caries. J Evid Based Dent Prac. 2010 Mar;10(1):16–7. doi: 10.1016/j.jebdp.2009.11.008. PMID: 20230957. Exclusion reason: Not a study20230957
85 Fee PA, Riley P, Worthington HV, Recall intervals for oral health in primary care patients. Cochrane Database Syst Rev. 2020 10 14;10:CD004346. doi: 10.1002/14651858.CD004346.pub5. PMID: 33053198. Exclusion reason: Ineligible outcome33053198
86 Fontana M, Gonzalez-Cabezas C. Noninvasive Caries Risk-based Management in Private Practice Settings May Lead to Reduced Caries Experience Over Time. J Evid Based Dent Prac. 2016 12;16(4):239–42. doi: 10.1016/j.jebdp.2016.11.003. PMID: 27938697. Exclusion reason: Not a study27938697
87 Fontana M, Young DA, Wolff MS. Evidence-Based Caries, Risk Assessment, and Treatment. Dent Clin North Am. 2009;53(1):149–61. doi: 10.1016/j.cden.2008.10.003. PMID: 19215749. Exclusion reason: Not a study19215749
88 USPSTF. Using nontraditional risk factors in coronary heart disease risk assessment: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009 Oct 06;151(7):474–82. doi: 10.7326/0003–4819-151–7-200910060–00008. PMID: 19805770. Exclusion reason: Ineligible intervention19805770
89 Fure S, Gahnberg L, Birkhed D. A comparison of four home-care fluoride programs on the caries incidence in the elderly. Gerodontology. 1998;15(2):51–60. doi: 10.1111/j.1741–2358.1998.00051.x. PMID: 10530177. Exclusion reason: Ineligible intervention10530177
90 Gao X, Lo EC, Kot SC, Motivational interviewing in improving oral health: a systematic review of randomized controlled trials. J Periodontol. 2014 Mar;85(3):426–37. doi: 10.1902/jop.2013.130205. PMID: 23805818. Exclusion reason: Ineligible intervention23805818
91 Garcia-Pola MJ, Rodriguez-Lopez S, Fernanz-Vigil A, Oral hygiene instructions and professional control as part of the treatment of desquamative gingivitis. Systematic review. Med Oral Patol Oral Cir Bucal. 2019 Mar 01;24(2):e136–e44. doi: 10.4317/medoral.22782. PMID: 30818305. Exclusion reason: Ineligible intervention30818305
92 George A, Johnson M, Blinkhorn A, Promoting oral health during pregnancy: current evidence and implications for Australian midwives. J Clin Nurs. 2010 Dec;19(23–24):3324–33. doi: 10.1111/j.1365–2702.2010.03426.x. PMID: 20955483. Exclusion reason: Ineligible study design20955483
93 Ghaffari M, Rakhshanderou S, Ramezankhani A, Are educating and promoting interventions effective in oral health?: A systematic review. Int J Dent Hyg. 2018 Feb;16(1):48–58. doi: 10.1111/idh.12305. PMID: 28834249. Exclusion reason: Used as source document28834249
94 Gibson G, Jurasic MM, Wehler CJ, Supplemental fluoride use for moderate and high caries risk adults: a systematic review. J Public Health Dent. 2011;71(3):171–84. doi: 10.1111/j.1752–7325.2011.00261.x. PMID: 21972457. Exclusion reason: Ineligible intervention21972457
95 Gimenez T, Piovesan C, Braga MM, Visual Inspection for Caries Detection: A Systematic Review and Meta-analysis. J Dent Res. 2015 Jul;94(7):895–904. doi: 10.1177/0022034515586763. PMID: 25994176. Exclusion reason: Ineligible study design25994176
96 Gluzman R, Katz RV, Frey BJ, Prevention of root caries: a literature review of primary and secondary preventive agents. Spec Care Dentist. 2013 May-Jun;33(3):133–40. doi: 10.1111/j.1754–4505.2012.00318.x. PMID: 23600985. Exclusion reason: Used as source document23600985
97 Gold J. Silver Diamine Fluoride May Prevent and Arrest Root Caries in Older Adults. J Evid Based Dent Pract. 2019 Jun;19(2):186–8. doi: 10.1016/j.jebdp.2019.05.009. PMID: 31326052. Exclusion reason: Not a study31326052
98 Grandjean ML, Maccarone NR, McKenna G, Silver Diamine Fluoride (SDF) in the management of root caries in elders: a systematic review and meta-analysis. Swiss Dent J. 2021 05 10;131(5):417–24. PMID: 33515230. Exclusion reason: Used as source document33515230
99 Griffin SO, Regnier E, Griffin PM, Effectiveness of fluoride in preventing caries in adults. J Dent Res. 2007 May;86(5):410–5. doi: 10.1177/154405910708600504. PMID: 17452559. Exclusion reason: Used as source document17452559
100 Harris R, Gamboa A, Dailey Y, One-to-one dietary interventions undertaken in a dental setting to change dietary behaviour. Cochrane Database Syst Rev. 2012 Mar 14(3):CD006540. doi: 10.1002/14651858.CD006540.pub2. PMID: 22419315. Exclusion reason: Ineligible intervention22419315
101 Harris R, Vernazza C, Laverty L, NIHR Journals Library. 2020 1;1:1. doi: 10.3310/hsdr08030. PMID: 31985916. Exclusion reason: Used as source document31985916
102 Hausen H. Oral health promotion reduces plaque and gingival bleeding in the short term. Evid Based Dent. 2005;6(2):31. doi: 10.1038/sj.ebd.6400325. PMID: 16208381. Exclusion reason: Not a study16208381
103 Hayes M. Topical agents for root caries prevention. Evid Based Dent. 2015 Mar;16(1):10–1. doi: 10.1038/sj.ebd.6401074. PMID: 25909930. Exclusion reason: Not a study25909930
104 Hayes M, Da Mata C, McKenna G, Evaluation of the Cariogram for root caries prediction. J Dent. 2017 Jul;62:25–30. doi: 10.1016/j.jdent.2017.04.010. PMID: 28456556. Exclusion reason: Ineligible intervention28456556
105 Heijnsbroek M, Paraskevas S, Van der Weijden GA. Fluoride interventions for root caries: a review. Oral Health Prev. 2007;5(2):145–52. doi: 10.3290/j.ohpd.a12307. PMID: 17722442. Exclusion reason: Ineligible population17722442
106 Helfenstein U, Steiner M. Fluoride varnishes (Duraphat): a meta-analysis. Community Dent Oral Epidemiol. 1994 Feb;22(1):1–5. doi: 10.1111/j.1600–0528.1994.tb01559.x. PMID: 8143435. Exclusion reason: Used as source document8143435
107 Hendre AD, Taylor GW, Chávez EM, A systematic review of silver diamine fluoride: Effectiveness and application in older adults. Gerodontology. 2017 Dec;34(4):411–9. doi: 10.1111/ger.12294. PMID: 28812312. Exclusion reason: Used as source document28812312
108 Hoben M, Kent A, Kobagi N, Effective strategies to motivate nursing home residents in oral care and to prevent or reduce responsive behaviors to oral care: A systematic review. PLoS ONE. 2017;12(6):e0178913. doi: 10.1371/journal.pone.0178913. PMID: 28609476. Exclusion reason: Ineligible intervention28609476
109 Hoben M, Kent A, Kobagi N, Effective strategies to motivate nursing home residents in oral healthcare and to prevent or reduce responsive behaviours to oral healthcare: a systematic review protocol. BMJ Open. 2016 Mar 24;6(3):e011159. doi: 10.1136/bmjopen-2016–011159. PMID: 27013601. Exclusion reason: Not a study27013601
110 Holloway PJ, Booth EM, Wragg KA. Dietary counselling in the control of dental caries. Br Dent J. 1969 Feb 18;126(4):161–5. PMID: 5251322. Exclusion reason: Ineligible intervention5251322
111 Horowitz HS, Heifetz SB, Poulsen S. Retention and effectiveness of a single application of an adhesive sealant in preventing occlusal caries: final report after five years of a study in Kalispell, Montana. J Am Dent Assoc. 1977 Dec;95(6):1133–9. doi: 10.14219/jada.archive.1977.0201. PMID: 271677. Exclusion reason: Ineligible intervention271677
112 Horst JA. Silver Fluoride as a Treatment for Dental Caries. Adv Dent Res. 2018 02;29(1):135–40. doi: 10.1177/0022034517743750. PMID: 29355428. Exclusion reason: Not a study29355428
113 Hoskin ER, Keenan AV. Can we trust visual methods alone for detecting caries in teeth? Evid Based Dent. 2016 06;17(2):41–2. doi: 10.1038/sj.ebd.6401165. PMID: 27339234. Exclusion reason: Not a study27339234
114 Hugoson A, Lundgren D, Asklow B, The effect of different dental health programmes on young adult individuals. A longitudinal evaluation of knowledge and behaviour including cost aspects. Swed Dent J. 2003;27(3):115–30. PMID: 14608968. Exclusion reason: Ineligible study design14608968
115 Hugoson A, Lundgren D, Asklow B, Effect of three different dental health preventive programmes on young adult individuals: a randomized, blinded, parallel group, controlled evaluation of oral hygiene behaviour on plaque and gingivitis. J Clin Periodontol. 2007;34(5):407–15. doi: 10.1111/j.1600–051X.2007.001069.x. PMID: 17448044. Exclusion reason: Ineligible outcome17448044
116 Innes NP, Evans DJ. Evidence of improved access to dental care with direct access arrangements. Evid Based Dent. 2013;14(2):36–7. doi: 10.1038/sj.ebd.6400926. PMID: 23792392. Exclusion reason: Not a study23792392
117 Jadhav HC, Dodamani AS, Karibasappa GN, Effect of Reinforcement of Oral Health Education Message through Short Messaging Service in Mobile Phones: a Quasi-Experimental Trial. International Journal of Telemedicine and Applications. 2016;2016doi: 10.1155/2016/7293516. PMID: 26941793. Exclusion reason: Ineligible intervention26941793
118 Janakiram C, Deepan Kumar CV, Joseph J. Xylitol in preventing dental caries: A systematic review and meta-analyses. J. 2017 Jan-Jun;8(1):16–21. doi: 10.4103/0976–9668.198344. PMID: 28250669. Exclusion reason: Used as source document28250669
119 Janket SJ, Benwait J, Isaac P, Oral and Systemic Effects of Xylitol Consumption. Caries Res. 2019;53(5):491–501. doi: 10.1159/000499194. PMID: 31060040. Exclusion reason: Not a study31060040
120 Janssens B, Vanobbergen J, Petrovic M, The impact of a preventive and curative oral healthcare program on the prevalence and incidence of oral health problems in nursing home residents. PLoS ONE. 2018;13(6):e0198910. doi: 10.1371/journal.pone.0198910. PMID: 29894494. Exclusion reason: Ineligible study design29894494
121 Jayashankar S, Panagoda GJ, Amaratunga EA, A randomised double-blind placebo-controlled study on the effects of a herbal toothpaste on gingival bleeding, oral hygiene and microbial variables. Ceylon Medical Journal. 2011;56(1):5–9. doi: 10.4038/cmj.v56i1.2887. PMID: 21542426. Exclusion reason: Ineligible intervention21542426
122 Jensen ME, Kohout F. The effect of a fluoridated dentifrice on root and coronal caries in an older adult population. J Am Dent Asoc. 1988;117(7):829–32. doi: 10.14219/jada.archive.1988.0128. PMID: 3204243. Exclusion reason: Ineligible intervention3204243
123 Jepsen S, Blanco J, Buchalla W, Prevention and control of dental caries and periodontal diseases at individual and population level: consensus report of group 3 of joint EFP/ORCA workshop on the boundaries between caries and periodontal diseases. J Clin Periodontol. 2017 Mar;44 Suppl 18:S85–S93. doi: 10.1111/jcpe.12687. PMID: 28266120. Exclusion reason: Not a study28266120
124 Jia C, Sun M, Wang W, Effect of oral plaque control on postoperative pneumonia following lung cancer surgery. Thorac Cancer. 2020 06;11(6):1655–60. doi: 10.1111/1759–7714.13448. PMID: 32339413. Exclusion reason: Ineligible population32339413
125 Jiang CM, Duangthip D, Chan AK Y, Global research interest regarding silver diamine fluoride in dentistry: A bibliometric analysis. J Dent. 2021 Oct;113:103778. doi: 10.1016/j.jdent.2021.103778. PMID: 34391874. Exclusion reason: Ineligible study design34391874
126 Johansson I, Torge CJ, Lindmark U. Is an oral health coaching programme a way to sustain oral health for elderly people in nursing homes? A feasibility study. Int J Dent Hyg. 2020 Feb;18(1):107–15. doi: 10.1111/idh.12421. PMID: 31618518. Exclusion reason: Ineligible intervention31618518
127 Ju X, Jamieson LM, Mejia GC, Effect of oral health literacy on self-reported tooth loss: A multiple mediation analysis. Community Dent Oral Epidemiol. 2021 Sep 24;24:24. doi: 10.1111/cdoe.12699. PMID: 34561880. Exclusion reason: Ineligible intervention34561880
128 Jurasic MM, Gibson G, Wehler CJ, Fluoride effectiveness in high caries risk and medically complex Veterans. Community Dent Oral Epidemiol. 2014 Dec;42(6):543–52. doi: 10.1111/cdoe.12121. PMID: 25040074. Exclusion reason: Ineligible study design25040074
129 Kamal D, Hassanein H, Akah M, Caries Preventive and Antibacterial Effects of Two Natural Mouthwashes vs Chlorhexidine in High Caries-risk Patients: a Randomized Clinical Trial. J Contemp Dent Pract. 2020;21(12):1316–24. PMID: 33893252. Exclusion reason: Ineligible intervention33893252
130 Kanoute A, Gare J, Meda N, Effect of Oral Prophylactic Measures on the Occurrence of Pre-Eclampsia (OP-PE) in High-Risk Pregnant Women: A Cluster Randomized Controlled Trial. Methods Protoc. 2021 Sep 05;4(3):05. doi: 10.3390/mps4030061. PMID: 34564307. Exclusion reason: Ineligible intervention34564307
131 Karabekiroglu S, Unlu N. Effectiveness of Different Preventive Programs in Cariogram Parameters of Young Adults at High Caries Risk. Int J Dent Hyg. 2017;2017:7189270. doi: 10.1155/2017/7189270. PMID: 28634492. Exclusion reason: Ineligible outcome28634492
132 Kay EJ, Vascott D, Hocking A, Motivational interviewing in general dental practice: A review of the evidence. Br Dent J. 2016 Dec 16;221(12):785–91. doi: 10.1038/sj.bdj.2016.952. PMID: 27982007. Exclusion reason: Ineligible intervention27982007
133 Kazmierczak M, Mather M, Ciancio S, Clinical evaluation of anticalculus dentifrices. Clin Prev Dent. 1990;12(1):13–7. PMID: 2376102. Exclusion reason: Ineligible intervention2376102
134 Keenan JR, Keenan AV. Accuracy of dental radiographs for caries detection. Evid Based Dent. 2016 06;17(2):43. doi: 10.1038/sj.ebd.6401166. PMID: 27339235. Exclusion reason: Ineligible intervention27339235
135 Keltjens HM, Schaeken MJ, van der Hoeven JS, Caries control in overdenture patients: 18-month evaluation on fluoride and chlorhexidine therapies. Caries Res. 1990;24(5):371–5. doi: 10.1159/000261298. PMID: 2261610. Exclusion reason: Ineligible intervention2261610
136 Kim ES, Lee ES, Kang SM, A new screening method to detect proximal dental caries using fluorescence imaging. Photodiagnosis Photodyn Ther. 2017 Dec;20:257–62. doi: 10.1016/j.pdpdt.2017.10.009. PMID: 29079349. Exclusion reason: Ineligible intervention29079349
137 Komulainen K, Ylostalo P, Syrjala AM, Oral health intervention among community-dwelling older people: a randomised 2-year intervention study. Gerodontology. 2015;32(1):62–72. doi: 10.1111/ger.12067. PMID: 23841567. Exclusion reason: Ineligible intervention23841567
138 Kopczyk RA, Abrams H, Brown AT, Clinical and microbiological effects of a sanguinaria-containing mouthrinse and dentifrice with and without fluoride during 6 months of use. J Periodontol. 1991;62(10):617–22. doi: 10.1902/jop.1991.62.10.617. PMID: 1770421. Exclusion reason: Ineligible intervention1770421
139 Kothari S, Gray AR, Lyons K, Vital bleaching and oral-health-related quality of life in adults: A systematic review and meta-analysis. J Dent. 2019 05;84:22–9. doi: 10.1016/j.jdent.2019.03.007. PMID: 30904560. Exclusion reason: Ineligible intervention30904560
140 Kraivaphan P, Amornchat C. Effect of an essential oil-containing dentifrice on established plaque and gingivitis. Southeast Asian Journal of Tropical Medicine and Public Health. 2012;43(1):243–8. PMID: 23082576. Exclusion reason: Ineligible intervention23082576
141 Kraivaphan P, Amornchat C, Triratana T. Effects of a triclosan dentifrice on plaque formation, gingivitis and gingival bleeding in pregnant women: five-month clinical results. Southeast Asian Journal of Tropical Medicine and Public Health. 2007;38(3):594–7. PMID: 17877239. Exclusion reason: Ineligible intervention17877239
142 Kraivaphan P, Amornchat C, Triratana T, Clinical effect of a triclosan containing dentifrice on gingivitis during pregnancy and post-partum. Southeast Asian Journal of Tropical Medicine and Public Health. 2006;37(4):820–5. PMID: 17121312. Exclusion reason: Ineligible intervention17121312
143 Kuhnisch J, Bedir A, Lo YF, Meta-analysis of the longevity of commonly used pit and fissure sealant materials. Dent Mater. 2020 05;36(5):e158–e68. doi: 10.1016/j.dental.2020.02.001. PMID: 32061445. Exclusion reason: Ineligible outcome32061445
144 Lang NP, Suvan JE, Tonetti MS. Risk factor assessment tools for the prevention of periodontitis progression a systematic review. J Clin Periodontol. 2015 Apr;42 Suppl 16:S59–70. doi: 10.1111/jcpe.12350. PMID: 25496279. Exclusion reason: Ineligible intervention25496279
145 Larsson P, Bondemark L, Haggman-Henrikson B. The impact of oro-facial appearance on oral health-related quality of life: A systematic review. J Oral Rehabil. 2020 Mar 20;20:20. doi: 10.1111/joor.12965. PMID: 32196720. Exclusion reason: Ineligible intervention32196720
146 Laudenbach JM, Simon Z. Common dental and periodontal diseases: evaluation and management. Med Clin North Am. 2014 Nov;98(6):1239–60. doi: 10.1016/j.mcna.2014.08.002. PMID: 25443675. Exclusion reason: Not a study25443675
147 Lawal FB, Nasiru WO, Taiwo JO. The effectiveness of oral health education conducted at a rural community market setting. Journal of the West African Colleges of Surgeons. 2013 Oct-Dec;3(4):53–69. PMID: 26046025. Exclusion reason: Ineligible intervention26046025
148 Leake JL, Martinello BP. A four year evaluation of a a fissure sealant in a public health setting. Dent J. 1976 Aug;42(8):409–15. PMID: 1068139. Exclusion reason: Ineligible intervention1068139
149 Leal SC. Are standardised caries risk assessment models effective? Evid Based Dent. 2018 12;19(4):102–3. doi: 10.1038/sj.ebd.6401338. PMID: 30573864. Exclusion reason: Not a study30573864
150 Lee JY. Lower Oral Health Literacy may Lead to Poorer Oral Health Outcomes. J Evid Based Dent Prac. 2018 09;18(3):255–7. doi: 10.1016/j.jebdp.2018.05.003. PMID: 30077381. Exclusion reason: Not a study30077381
151 Lenzi TL, Montagner AF, Soares FZ, Are topical fluorides effective for treating incipient carious lesions?: A systematic review and meta-analysis. J Am Dent Assoc. 2016 Feb;147(2):84–91.e1. doi: 10.1016/j.adaj.2015.06.018. PMID: 26562737. Exclusion reason: Ineligible intervention26562737
152 Leverett DH, Handelman SL, Brenner CM, Use of sealants in the prevention and early treatment of carious lesions: cost analysis. J Am Dent Assoc. 1983 Jan;106(1):39–42. doi: 10.14219/jada.archive.1983.0024. PMID: 6222101. Exclusion reason: Ineligible comparison6222101
153 Lewis DW, Ismail AI. Periodic health examination, 1995 update: 2. Prevention of dental caries. The Canadian Task Force on the Periodic Health Examination. CMAJ. 1995 Mar 15;152(6):836–46. PMID: 7697577. Exclusion reason: Not a study7697577
154 Lewney J. Quality measures for dental care: A systematic review. Evid Based Dent. 2019 09;20(3):79–80. doi: 10.1038/s41432–019-0048-z. PMID: 31562407. Exclusion reason: Not a study31562407
155 Li F, Jiang P, Yu F, Comparison between Fissure Sealant and Fluoride Varnish on Caries Prevention for First Permanent Molars: a Systematic Review and Meta-analysis. Sci Rep. 2020 Feb 13;10(1):2578. doi: 10.1038/s41598–020-59564–5. PMID: 32055001. Exclusion reason: Ineligible comparison32055001
156 Li Q, Fan X, Li X. [The effectiveness of oral health education programme for middle school student to improve oral health knowledge]. Hua Xi Kou Qiang Yi Xue Za Zhi. 2009 Dec;27(6):642–4, 8. PMID: 20077901. Exclusion reason: Not in English20077901
157 Li R, Lo EC, Liu BY, Randomized clinical trial on arresting dental root caries through silver diammine fluoride applications in community-dwelling elders. J Dent. 2016;51:15–20. doi: 10.1016/j.jdent.2016.05.005. PMID: 27208876. Exclusion reason: Ineligible intervention27208876
158 Llodra JC, Bravo M, Delgado-Rodriguez M, Factors influencing the effectiveness of sealants--a meta-analysis. Community Dent Oral Epidemiol. 1993 Oct;21(5):261–8. doi: 10.1111/j.1600–0528.1993.tb00771.x. PMID: 8222598. Exclusion reason: Used as source document8222598
159 Low LF, Fletcher J, Goodenough B, A Systematic Review of Interventions to Change Staff Care Practices in Order to Improve Resident Outcomes in Nursing Homes. PLoS ONE. 2015;10(11):e0140711. doi: 10.1371/journal.pone.0140711. PMID: 26559675. Exclusion reason: Ineligible intervention26559675
160 Lowe C, Blinkhorn AS, Worthington HV, Testing the effect of including oral health in general health checks for elderly patients in medical practice--a randomized controlled trial. Community Dent Oral Epidemiol. 2007 Feb;35(1):12–7. doi: 10.1111/j.1600–0528.2007.00360.x. PMID: 17244133. Exclusion reason: Ineligible outcome17244133
161 Luciak-Donsberger C, Piribauer F. Evidence-based rationale supports a national periodontal disease screening program. J Evid Based Dent Prac. 2007 Jun;7(2):51–9. doi: 10.1016/j.jebdp.2007.02.001. PMID: 17599649. Exclusion reason: Not a study17599649
162 MacEntee MI, Wyatt CC, Beattie BL, Provision of mouth-care in long-term care facilities: an educational trial. Community Dent Oral Epidemiol. 2007;35(1):25–34. doi: 10.1111/j.1600–0528.2007.00318.x. PMID: 17244135. Exclusion reason: Ineligible population17244135
163 Macey R, Glenny A, Walsh T, The efficacy of screening for common dental diseases by hygiene-therapists: a diagnostic test accuracy study. J Dent Res. 2015;94(3 Suppl):70S-8S. PMID: CN-01110986. Exclusion reason: Ineligible intervention25604256
164 Macey R, Walsh T, Glenny AM, Protocol for diagnostic test accuracy study: the efficacy of screening for common dental diseases by dental care professionals. BMC Oral Health. 2013 Sep 21;13:45. doi: 10.1186/1472–6831-13–45. PMID: 24053760. Exclusion reason: Ineligible study design24053760
165 Macey R, Walsh T, Riley P, Tests to detect and inform the diagnosis of caries. Cochrane Database Syst Rev. 2018(12):Art. No.: CD013215. doi: 10.1002/14651858.Cd013215. PMID: 33284484. Exclusion reason: Not a study33284484
166 Makinen KK, Pemberton D, Makinen PL, Polyol-combinant saliva stimulants and oral health in Veterans Affairs patients--an exploratory study. Spec Care Dentist. 1996;16(3):104–15. doi: 10.1111/j.1754–4505.1996.tb00843.x. PMID: 9084323. Exclusion reason: Ineligible intervention9084323
167 Malekmahmoodi M, Shamsi M, Roozbahani N, A randomized controlled trial of an educational intervention to promote oral and dental health of patients with type 2 diabetes mellitus. BMC Public Health. 2020;20(1):287. doi: 10.1186/s12889–020-8395–4. PMID: 32131790. Exclusion reason: Ineligible population32131790
168 Mandel ID. Caries prevention: current strategies, new directions. J Am Dent Assoc. 1996 Oct;127(10):1477–88. doi: 10.14219/jada.archive.1996.0057. PMID: 8908917. Exclusion reason: Not a study8908917
169 Mann J, Vered Y, Babayof I, The comparative anticaries efficacy of a dentifrice containing 0.3% triclosan and 2.0% copolymer in a 0.243% sodium fluoride/silica base and a dentifrice containing 0.243% sodium fluoride/silica base: a two-year coronal caries clinical trial on adults in Israel. J Clin Dent. 2001;12(3):71–6. PMID: 11505964. Exclusion reason: Ineligible intervention11505964
170 Marchini L, Recker E, Hartshorn J, Iowa nursing facility oral hygiene (INFOH) intervention: a clinical and microbiological pilot randomized trial. Spec Care Dentist. 2018;38(6):345–55. doi: 10.1111/scd.12327. PMID: 30194737. Exclusion reason: Ineligible population30194737
171 Matthews DC. Prevention and treatment of periodontal diseases in primary care. Evid Based Dent. 2014 Sep;15(3):68–9. doi: 10.1038/sj.ebd.6401036. PMID: 25343386. Exclusion reason: Ineligible outcome25343386
172 McGrath C, Zhang W, Lo EC. A review of the effectiveness of oral health promotion activities among elderly people. Gerodontology. 2009 Jun;26(2):85–96. doi: 10.1111/j.1741–2358.2008.00232.x. PMID: 19490131. Exclusion reason: Used as source document19490131
173 McLaren HR, Brown HK. A study of the use of a topically applied stannous fluoride solution in the prevention of dental caries. Can J Public Health. 1955 Oct;46(10):387–95. PMID: 13270163. Exclusion reason: Ineligible comparison13270163
174 McReynolds D, Duane B. Systematic review finds that silver diamine fluoride is effective for both root caries prevention and arrest in older adults. Evid Based Dent. 2018 Jun;19(2):46–7. doi: 10.1038/sj.ebd.6401304. PMID: 29930359. Exclusion reason: Not a study29930359
175 Meurman JH, Helminen SK. Effectiveness of fissure sealant 3 years after application. Scand J Dent Res. 1976 Jul;84(4):218–23. doi: 10.1111/j.1600–0722.1976.tb00482.x. PMID: 1065948. Exclusion reason: Ineligible intervention1065948
176 Mickenautsch S, Leal SC, Yengopal V, Sugar-free chewing gum and dental caries: a systematic review. Journal of Applied Oral Science. 2007 Apr;15(2):83–8. doi: 10.1590/s1678–77572007000200002. PMID: 19089107. Exclusion reason: Ineligible comparison19089107
177 Mickenautsch S, Yengopal V. Caries-preventive effect of glass ionomer and resin-based fissure sealants on permanent teeth: An update of systematic review evidence. BMC Res Notes. 2011 Jan 28;4:22. doi: 10.1186/1756–0500-4–22. PMID: 21276215. Exclusion reason: Ineligible comparison21276215
178 Mickenautsch S, Yengopal V. Anticariogenic effect of xylitol versus fluoride - a quantitative systematic review of clinical trials. Int Dent J. 2012 Feb;62(1):6–20. doi: 10.1111/j.1875–595X.2011.00086.x. PMID: 22251032. Exclusion reason: Used as source document22251032
179 Mickenautsch S, Yengopal V. Caries-Preventive Effect of High-Viscosity Glass Ionomer and Resin-Based Fissure Sealants on Permanent Teeth: A Systematic Review of Clinical Trials. PLoS ONE. 2016;11(1):e0146512. doi: 10.1371/journal.pone.0146512. PMID: 26799812. Exclusion reason: Ineligible comparison26799812
180 Neurath C, Limeback H, Osmunson B, Dental Fluorosis Trends in US Oral Health Surveys: 1986 to 2012. JDR Clinical and Translational Research. 2019 Mar 6:2380084419830957. doi: 10.1177/2380084419830957. PMID: 30931722. Exclusion reason: Ineligible study design30931722
181 Newton JT, Asimakopoulou K. Managing oral hygiene as a risk factor for periodontal disease: a systematic review of psychological approaches to behaviour change for improved plaque control in periodontal management. J Clin Periodontol. 2015 Apr;42 Suppl 16:S36–46. doi: 10.1111/jcpe.12356. PMID: 25639708. Exclusion reason: Ineligible population25639708
182 Newton JT, Awojobi O, Nasseripour M, A Systematic Review and Meta-Analysis of the Role of Sugar-Free Chewing Gum in Dental Caries. JDR Clin Trans Res. 2020 Jul;5(3):214–23. doi: 10.1177/2380084419887178. PMID: 31743654. Exclusion reason: Ineligible intervention31743654
183 Niederman R. Psychological approaches may improve oral hygiene behaviour. Evid Based Dent. 2007;8(2):39–40. doi: 10.1038/sj.ebd.6400487. PMID: 17589482. Exclusion reason: Ineligible population17589482
184 Niederman R. Glass ionomer and resin-based fissure sealants - equally effective? Evid Based Dent. 2010;11(1):10. doi: 10.1038/sj.ebd.6400700. PMID: 20348889. Exclusion reason: Not a study20348889
185 Nomura Y, Okada A, Tamaki Y, Salivary Levels of Hemoglobin for Screening Periodontal Disease: A Systematic Review. Int J Dent Hyg. 2018;2018:2541204. doi: 10.1155/2018/2541204. PMID: 29755526. Exclusion reason: Ineligible intervention29755526
186 Nwhator SO, Ayanbadejo PO, Umeizudike KA, Clinical correlates of a lateral-flow immunoassay oral risk indicator. J Periodontol. 2014 Jan;85(1):188–94. doi: 10.1902/jop.2013.130116. PMID: 23600996. Exclusion reason: Ineligible intervention23600996
187 Obersztyn A, Kolwinski K. Amine fluoride gel in a caries prophylaxis program for soldiers in Poland. Community Dent Oral Epidemiol. 1984;12(5):288–91. doi: 10.1111/j.1600–0528.1984.tb01457.x. PMID: 6593147. Exclusion reason: Ineligible intervention6593147
188 Ojima M, Hanioka T, Kuboniwa M, Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291–8. doi: 10.1080/14639230310001617823. PMID: 14668131. Exclusion reason: Ineligible intervention14668131
189 Oliveira BH, Cunha-Cruz J, Rajendra A, Controlling caries in exposed root surfaces with silver diamine fluoride: A systematic review with meta-analysis. J Am Dent Assoc. 2018 Aug;149(8):671–9.e1. doi: 10.1016/j.adaj.2018.03.028. PMID: 29805039. Exclusion reason: Used as source document29805039
190 Oliveira LM, Pazinatto J, Zanatta FB. Are oral hygiene instructions with aid of plaque-disclosing methods effective in improving self-performed dental plaque control? A systematic review of randomized controlled trials. Int J Dent Hyg. 2021 Aug;19(3):239–54. doi: 10.1111/idh.12491. PMID: 33638295. Exclusion reason: Ineligible intervention33638295
191 Orlandi M, Graziani F, D'Aiuto F. Periodontal therapy and cardiovascular risk. Periodontology 2000. 2020 06;83(1):107–24. doi: 10.1111/prd.12299. PMID: 32385887. Exclusion reason: Ineligible study design32385887
192 Ortiz MI G, Ribeiro ME S, Lima D, Compliance of Randomized Clinical Trials on Dental Caries Prevention Methods with the Consort Statement: A Systematic Review. J Evid Based Dent Prac. 2021 Jun;21(2):101542. doi: 10.1016/j.jebdp.2021.101542. PMID: 34391554. Exclusion reason: Ineligible outcome34391554
193 Pandis N, Fleming PS, Worthington H, The Quality of the Evidence According to GRADE Is Predominantly Low or Very Low in Oral Health Systematic Reviews. PLoS ONE. 2015;10(7):e0131644. doi: 10.1371/journal.pone.0131644. PMID: 26162076. Exclusion reason: Ineligible outcome26162076
194 Papas A, Russell D, Singh M, Caries clinical trial of a remineralising toothpaste in radiation patients. Gerodontology. 2008;25(2):76–88. doi: 10.1111/j.1741–2358.2007.00199.x. PMID: 18485139. Exclusion reason: Ineligible population18485139
195 Paris S, Banerjee A, Bottenberg P, How to Intervene in the Caries Process in Older Adults: A Joint ORCA and EFCD Expert Delphi Consensus Statement. Caries Res. 2020 Dec 08;54(5–6):1–7. doi: 10.1159/000510843. PMID: 33291110. Exclusion reason: Not a study33291110
196 Parker EJ, Misan G, Chong A, An oral health literacy intervention for Indigenous adults in a rural setting in Australia. BMC Public Health. 2012;12(461)doi: 10.1186/1471–2458-12–461. PMID: 22716205. Exclusion reason: Ineligible study design22716205
197 Parker-Groves D. Should dentists recommend sugar-free chewing gum to help prevent decay? Evid Based Dent. 2020 09;21(3):88. doi: 10.1038/s41432–020-0110-x. PMID: 32978534. Exclusion reason: Ineligible intervention32978534
198 Peldyak J, Makinen KK. Xylitol for caries prevention. J Dent Hyg. 2002;76(4):276–85. PMID: 12592919. Exclusion reason: Ineligible study design12592919
199 Peric TO, Markovic DL, Radojevic VJ, Influence of pastes containing casein phosphopeptide-amorphous calcium phosphate on surface of demineralized enamel. J Appl Biomater Function Mater. 2014 Dec 30;12(3):234–9. doi: 10.5301/jabfm.5000194. PMID: 24700266. Exclusion reason: Ineligible intervention24700266
200 Petelin M, Cotic J, Perkic K, Oral health of the elderly living in residential homes in Slovenia. Gerodontology. 2012 Jun;29(2):e447–57. doi: 10.1111/j.1741–2358.2011.00497.x. PMID: 21615469. Exclusion reason: Ineligible intervention21615469
201 Petersen PE, Nortov B. [The effect of a three-year trial of a community dental care program for aged pensioners in Denmark]. Ugeskr Laeger. 1995 May 08;157(19):2712–6. PMID: 7770970. Exclusion reason: Irretrievable7770970
202 Petersson LG. The role of fluoride in the preventive management of dentin hypersensitivity and root caries. Clin Oral Investig. 2013 Mar;17 Suppl 1:S63–71. doi: 10.1007/s00784–012-0916–9. PMID: 23271217. Exclusion reason: Ineligible outcome23271217
203 Petersson LG, Twetman S, Dahlgren H, Professional fluoride varnish treatment for caries control: a systematic review of clinical trials. Acta Odontol Scand. 2004 Jun;62(3):170–6. doi: 10.1080/00016350410006392. PMID: 15370638. Exclusion reason: Used as source document15370638
204 Pienihakkinen K, Jokela J, Alanen P. Risk-based early prevention in comparison with routine prevention of dental caries: a 7-year follow-up of a controlled clinical trial; clinical and economic aspects. BMC Oral Health. 2005;5(1):2–7. doi: 10.1186/1472–6831-5–2. PMID: 15784155. Exclusion reason: Ineligible intervention15784155
205 Pirie M, Linden G, Irwin C. Intrapregnancy non-surgical periodontal treatment and pregnancy outcome: a randomized controlled trial. J Periodontol. 2013;84(10):1391–400. doi: 10.1902/jop.2012.120572. PMID: 23237583. Exclusion reason: Ineligible population23237583
206 Poulsen S. Fluoride-containing gels, mouth rinses and varnishes: an update of evidence of efficacy. European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2009 Sep;10(3):157–61. doi: 10.1007/BF03262677. PMID: 19772845. Exclusion reason: Used as source document19772845
207 Powell LV, Persson RE, Kiyak HA, Caries prevention in a community-dwelling older population. Caries Res. 1999;33(5):333–9. doi: 10.1159/000016531. PMID: 10460956. Exclusion reason: Ineligible intervention10460956
208 Qin X, Zhao Y, Guo Y. Periodontal disease and myocardial infarction risk: A meta-analysis of cohort studies. Am J Emerg Med. 2021 Apr 08;48:103–9. doi: 10.1016/j.ajem.2021.03.071. PMID: 33866268. Exclusion reason: Ineligible study design33866268
209 Raff A, Hunt LC. Probiotics for periodontal health: a review of the literature. J Dent Hyg. 2012;86(2):71–81. PMID: 22584444. Exclusion reason: Ineligible intervention22584444
210 Rajendra A, Veitz-Keenan A, Oliveira BH, Topical silver diamine fluoride for managing dental caries in children and adults. Cochrane Database Syst Rev. 2017 12 July(7)doi: 10.1002/14651858.Cd012718. Exclusion reason: Not a study
211 Ramesh H, Ashok R, Rajan M, Retention of pit and fissure sealants versus flowable composites in permanent teeth: A systematic review. Heliyon. 2020 Sep;6(9):e04964. doi: 10.1016/j.heliyon.2020.e04964. PMID: 33005790. Exclusion reason: Ineligible comparison33005790
212 Rask PI, Emilson CG, Krasse B, Effect of preventive measures in 50–60-year-olds with a high risk of dental caries. Scand J Dent Res. 1988;96(6):500–4. doi: 10.1111/j.1600–0722.1988.tb01589.x. PMID: 3206197. Exclusion reason: Ineligible comparison3206197
213 Richards D. Substantial reduction in caries from regular fluoride varnish application. Evid Based Dent. 2013 Sep;14(3):72–3. doi: 10.1038/sj.ebd.6400947. PMID: 24071672. Exclusion reason: Not a study24071672
214 Richards DA, Hilli A, Pentecost C, Fundamental nursing care: A systematic review of the evidence on the effect of nursing care interventions for nutrition, elimination, mobility and hygiene. J Clin Nurs. 2018 Jun;27(11–12):2179–88. doi: 10.1111/jocn.14150. PMID: 29156087. Exclusion reason: Ineligible outcome29156087
215 Riley P, Moore D, Ahmed F, Xylitol-containing products for preventing dental caries in children and adults. Cochrane Database Syst Rev. 2015 Mar 26(3):CD010743. doi: 10.1002/14651858.CD010743.pub2. PMID: 25809586. Exclusion reason: Used as source document25809586
216 Ritter AV, Bader JD, Leo MC, Tooth-surface-specific effects of xylitol: randomized trial results. J Dent Res. 2013;92(6):512–7. doi: 10.1177/0022034513487211. PMID: 23589387. Exclusion reason: Ineligible population23589387
217 Ritter AV, Ramos MD, Astorga F, Visual-tactile versus radiographic caries detection agreement in caries-active adults. J Public Health Dent. 2013;73(3):252–60. doi: 10.1111/jphd.12024. PMID: 23772747. Exclusion reason: Ineligible screener23772747
218 Ritter AV, Shugars DA, Bader JD. Root caries risk indicators: a systematic review of risk models. Community Dent Oral Epidemiol. 2010 Oct;38(5):383–97. doi: 10.1111/j.1600–0528.2010.00551.x. PMID: 20545716. Exclusion reason: Ineligible intervention20545716
219 Rock WP. Fissure sealants. Results of a 3-year clinical trial using an ultra-violet sensitive resin. Br Dent J. 1977 Jan 4;142(1):16–8. doi: 10.1038/sj.bdj.4803856. PMID: 318835. Exclusion reason: Ineligible intervention318835
220 Rosen B, Olavi G, Birkhed D, Effect of different frequencies of preventive maintenance treatment on dental caries: five-year observations in general dentistry patients. Acta Odontol Scand. 2004;62(5):282–8. doi: 10.1080/00016350410001757. PMID: 15841817. Exclusion reason: Ineligible intervention15841817
221 Rosenblatt A, Stamford TC, Niederman R. Silver diamine fluoride: a caries "silver-fluoride bullet". J Dent Res. 2009 Feb;88(2):116–25. doi: 10.1177/0022034508329406. PMID: 19278981. Exclusion reason: Ineligible intervention19278981
222 Rosin M, Kramer A, Bradtke D, The effect of a SCN-/H2O2 toothpaste compared to a commercially available triclosan-containing toothpaste on oral hygiene and gingival health -- a 6-month home-use study. J Clin Periodontol. 2002;29(12):1086–91. doi: 10.1034/j.1600–051x.2002.291207.x. PMID: 12492909. Exclusion reason: Ineligible intervention12492909
223 Roxo-Goncalves M, Strey JR, Bavaresco CS, Teledentistry: A Tool to Promote Continuing Education Actions on Oral Medicine for Primary Healthcare Professionals. Telemedicine Journal & E-Health. 2017 04;23(4):327–33. doi: 10.1089/tmj.2016.0101. PMID: 27802117. Exclusion reason: Ineligible outcome27802117
224 Rozas NS, Sadowsky JM, Jeter CB. Strategies to improve dental health in elderly patients with cognitive impairment: A systematic review. J Am Dent Assoc. 2017 04;148(4):236–45.e3. doi: 10.1016/j.adaj.2016.12.022. PMID: 28168970. Exclusion reason: Ineligible intervention28168970
225 Saengtipbovorn S, Taneepanichskul S. Effectiveness of lifestyle change plus dental care (LCDC) program on improving glycemic and periodontal status in the elderly with type 2 diabetes. BMC Oral Health. 2014;14(72)doi: 10.1186/1472–6831-14–72. PMID: 24934646. Exclusion reason: Ineligible population24934646
226 Saffari M, Sanaeinasab H, Mobini M, Effect of a health-education program using motivational interviewing on oral health behavior and self-efficacy in pregnant women: a randomized controlled trial. Eur J Oral Sci. 2020;128(4):308–16. doi: 10.1111/eos.12704. PMID: 32618034. Exclusion reason: Ineligible intervention32618034
227 Sakakibara Y, Morita I, Tsuboi S, [An intervention comparison of dental hygienist visits and leaflet mailing for improvement of oral health scores in village residents]. Nippon Koshu Eisei Zasshi. 2009 Nov;56(11):795–804. PMID: 20077857. Exclusion reason: Irretrievable20077857
228 Saltaji H, Armijo-Olivo S, Cummings GG, Influence of Sponsorship Bias on Treatment Effect Size Estimates in Randomized Trials of Oral Health Interventions: A Meta-epidemiological Study. J Evid Based Dent Prac. 2021 Jun;21(2):101544. doi: 10.1016/j.jebdp.2021.101544. PMID: 34391563. Exclusion reason: Ineligible outcome34391563
229 Saltaji H, Ospina MB, Armijo-Olivo S, Evaluation of risk of bias assessment of trials in systematic reviews of oral health interventions, 1991–2014: A methodology study. J Am Dent Assoc. 2016 09;147(9):720–8.e1. doi: 10.1016/j.adaj.2016.03.017. PMID: 27155754. Exclusion reason: Ineligible outcome27155754
230 Sampson C. Is routine dental prophylaxis effective? Evid Based Dent. 2010;11(1):16–7. doi: 10.1038/sj.ebd.6400704. PMID: 20348893. Exclusion reason: Not a study20348893
231 Savage A, Eaton KA, Moles DR, A systematic review of definitions of periodontitis and methods that have been used to identify this disease. J Clin Periodontol. 2009 Jun;36(6):458–67. doi: 10.1111/j.1600–051X.2009.01408.x. PMID: 19508246. Exclusion reason: Ineligible outcome19508246
232 Saxton CA. The effects of a dentifrice containing zinc citrate and 2,4,4' trichloro-2'-hydroxydiphenyl ether. J Periodontol. 1986;57(9):555–61. doi: 10.1902/jop.1986.57.9.555. PMID: 3463727. Exclusion reason: Ineligible intervention3463727
233 Saxton CA, Huntington E, Cummins D. The effect of dentifrices containing Triclosan on the development of gingivitis in a 21-day experimental gingivitis study. Int Dent J. 1993;43(4 Suppl 1):423–9. PMID: 8282425. Exclusion reason: Ineligible intervention8282425
234 Scheinin A. Xylitol in relation to the incidence of dental caries. Internationale Zeitschrift fur Vitamin und Ernahrungsforschung. Beiheft. 1976;15:358–67. PMID: 1066333. Exclusion reason: Ineligible comparison1066333
235 Scheinin A, Makinen KK, Tammisalo E, Turku sugar studies XVIII. Incidence of dental caries in relation to 1-year consumption of xylitol chewing gum. Acta Odontol Scand. 1975;33(5):269–78. doi: 10.3109/00016357509004632. PMID: 1067728. Exclusion reason: Ineligible comparison1067728
236 Schwartz N, Kaye EK, Nunn ME, High-fiber foods reduce periodontal disease progression in men aged 65 and older: the Veterans Affairs normative aging study/Dental Longitudinal Study. Journal of the American Geriatrics Society. 2012 Apr;60(4):676–83. doi: 10.1111/j.1532–5415.2011.03866.x. PMID: 22316111. Exclusion reason: Ineligible study design22316111
237 Seifo N, Cassie H, Radford JR, Silver diamine fluoride for managing carious lesions: an umbrella review. BMC Oral Health. 2019 07 12;19(1):145. doi: 10.1186/s12903–019-0830–5. PMID: 31299955. Exclusion reason: Used as source document31299955
238 Shapira L, Shapira M, Tandlich M, Effect of amine fluoride-stannous fluoride containing toothpaste (Meridol) on plaque and gingivitis in adults: a six-month clinical study. Journal of the International Academy of Periodontology. 1999;1(4):117–20. PMID: 12666956. Exclusion reason: Ineligible intervention12666956
239 Shokouhi E, Mohamadian H, Babadi F, Improvement in oral health related quality of life among the elderly: a randomized controlled trial. Biopsychosoc Med. 2019;13:31. doi: 10.1186/s13030–019-0170–3. PMID: 31827601. Exclusion reason: Ineligible intervention31827601
240 Sicca C, Bobbio E, Quartuccio N, Prevention of dental caries: A review of effective treatments. Journal of Clinical & Experimental Dentistry. 2016 Dec;8(5):e604–e10. doi: 10.4317/jced.52890. PMID: 27957278. Exclusion reason: Used as source document27957278
241 Singh SM, Petrone ME, Volpe AR, Comparison of the anticalculus effect of two soluble pyrophosphate dentifrices with and without a copolymer. J Clin Dent. 1990;2(2):53–5. PMID: 1965290. Exclusion reason: Ineligible intervention1965290
242 Slot DE, Van der Weijden F. Insufficient evidence to determine the effects of routine scale and polish treatments. Evid Based Dent. 2014 Sep;15(3):74–5. doi: 10.1038/sj.ebd.6401039. PMID: 25343389. Exclusion reason: Not a study25343389
243 Snoad R. Description of a system designed to assist primary dental care clinicians in decision-making with regard to specialist periodontal referrals and report of two clinical audits using the system. Prim Dent care. 2005 Oct;12(4):135–41. doi: 10.1308/135576105774342938. PMID: 16212824. Exclusion reason: Ineligible outcome16212824
244 Soderstrom U, Johansson I, Sunnegardh-Gronberg K. A retrospective analysis of caries treatment and development in relation to assessed caries risk in an adult population in Sweden. BMC Oral Health. 2014 Oct 17;14:126. doi: 10.1186/1472–6831-14–126. PMID: 25326206. Exclusion reason: Ineligible intervention25326206
245 Sohn S, Yi K, Son HH, Caries-preventive activity of fluoride-containing resin-based desensitizers. Oper Dent. 2012 May-Jun;37(3):306–15. doi: 10.2341/11–007-L. PMID: 22313280. Exclusion reason: Ineligible population22313280
246 Sohn W, Ismail AI, Tellez M. Efficacy of educational interventions targeting primary care providers' practice behaviors: an overview of published systematic reviews. J Public Health Dent. 2004;64(3):164–72. doi: 10.1111/j.1752–7325.2004.tb02747.x. PMID: 15341140. Exclusion reason: Ineligible intervention15341140
247 Soldani FA, Lamont T, Jones K, One-to-one oral hygiene advice provided in a dental setting for oral health. Cochrane Database Syst Rev. 2018(10)doi: 10.1002/14651858.CD007447.pub2. PMID: 30380139. Exclusion reason: Ineligible intervention30380139
248 Souza ML, Cury JA, Tenuta LM, Comparing the efficacy of a dentifrice containing 1.5% arginine and 1450 ppm fluoride to a dentifrice containing 1450 ppm fluoride alone in the management of primary root caries. J Dent. 2013;41(2)doi: 10.1016/j.jdent.2010.04.006. PMID: 23985437. Exclusion reason: Ineligible intervention23985437
249 Steinberg LM, Odusola F, Mandel ID. Remineralizing potential, antiplaque and antigingivitis effects of xylitol and sorbitol sweetened chewing gum. Clin Prev Dent. 1992;14(5):31–4. PMID: 1291185. Exclusion reason: Ineligible outcome1291185
250 Stephen KW. A four-year fissure sealing study in fluoridated and non-fluoridated Galloway. Health Bull (Edinb). 1978 May;36(3):138–45. PMID: 659106. Exclusion reason: Poor quality659106
251 Stookey GK. Current status of caries prevention. Compend Contin Educ Dent. 2000 Oct;21(10A):862–7; quiz 8. PMID: 11908363. Exclusion reason: Not a study11908363
252 Strohmenger L, Brambilla E. The use of fluoride varnishes in the prevention of dental caries: a short review. Oral Dis. 2001 Mar;7(2):71–80. doi: 10.1034/j.1601–0825.2001.70202.x. PMID: 11355442. Exclusion reason: Used as source document11355442
253 Subbiah GK, Gopinathan NM. Is Silver Diamine Fluoride Effective in Preventing and Arresting Caries in Elderly Adults? A Systematic Review. J Int Soc Prev Community Dent. 2018 May-Jun;8(3):191–9. doi: 10.4103/jispcd.JISPCD_99_18. PMID: 29911054. Exclusion reason: Used as source document29911054
254 Subramanian S, Emami H, Vucic E, High-dose atorvastatin reduces periodontal inflammation: a novel pleiotropic effect of statins. Journal of the American College of Cardiology. 2013;62(25):2382–91. doi: 10.1016/j.jacc.2013.08.1627. PMID: 24070911. Exclusion reason: Ineligible intervention24070911
255 Sun Y, Gao CZ. [Effect of dental varnish containing fluoride either with CPP-ACP or bioglass on root caries]. Shanghai Kou Qiang Yi Xue/Shanghai Journal of Stomatology. 2020 Feb;29(1):46–50. doi: 10.19439/j.sjos.2020.01.009. PMID: 32524120. Exclusion reason: Ineligible comparison32524120
256 Susanto H, Nesse W, Kertia N, Prevalence and severity of periodontitis in Indonesian patients with rheumatoid arthritis. J Periodontol. 2013 Aug;84(8):1067–74. doi: 10.1902/jop.2012.110321. PMID: 23075431. Exclusion reason: Ineligible study design23075431
257 Svatun B, Sadxton CA, Huntington E, The effects of three silica dentifrices containing Triclosan on supragingival plaque and calculus formation and on gingivitis. Int Dent J. 1993;43(4 Suppl 1):441–52. PMID: 8282427. Exclusion reason: Ineligible intervention8282427
258 Svatun B, Saxton CA, Huntington E, The effects of a silica dentifrice containing Triclosan and zinc citrate on supragingival plaque and calculus formation and the control of gingivitis. Int Dent J. 1993;43(4 Suppl 1):431–9. PMID: 8282426. Exclusion reason: Ineligible intervention8282426
259 Svatun B, Saxton CA, Rolla G. Six-month study of the effect of a dentifrice containing zinc citrate and triclosan on plaque, gingival health, and calculus. Scand J Dent Res. 1990;98(4):301–4. doi: 10.1111/j.1600–0722.1990.tb00976.x. PMID: 2399425. Exclusion reason: Ineligible intervention2399425
260 Svatun B, Saxton CA, Rolla G, A 1-year study on the maintenance of gingival health by a dentifrice containing a zinc salt and non-anionic antimicrobial agent. J Clin Periodontol. 1989 Feb;16(2):75–80. doi: 10.1111/j.1600–051x.1989.tb01617.x. PMID: 2921376. Exclusion reason: Not a study2921376
261 Svatun B, Saxton CA, van der Ouderaa F, The influence of a dentifrice containing a zinc salt and a nonionic antimicrobial agent on the maintenance of gingival health. J Clin Periodontol. 1987;14(8):457–61. doi: 10.1111/j.1600–051x.1987.tb02251.x. PMID: 3308970. Exclusion reason: Ineligible intervention3308970
262 Swedish Council on Health Technology A. Swedish Council on Health Technology Assessment (SBU). 2004 10;169:10. PMID: 28876734. Exclusion reason: Not a study28876734
263 Sweeney MP, Williams C, Kennedy C, Oral health care and status of elderly care home residents in Glasgow. Community Dent Health. 2007 Mar;24(1):37–42. PMID: 17405469. Exclusion reason: Ineligible study design17405469
264 Symington JM, Perry R, Kumar A, Efficacy of a 10% chlorhexidine coating to prevent caries in at-risk community-dwelling adults. Acta Odontol Scand. 2014;72(7):497–501. doi: 10.3109/00016357.2013.871647. PMID: 24460033. Exclusion reason: Ineligible intervention24460033
265 Tan HH, Ruiter E, Verhey H. Effects of repeated dental health care education on gingival health, knowledge, attitude, behavior and perception. Community Dent Oral Epidemiol. 1981 Feb;9(1):15–21. doi: 10.1111/j.1600–0528.1981.tb01022.x. PMID: 6941872. Exclusion reason: Ineligible intervention6941872
266 Tellez M, Gomez J, Kaur S, Non-surgical management methods of noncavitated carious lesions. Community Dent Oral Epidemiol. 2013 Feb;41(1):79–96. doi: 10.1111/cdoe.12028. PMID: 23253076. Exclusion reason: Ineligible study design23253076
267 Tellez M, Gomez J, Pretty I, Evidence on existing caries risk assessment systems: are they predictive of future caries? Community Dent Oral Epidemiol. 2013 Feb;41(1):67–78. doi: 10.1111/cdoe.12003. PMID: 22978796. Exclusion reason: Used as source document22978796
268 Teufer B, Sommer I, Nussbaumer-Streit B, Screening for periodontal diseases by non-dental health professionals: a protocol for a systematic review and overview of reviews. Syst. 2019 02 25;8(1):61. doi: 10.1186/s13643–019-0977–9. PMID: 30803450. Exclusion reason: Ineligible outcome30803450
269 Tikhonova SM, Feine JS, Pustavoitava NN, Reproducibility and diagnostic outcomes of two visual-tactile criteria used by dentists to assess caries lesion activity: a cross-over study. Caries Res. 2014;48(2):126–36. doi: 10.1159/000353094. PMID: 24335157. Exclusion reason: Ineligible screener24335157
270 Tomuro K. Development of oral home telecare programme for the home-dwelling elderly: a pilot study. Gerodontology. 2004 Sep;21(3):177–80. doi: 10.1111/j.1741–2358.2004.00021.x. PMID: 15369021. Exclusion reason: Ineligible outcome15369021
271 Toniazzo MP, Nodari D, Muniz F, Effect of mHealth in improving oral hygiene: A systematic review with meta-analysis. J Clin Periodontol. 2019 03;46(3):297–309. doi: 10.1111/jcpe.13083. PMID: 30761580. Exclusion reason: Ineligible outcome30761580
272 Toyama N, Taniguchi-Tabata A, Sawada N, Does Instruction of Oral Health Behavior for Workers Improve Work Performance?-Quasi-Randomized Trial. Int J Environ Res Public Health. 2018;15(12)doi: 10.3390/ijerph15122630. PMID: 30477210. Exclusion reason: Ineligible intervention30477210
273 Triratana T, Rustogi KN, Volpe AR, Clinical effect of a new liquid dentifrice containing triclosan/copolymer on existing plaque and gingivitis. J Am Dent Asoc. 2002;133(2):219–25. doi: 10.14219/jada.archive.2002.0147. PMID: 11868841. Exclusion reason: Ineligible intervention11868841
274 Twetman S. Consistent evidence to support the use of xylitol- and sorbitol-containing chewing gum to prevent dental caries. Evid Based Dent. 2009;10(1):10–1. doi: 10.1038/sj.ebd.6400626. PMID: 19322219. Exclusion reason: Not a study19322219
275 Twetman S, Keller MK. Fluoride Rinses, Gels and Foams: An Update of Controlled Clinical Trials. Caries Res. 2016;50 Suppl 1:38–44. doi: 10.1159/000439180. PMID: 27101002. Exclusion reason: Used as source document27101002
276 Vandamme K, Opdebeeck H, Naert I. Pathways in multidisciplinary oral health care as a tool to improve clinical performance. Int J Prosthodont. 2006;19(3):227–35. PMID: 16752617. Exclusion reason: Ineligible outcome16752617
277 Vargas JP, Uribe M, Ortuno D, Silver diamine fluoride compared to atraumatic restorative technique for the treatment of caries in primary and mixed first phase dentition. Medwave. 2020 Aug 25;20(7):e8003. doi: 10.5867/medwave.2020.07.8002. PMID: 32877393. Exclusion reason: Not in English32877393
278 Vasiliauskiene I, Milciuviene S, Bendoraitiene E, Dynamics of pregnant women's oral health status during preventive programme. Stomatologija /issued by public institution "Odontologijos studija." 2007;[]. 9(4):129–36. PMID: 18303278. Exclusion reason: Ineligible intervention18303278
279 Vasquez-Morales A, Sanz-Valero J. [Health promotions interventions designed and implemented in aged people over 65 years: a systematic review]. Rev Enferm. 2011 Nov;34(11):16–24. PMID: 25546897. Exclusion reason: Ineligible intervention25546897
280 Walls AW, Meurman JH. Approaches to caries prevention and therapy in the elderly. Adv Dent Res. 2012 Sep;24(2):36–40. doi: 10.1177/0022034512453590. PMID: 22899677. Exclusion reason: Not a study22899677
281 Watt RG. Motivational interviewing may be effective in dental setting. Evid Based Dent. 2010;11(1):13. doi: 10.1038/sj.ebd.6400702. PMID: 20348891. Exclusion reason: Not a study20348891
282 Watthanasaen S, Merchant AT, Luengpailin S, Xylitol-containing Chewing Gum for Caries Prevention in Students with Disabilities: a Randomised Trial. Oral Health Prev. 2017;15(6):519–27. doi: 10.3290/j.ohpd.a39668. PMID: 29319061. Exclusion reason: Ineligible intervention29319061
283 Werner H, Hakeberg M, Dahlström L, Psychological Interventions for Poor Oral Health: A Systematic Review. J Dent Res. 2016 May;95(5):506–14. doi: 10.1177/0022034516628506. PMID: 26826109. Exclusion reason: Used as source document26826109
284 Winand C, Shetty A, Senior A, Digital Imaging Capability for Caries Detection: A Metaanalysis. JDR Clin Trans Res. 2016 Jul;1(2):112–21. doi: 10.1177/2380084416645291. PMID: 30931795. Exclusion reason: Ineligible intervention30931795
285 Wolff LF, Pihlstrom BL, Bakdash MB, Effect of toothbrushing with 0.4% stannous fluoride and 0.22% sodium fluoride gel on gingivitis for 18 months. J Am Dent Asoc. 1989;119(2):283–9. doi: 10.14219/jada.archive.1989.0209. PMID: 2768695. Exclusion reason: Ineligible intervention2768695
286 Wu L, Geng K, Gao Q. Early Caries Preventive Effects of Casein Phosphopeptide-Amorphous Calcium Phosphate (CPP-ACP) Compared with Conventional Fluorides: A Meta-analysis. Oral Health Prev. 2019;17(6):495–503. doi: 10.3290/j.ohpd.a43637. PMID: 31825022. Exclusion reason: Ineligible comparison31825022
287 Wyatt CC, MacEntee MI. Caries management for institutionalized elders using fluoride and chlorhexidine mouthrinses. Community Dent Oral Epidemiol. 2004;32(5):322–8. doi: 10.1111/j.1600–0528.2004.00176.x. PMID: 15341616. Exclusion reason: Ineligible intervention15341616
288 Yengopal V, Mickenautsch S. Caries-preventive effect of resin-modified glass-ionomer cement (RM-GIC) versus composite resin: a quantitative systematic review. European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2011 Feb;12(1):5–14. doi: 10.1007/BF03262772. PMID: 21299939. Exclusion reason: Ineligible outcome21299939
289 Yengopal V, Mickenautsch S, Bezerra AC, Caries-preventive effect of glass ionomer and resin-based fissure sealants on permanent teeth: a meta analysis. J Oral Sci. 2009 Sep;51(3):373–82. doi: 10.2334/josnusd.51.373. PMID: 19776504. Exclusion reason: Ineligible comparison19776504
290 Yevlahova D, Satur J. Models for individual oral health promotion and their effectiveness: a systematic review. Aust Dent J. 2009 Sep;54(3):190–7. doi: 10.1111/j.1834–7819.2009.01118.x. PMID: 19709105. Exclusion reason: Used as source document19709105
291 Yuen HK, Weng Y, Bandyopadhyay D, Effect of a multi-faceted intervention on gingival health among adults with systemic sclerosis. Clinical and Experimental Rheumatology. 2011;29(2 Suppl 65):S26–32. PMID: 21586215. Exclusion reason: Ineligible population21586215
292 Zanatta RF, Caneppele TM F, Scaramucci T, Protective effect of fluorides on erosion and erosion/abrasion in enamel: a systematic review and meta-analysis of randomized in situ trials. Arch Oral Biol. 2020 Dec;120:104945. doi: 10.1016/j.archoralbio.2020.104945. PMID: 33113459. Exclusion reason: Ineligible outcome33113459
293 Zandona AF, Zero DT. Diagnostic tools for early caries detection. J Am Dent Assoc. 2006 Dec;137(12):1675–84; quiz 730. doi: 10.14219/jada.archive.2006.0113. PMID: 17138712. Exclusion reason: Not a study17138712
294 Zhang J, Sardana D, Li KY, Topical Fluoride to Prevent Root Caries: Systematic Review with Network Meta-analysis. J Dent Res. 2020 May;99(5):506–13. doi: 10.1177/0022034520906384. PMID: 32142400. Exclusion reason: Used as source document32142400
295 Ziebolz D, Herz A, Brunner E, Individual versus group oral hygiene instruction for adults. Oral Health Prev. 2009;7(1):93–9. doi: 10.3290/j.ohpd.a15273. PMID: 19408821. Exclusion reason: Ineligible comparison19408821

## Appendix A6 Criteria for Assessing Internal Validity of Individual Studies

Design | Criteria | Definition of good | Definition of fair | Definition of poor
Systematic reviews | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance (especially important for systematic reviews) | Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions | Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies | Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies
RCTS and cohort studies | - Initial assembly of comparable groups:; ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; ○ For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination); - Important differential loss to follow up or overall high loss to follow up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of interventions; - All important outcomes considered; - Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow up ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs. | Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with follow up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs. | Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.
Diagnostic Accuracy Studies | - Screening test relevant, available for primary care, and adequately described; - Credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Indeterminate results handled in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Reliable screening test | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients | Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Source: U.S. Preventive Services Task Force. Procedure Manual. Accessed at https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-appendix-vi-criteria-assessing-internal-validity-individual-studies

## Appendix A7 Expert Reviewers of the Draft Report

Hugh Silk, MD, MPH, Professor, Department of Family Medicine and Community Health, University of Massachusetts Medical School

Robert Weyant, MD, MDM, DrPH, Associate Dean, University of Pittsburgh School of Dental Medicine; Chair, Department of Dental Public Health

Christine Riedy, PhD, MPH, Chair and Associate Professor, Department of Oral Health Policy and Epidemiology, Harvard School of Dental Medicine

Federal Partners

- The Centers for Disease Control and Prevention (1 reviewer)
- The National Institute of Dental and Craniofacial Research (3 reviewers)